# Excluded Systematic Reviews List

Code | Definition
AP | Adults – pharmacological
AB | Adults – behavioral
AC | Adults – combined
AM | Adults – mental
PWP | Pregnant women – pharmacological
PWB | Pregnant women – behavioral
PWC | Pregnant women – combined
PPP | Pregnant women – pharmacological (from primary studies search)
ENDS | Electronic nicotine delivery systems

Exclusion Code | Definition
E1 | Study aim not relevant
E2a | Not a systematic review
E2b | Does not describe search dates AND search databases AND search string
E2c | Does not indicate criteria used to select studies for inclusion
E2d | Review of reviews
E3a | Population: ≥50% of studies included focus on children and adolescents, and stratified results not presented
E3b | Population: > 50% of the included studies focus on groups not generalizable to primary care (e.g., COPD), and stratified results not presented
E4 | Intervention: Not a relevant intervention (e.g., systems-level, broad public health intervention, harm reduction, second-line or off-label medications, relapse prevention)
E5 | Setting: > 50% of the included studies take place in settings not applicable to primary care (e.g., worksites, specialty care), and stratified results not presented
E6 | Outcomes: No relevant outcomes (exclude reviews that only report tobacco reduction; reduction in withdrawal symptoms; attitudes, knowledge, beliefs; intentions; etc.)
E7 | Outcome Assessment: > 50% of the included studies report outcomes at < 6 months follow up, and stratified results not presented (does not apply for KQ3/harms data)
E8 | Country: > 50% of included studies take place in countries not on the “Very High” list for Human Development: Andorra, Argentina, Australia, Austria, Barbados, Belgium, Brunei Darussalam, Canada, Chile, Croatia, Cyprus, Czech Republic, Denmark, Estonia, Finland, France, Germany, Greece, Hong Kong, Hungary, Iceland, Ireland, Israel, Italy, Japan, Korea, Latvia, Liechtenstein, Lithuania, Luxembourg, Malta, Netherlands, New Zealand, Norway, Poland, Portugal, Qatar, Seychelles, Singapore, Slovakia, Slovenia, Spain, Sweden, Switzerland, United Arab Emirates, United Kingdom, United States
E9 | Review published in language other than English
E10 | All included studies are included in a more comprehensive, more recent, or higher quality ESR
E11 | Poor quality rating

1 Adkison SE, O'Connor RJ, Bansal-Travers M, et al. Electronic nicotine delivery systems: international tobacco control four-country survey. Am J Prev Med. Mar. 2013;44(3):207-15. ENDSE2. [pmid: 23415116].
2 Adriaens K, Van GD, Declerck P, et al. Effectiveness of the Electronic Cigarette: An Eight-Week Flemish Study with Six-Month Follow-up on Smoking Reduction, Craving and Experienced Benefits and Complaints. Int J Environ Res Public Health. 2014;11(11):11220-48. ENDSE2. [pmid: 25358095].
3 Ahmed AI, Ali AN, Kramers C, et al. Neuropsychiatric adverse events of varenicline: a systematic review of published reports. J Clin Psychopharmacol. Feb. 2013;33(1):55-62. AME2a. [pmid: 23277249].
4 Apollonio D, Philipps R, Bero L. Interventions for tobacco use cessation in people in treatment for or recovery from substance abuse. Cochrane Database of Systematic Reviews. 2012. AME2.
5 Asfar T, Ebbert JO, Klesges RC, et al. Do smoking reduction interventions promote cessation in smokers not ready to quit?. Addictive Behaviors. 2011;36(7):764-8. ACE4. [pmid: 21420791].
6 Baxter S, Blank L, Guillaume L, et al. Systematic review of how to stop smoking in pregnancy and following childbirth. United Kingdom. University of Sheffield School of Health and Related Research (ScHARR). 2009. PWCE6.
7 Bennett ME, Wilson AL, Genderson M, et al. Smoking Cessation in People with Schizophrenia. Curr Drug Abuse Rev. 2013. May. 30. AME2a. [pmid: 23721094].
8 Bullen C, McRobbie H, Thornley S, et al. Effect of an electronic nicotine delivery device (e cigarette) on desire to smoke and withdrawal, user preferences and nicotine delivery: randomised cross-over trial. Tob Control. Apr. 2010;19(2):98-103. ENDSE6. [pmid: 20378585].
9 Bullen C, Howe C, Laugesen M, et al. Electronic cigarettes for smoking cessation: a randomised controlled trial. Lancet. 2013. Sep. 9. ENDSI1. [pmid: 24029165].
10 Cahill K, Stevens S, Perera R, et al. Pharmacological interventions for smoking cessation: an overview and network meta-analysis. Cochrane Database Syst Rev. 2013;5. CD009329. APE2d. [pmid: 23728690].
11 Cahill K, Stevens S, Lancaster T. Pharmacological treatments for smoking cessation. JAMA. Jan. 8. 2014;311(2):193-4. APE2a. [pmid: 24399558].
12 Canadian Agency for Drugs and Technologies in Health. Varenicline for smoking cessation in patients with psychiatric illness: a review of the risks. 2010. AME2a.
13 Canadian Agency for Drugs and Technologies in Health. Smoking cessation interventions for pregnant women and mothers of infants: a review of the clinical effectiveness, safety, and guidelines. 2012. PWCE2a.
14 Canadian Agency for Drugs and Technologies in Health. Nicotine Replacement Therapy for Smoking Cessation or Reduction: A Review of the Clinical Evidence. 2014. [pmid: 24741730]. APE2a.
15 Caponnetto P, Campagna D, Cibella F, et al. EffiCiency and Safety of an eLectronic cigAreTte (ECLAT) as tobacco cigarettes substitute: a prospective 12-month randomized control design study. PLoS ONE. 2013;8(6):e66317. ENDSI1. [pmid: 23826093].
16 Caponnetto P, Auditore R, Russo C, et al. Impact of an electronic cigarette on smoking reduction and cessation in schizophrenic smokers: a prospective 12-month pilot study. Int J Environ Res Public Health. Feb. 2013;10(2):446-61. ENDSE2. [pmid: 23358230].
17 Carim-Todd L, Mitchell SH, Oken BS. Mind-body practices: An alternative, drug-free treatment for smoking cessation? A systematic review of the literature. Drug Alcohol Depend. 2013. May. 7. ABE6. [pmid: 23664122].
18 Choi K, Forster JL. Beliefs and experimentation with electronic cigarettes: a prospective analysis among young adults. Am J Prev Med. Feb. 2014;46(2):175-8. ENDSE2. [pmid: 24439352].
19 Coleman T, Agboola S, Leonardi-Bee J, et al. Relapse prevention in UK stop smoking services: current practice, systematic reviews of effectiveness and cost-effectiveness analysis. Health Technology Assessment. 2010;14(49):1-152. ACE4, PWCE4. [pmid: 21040645].
20 Coleman T, Chamberlain C, Cooper S, et al. Efficacy and safety of nicotine replacement therapy for smoking cessation in pregnancy: systematic review and meta-analysis. Addiction. 2011;106(1):52-61. PWPE10. [pmid: 21054620].
21 Coleman T, Cooper S, Thornton JG, et al. A randomized trial of nicotine-replacement therapy patches in pregnancy. New England Journal of Medicine. Mar. 1. 2012;366(9):808-18. PPPE8. [pmid: 22375972].
22 Dai CL, Sharma M. Between inhale and exhale: yoga as an intervention in smoking cessation. J Evid Based Complementary Altern Med. Apr. 2014;19(2):144-9. ABE6. [pmid: 24647095].
23 Dawkins L, Turner J, Hasna S, et al. The electronic-cigarette: effects on desire to smoke, withdrawal symptoms and cognition. Addictive Behaviors. 2012;37(8):970-3. ENDSE6. [pmid: 22503574].
24 Dawkins L, Turner J, Roberts A, et al. ‘Vaping’ profiles and preferences: an online survey of electronic cigarette users. Addiction. Jun. 2013;108(6):1115-25. ENDSE2. [pmid: 23551515].
25 Dornelas E, Oncken C, Greene J, et al. Major depression and PTSD in pregnant smokers enrolled in nicotine gum treatment trial. American Journal on Addictions. Jan. 2013;22(1):54-9. PPPE6. [pmid: 23398227].
26 El-Mohandes AA, Windsor R, Tan S, et al. A randomized clinical trial of trans-dermal nicotine replacement in pregnant African-American smokers. Maternal & Child Health Journal. Jul. 2013;17(5):897-906. PPPE8. [pmid: 22761006].
27 Ellery B, Hiller JE. Quit onQ SMS for smoking cessation support for individuals. 2010. ABE2a.
28 Etter JF. Electronic cigarettes: a survey of users. BMC Public Health. 2010;10:231. ENDSE2. [pmid: 20441579].
29 Etter JF, Bullen C. Electronic cigarette: users profile, utilization, satisfaction and perceived efficacy. Addiction. Nov. 2011;106(11):2017-28. ENDSE2. [pmid: 21592253].
30 Etter JF, Bullen C. A longitudinal study of electronic cigarette users. Addict Behav. Feb. 2014;39(2):491-4. ENDSE2. [pmid: 24229843].
31 Fagerstrom K, Nakamura M, Cho HJ, et al. Varenicline treatment for smoking cessation in Asian populations: a pooled analysis of placebo-controlled trials conducted in six Asian countries. Curr Med Res Opin. Sep. 2010;26(9):2165-73. APE2b. [pmid: 20666691].
32 Farsalinos KE, Romagna G, Tsiapras D, et al. Evaluating nicotine levels selection and patterns of electronic cigarette use in a group of “vapers” who had achieved complete substitution of smoking. Subst Abuse. 2013;7:139-46. ENDSE2. [pmid: 24049448].
33 Farsalinos KE, Romagna G, Tsiapras D, et al. Evaluation of electronic cigarette use (vaping) topography and estimation of liquid consumption: implications for research protocol standards definition and for public health authorities' regulation. Int J Environ Res Public Health. Jun. 2013;10(6):2500-14. ENDSE6. [pmid: 23778060].
34 Ferguson J, Docherty G, Bauld L, et al. Effect of offering different levels of support and free nicotine replacement therapy via an English national telephone quitline: randomised controlled trial. BMJ. 2012;344:e1696. PPPE3. [pmid: 22446739].
35 Ferron JC, Alterman AI, McHugo GJ, et al. A review of research on smoking cessation interventions for adults with schizophrenia spectrum disorders. Mental Health and Substance Use. 2009;2(1):64-79. PMID: none. AME11.
36 Foulds J, Veldheer S, Berg A. Electronic cigarettes (e-cigs): views of aficionados and clinical/public health perspectives. Int J Clin Pract. Oct. 2011;65(10):1037-42. ENDSE2. [pmid: 21801287].
37 Gierisch JM, Bastian LA, Calhoun PS, et al. Smoking cessation interventions for patients with depression: a systematic review and meta-analysis. Journal of General Internal Medicine. 2012;27(3):351-60. AME10. [pmid: 22038468].
38 Goniewicz ML, Lingas EO, Hajek P. Patterns of electronic cigarette use and user beliefs about their safety and benefits: an internet survey. Drug Alcohol Rev. Mar. 2013;32(2):133-40. ENDSE2. [pmid: 22994631].
39 Grana R, Popova L, Ling PM. A Longitudinal Analysis of Electronic Cigarette Use and Smoking Cessation. JAMA. Mar. 24. 2014;174(5):812-3. ENDSE2. [pmid: 24664434].
40 Hajek P, Stead LF, West R, et al. Relapse prevention interventions for smoking cessation. Cochrane Database of Systematic Reviews: Reviews. 2009;(1). ACE4. [pmid: 23963584].
41 Hartmann-Boyce J, Stead LF, Cahill K, et al. Efficacy of interventions to combat tobacco addiction: Cochrane update of 2012 reviews. Addiction. Jul. 9. 2013;108(10):1711-21. ACE2a. [pmid: 23834141].
42 HAYES. Smoking cessation in patients with schizophrenia. 2014. AME2a.
43 Hayes Inc. Chantix (Varenicline Tartrate) (Pfizer Inc.) for smoking cessation. 2010. APE2a.
44 Hayes Inc. Nicotine replacement therapy for smoking cessation: nicotine patch. 2011. APE2a.
45 Hayes Inc. Bupropion for smoking cessation. 2011. APE2a.
46 Hayes Inc. Nicotine replacement therapy for smoking cessation: nicotine gum and nicotine lozenge. 2011. APE2a.
47 Hayes Inc. Nicotine replacement therapy for smoking cessation: nicotine nasal spray and nicotine inhaler. 2011. APE2a.
48 Heydari G, Masjedi M, Ahmady AE, et al. A comparative study on tobacco cessation methods: a quantitative systematic review. Int J Prev Med. Jun. 2014;5(6):673-8. ABE2a, APE2a. [pmid: 25013685].
49 Hind D, Tappenden P, Peters J, et al. Varenicline in the management of smoking cessation: a single technology appraisal. Health Technology Assessment. 2009;13(Suppl 2 Article 2):9-13. PMID: none. APE2a. [pmid: 19804684].
50 Hitsman B, Papandonatos GD, McChargue DE, et al. Past major depression and smoking cessation outcome: a systematic review and meta-analysis update. Addiction. Feb. 2013;108(2):294-306. AME1. [pmid: 23072580].
51 Hoedjes M, Berks D, Vogel I, et al. Effect of postpartum lifestyle interventions on weight loss, smoking cessation, and prevention of smoking relapse: a systematic review. Obstetrical and Gynecological Survey. 2010;65(10):631-52. PWBE11. [pmid: 21182803].
52 Hollands GJ, Vogt F, McDermott MÃ, et al. Interventions to increase adherence to medications for tobacco dependence. Cochrane Database of Systematic Reviews: Reviews. 2011;(6). PMID: none. APE1.
53 Kaur K, Kaushal S, Chopra SC. Varenicline for smoking cessation: A review of the literature. Curr Ther Res Clin Exp. Feb. 2009;70(1):35-54. APE11. [pmid: 24692831].
54 Kimura K, Sairenchi T, Muto T. Meta-analysis study for one year effects of a nicotine patch. Journal of Health Science. 2009;55(2):233-41. PMID: None. APE11.
55 Kitikannakorn N, Chaiyakunapruk N, Nimpitakpong P, et al. An overview of the evidences of herbals for smoking cessation. Complementary Therapies in Medicine. 2013;21(5):557-64. ABE7. [pmid: 24050594].
56 Lorencatto F, West R, Michie S. Specifying evidence-based behavior change techniques to aid smoking cessation in pregnancy. Nicotine Tob Res. Sep. 2012;14(9):1019-26. PWBE2a. [pmid: 22318690].
57 Louik C, Kerr S, Mitchell AA. First-trimester exposure to bupropion and risk of cardiac malformations. Pharmacoepidemiol Drug Saf. Jun. 12. 2014;344:e1696. PPPE2. [pmid: 24920293].
58 Mantler T, Irwin JD, Morrow D. Motivational interviewing and smoking behaviors: a critical appraisal and literature review of selected cessation initiatives. Psychol Rep. Apr. 2012;110(2):445-60. ABE11. [pmid: 22662398].
59 Manzoli L, La VC, Flacco ME, et al. Multicentric cohort study on the long-term efficacy and safety of electronic cigarettes: study design and methodology. BMC Public Health. 2013;13:883. ENDSE2. [pmid: 24063569].
60 Mdege ND, Chindove SE-MA, Mdege NDnmacu. Effectiveness of tobacco use cessation interventions delivered by pharmacy personnel: A systematic review. [References]. Research in Social & Administrative Pharmacy. Jan. 2014;10(1):21-44. ABE4, APE4, ACE4. [pmid: 23743504].
61 Mitchell MD, Leone F, Williams K. Varenicline for smoking cessation. 2009. APE11.
62 Napierkowski D. Acupuncture and related interventions for smoking cessation. International Journal of Evidence-Based Healthcare. 2012;10(2):162-3. PMID: None. ABE2a.
63 National Institute for Health and Care Excellence. Quitting smoking in pregnancy and following childbirth. London. National Institute for Health and Care Excellence. 2010. PWCE2a.
64 Okoli CT, Torchalla I, Oliffe JL, et al. Men's smoking cessation interventions: a brief review. Journal of Men's Health. 2011;8(2):100-8. PMID: None. ACE11.
65 Oncken C. Nicotine replacement for smoking cessation during pregnancy. [References]. The New England Journal of Medicine. Mar. 2012;366(9):846-7. PPPE2. [pmid: 22375978].
66 Polosa R, Caponnetto P, Morjaria JB, et al. Effect of an electronic nicotine delivery device (e-Cigarette) on smoking reduction and cessation: a prospective 6-month pilot study. BMC Public Health. 2011;11:786. ENDSE2. [pmid: 21989407].
67 Polosa R, Morjaria JB, Caponnetto P, et al. Effectiveness and tolerability of electronic cigarette in real-life: a 24-month prospective observational study. Intern Emerg Med. 2013. Jul. 20. ENDSE2. [pmid: 23873169].
68 Popova L, Ling PM. Alternative tobacco product use and smoking cessation: a national study. Am J Public Health. May. 2013;103(5):923-30. ENDSE2. [pmid: 23488521].
69 Regan AK, Promoff G, Dube SR, et al. Electronic nicotine delivery systems: adult use and awareness of the ‘e-cigarette’ in the USA. Tob Control. Jan. 2013;22(1):19-23. ENDSE2. [pmid: 22034071].
70 Rooke S, Thorsteinsson E, Karpin A, et al. Computer-delivered interventions for alcohol and tobacco use: a meta-analysis. Addiction. Aug. 2010;105(8):1381-90. ABE6. [pmid: 20528806].
71 Rosen LJ, Noach MB, Winickoff JP, et al. Parental smoking cessation to protect young children: a systematic review and meta-analysis. Pediatrics. 2012;129(1):141-52. ABE1, X2. [pmid: 22201152].
72 Rutqvist LE, Fry JS, Lee PN. Systematic review of Swedish snus for smoking cessation based on primary subject data from randomised clinical trials. Journal of Smoking Cessation. 2013;8(1):33-44. PMID: none. ABE4.
73 Saba M, Diep J, Saini B, et al. Meta-analysis of the effectiveness of smoking cessation interventions in community pharmacy. J Clin Pharm Ther. Jun. 2014;39(3):240-7. ABE4. [pmid: 24749899].
74 Sanderson CL, Okuyemi K, Choi WS, et al. A review of tobacco use treatments in US ethnic minority populations. American Journal of Health Promotion. 2011;25(5):S11-S30. ACE11. [pmid: 21510783].
75 Siegel MB, Tanwar KL, Wood KS. Electronic cigarettes as a smoking-cessation: tool results from an online survey. Am J Prev Med. Apr. 2011;40(4):472-5. ENDSE2. [pmid: 21406283].
76 Song F, Huttunen-Lenz M, Holland R. Effectiveness of complex psycho-educational interventions for smoking relapse prevention: an exploratory meta-analysis. Journal of Public Health. 2010;32(3):350-9. ABE4. [pmid: 19939787].
77 Spata J, Kelsberg G, Safranek S. Clinical inquiries. Does office spirometry improve quit rates in smokers?. J Fam Pract. Oct. 2010;59(10):593-4. ABE2a. [pmid: 20922180].
78 Spring B, Howe D, Berendsen M, et al. Behavioral intervention to promote smoking cessation and prevent weight gain: a systematic review and meta-analysis. Addiction. Sep. 2009;104(9):1472-86. ABE1. [pmid: 19549058].
79 Steinberg MB, Zimmermann MH, Delnevo CD, et al. E-Cigarette Versus Nicotine Inhaler: Comparing the Perceptions and Experiences of Inhaled Nicotine Devices. J Gen Intern Med. 2014. May. 15. ENDSE6. [pmid: 24830741].
80 Suls JM, Luger TM, Curry SJ, et al. Efficacy of smoking-cessation interventions for young adults: a meta-analysis. Am J Prev Med. Jun. 2012;42(6):655-62. ACE2a. [pmid: 22608385].
81 Tonstad S, Davies S, Flammer M, et al. Psychiatric adverse events in randomized, double-blind, placebo-controlled clinical trials of varenicline: a pooled analysis. Drug Saf. Apr. 1. 2010;33(4):289-301. APE2a. [pmid: 20297861].
82 Tsoi DT, Porwal M, Webster AC. Efficacy and safety of bupropion for smoking cessation and reduction in schizophrenia: systematic review and meta-analysis. Br J Psychiatry. May. 2010;196(5):346-53. AME10. [pmid: 20435957].
83 Umeda A, Kato T, Yamane T, et al. Does smoking cessation with varenicline worsen vascular endothelial function?. BMJ Open. 2013;3(6). APE2a. [pmid: 23794597].
84 Vaz LR, Leonardi BJ, Aveyard P, et al. Factors associated with smoking cessation in early and late pregnancy in the smoking, nicotine, and pregnancy trial: A trial of nicotine replacement therapy. Nicotine & Tobacco Research. 2014;16(4):381-9. PPPE8. [pmid: 24127265].
85 Vickerman KA, Carpenter KM, Altman T, et al. Use of electronic cigarettes among state tobacco cessation quitline callers. Nicotine Tob Res. Oct. 2013;15(10):1787-91. ENDSE2. [pmid: 23658395].
86 Webb MS, Rodriguez-Esquivel D, Baker EA. Smoking cessation interventions among Hispanics in the United States: A systematic review and mini meta-analysis. Am J Health Promot. Nov. 2010;25(2):109-18. ACE7. [pmid: 21039291].
87 Weinberger AH, Mazure CM, Morlett A, et al. Two decades of smoking cessation treatment research on smokers with depression: 1990-2010. Nicotine Tob Res. Jun. 2013;15(6):1014-31. AME6. [pmid: 23100459].
88 Weiner E, Ball MP, Buchholz AS, et al. Bupropion sustained release added to group support for smoking cessation in schizophrenia: a new randomized trial and a meta-analysis. J Clin Psychiatry. Jan. 2012;73(1):95-102. AME2a. [pmid: 21535998].
89 Wray JM, Gass JC, Tiffany ST. A systematic review of the relationships between craving and smoking cessation. Nicotine Tob Res. Jul. 2013;15(7):1167-82. ACE6. [pmid: 23291636].