# Existing Systematic Reviews Included Studies

Appendix C Figure 1 Overlap in Included Studies in Existing Systematic Reviews on the Effectiveness of Nicotine Replacement Therapy Among Adults

* Review served as basis for main finding

Appendix C Figure 1 is a Venn diagram that depicts the overlap in included studies in existing systematic reviews on the effectiveness of nicotine replacement therapy among adults.

Appendix C Figure 2 Overlap in Included Studies in Existing Systematic Reviews on the Effectiveness of Bupropion Among Adults

* Review served as basis for main finding

Appendix C Figure 2 is a Venn diagram that depicts the overlap in included studies in existing systematic reviews on the effectiveness of bupropion among adults.

Appendix C Figure 3 Overlap in Included Studies in Existing Systematic Reviews on the Effectiveness of Varenicline Among Adults

* Review served as basis for main finding

Appendix C Figure 3 is a Venn diagram that depicts the overlap in included studies in existing systematic reviews on the effectiveness of varenicline among adults.

Appendix C Figure 4 Overlap in Included Studies in Existing Systematic Reviews on the Effectiveness of Pharmacotherapy Among Pregnant Women

* Review served as basis for main finding

Appendix C Figure 4 is a Venn diagram that depicts the overlap in included studies in existing systematic reviews on the effectiveness of pharmacotherapy among pregnant women.

Appendix C Table 1 List of Included Studies for Behavioral Intervention Reviews: Adults

Appendix C Table 2 List of Included Studies for Behavioral Intervention Reviews: Pregnant Women