# Detailed Methods

## Search Strategies

### Systematic Evidence Review Search

#### Database: AHRQ

---------------------------------------------------------------------------------

Treating Tobacco Use and Dependence: 2009 Update

http://www.ahrq.gov/professionals/clinicians-providers/guidelines-recommendations/tobacco/index.html

Smoking Cessation Interventions During Pregnancy and the Postpartum Period

[Research Protocol – Mar 8, 2013]

http://effectivehealthcare.ahrq.gov/ehc/products/517/1423/Pregnancy-Smoking%20Cessation-130311.pdf

#### Database: Canadian Agency for Drugs and Technologies in Health

---------------------------------------------------------------------------------

Pharmacologic-based Strategies for Smoking Cessation – September 2010

http://www.cadth.ca/en/products/health-technology-assessment/publication/3141

#### Database: Cochrane Database of Systematic Reviews (Issue 12 of 12, Dec 2012)

---------------------------------------------------------------------------------

#1 tobacco:ti from 2009 to 2013, in Cochrane Reviews (Reviews only)
#2 smoking:ti from 2009 to 2013, in Cochrane Reviews (Reviews only)
#3 smoker*:ti from 2009 to 2013, in Cochrane Reviews (Reviews only)
#4 nicotine:ti from 2009 to 2013, in Cochrane Reviews (Reviews only)
#5 cigarette*:ti from 2009 to 2013, in Cochrane Reviews (Reviews only)
#6 #1 or #2 or #3 or #4 or #5

#### Database: Community Guide

---------------------------------------------------------------------------------

Reducing tobacco use and secondhand exposure [multiple TF recommendations]

http://www.thecommunityguide.org/tobacco/index.html

#### Database: Database of Abstracts of Reviews of Effects (Via CRD)

---------------------------------------------------------------------------------

(smoking):TI OR (smoker*):TI OR (tobacco):TI OR (nicotine):TI OR (cigarette*):TI IN DARE FROM 2009 TO 2013

#### Database: Health Technology Assessment

---------------------------------------------------------------------------------

(smoking):TI OR (smoker*):TI OR (tobacco):TI OR (nicotine):TI OR (cigarette*):TI IN HTA FROM 2009 TO 2013

#### Database: Institute of Medicine

---------------------------------------------------------------------------------

Combating Tobacco in Military and Veteran Populations, June 2009

http://www.iom.edu/Reports/2009/MilitarySmokingCessation.aspx

Ending the Tobacco Problem: A Blueprint for the Nation, May 2007

http://www.iom.edu/Reports/2007/Ending-the-Tobacco-Problem-A-Blueprint-for-the-Nation.aspx

#### Database: NHS HTA Programme

---------------------------------------------------------------------------------

Relapse prevention in UK Stop Smoking Services: current practice, systematic reviews of effectiveness and cost-effectiveness analysis - October 2010

http://www.journalslibrary.nihr.ac.uk/hta/volume-14/issue-49

Cytisine for smoking cessation

Protocol October 2012

http://www.hta.ac.uk/protocols/201200460001.pdf

Effectiveness and cost-effectiveness of computer and other electronic aids for smoking cessation: a systematic review and network meta-analysis - October 2012

http://www.journalslibrary.nihr.ac.uk/hta/volume-16/issue-38

Evaluating longer term outcomes of NHS stop smoking services

Protocol December 2012

http://www.hta.ac.uk/protocols/200901610001.pdf

#### Database: NICE

---------------------------------------------------------------------------------

Quitting smoking in pregnancy and following childbirth

June 2010, expected update July 2013

http://guidance.nice.org.uk/PH26

Smokeless tobacco cessation - South Asian communities

September 2012, expected update September 2015

http://guidance.nice.org.uk/PH39

Tobacco harm reduction

June 2013, expected update June 2016

http://guidance.nice.org.uk/PH45

Smoking cessation - acute, maternity and mental health services

Anticipated publication date: November 2013

http://guidance.nice.org.uk/PHG/51

#### Database: PubMed

---------------------------------------------------------------------------------

1. “Smoking Cessation”[Mesh] OR “Tobacco Use Cessation”[Mesh:NoExp] OR “Tobacco Use Disorder”[Mesh] OR “Smoking/prevention and control”[Mesh:NoExp]
2. #1 AND systematic[sb] Limits: English, Adult: 19+ years, Publication Date from 2008 to 2013
3. (smoking[ti] OR smoker*[ti] OR tobacco[ti] OR nicotine[ti] OR cigarette*[ti])
4. #3 AND systematic[sb]
5. #4 AND (in process[sb] OR publisher[sb] OR pubmednotmedline[sb]) Limits: English, Publication Date from 2009 to 2013
6. #2 OR #5

#### Database: PsycINFO <1806 to July Week 5 2013 >

---------------------------------------------------------------------------------

1. tobacco smoking/
2. smoking cessation/
3. Smokeless tobacco/
4. (smoking or smoker$ or tobacco or nicotine or cigarette$).ti.
5. 1 or 2 or 3 or 4
6. limit 5 to “300 adulthood <age 18 yrs and older>”
7. limit 6 to (“0830 systematic review” or 1200 meta analysis)
8. limit 7 to (english language and yr=“2009 -Current”)

### Pregnant Women Evidence Search

#### Database: CENTRAL <Issue 7 of 12, July 2014>

---------------------------------------------------------------------------------

#1 (pregnan* or prenatal or “pre natal” or perinatal or “peri natal” or antenatal or “ante natal” or antepartum or “ante partum” or postnatal or “post natal” or postpartum or “post partum” or puerperal):ti,ab,kw 28995
#2 (smoking or smoker* or tobacco or nicotine or cigarette*):ti,ab,kw 16591
#3 nicotine:ti,ab,kw next replacement:ti,ab,kw next therap*:ti,ab,kw 542
#4 nicotine:ti,ab,kw near/3 (patch* or gum* or spray* or lozenge*):ti,ab,kw 1155
#5 (Bupropion or Zyban or Varenicline or Chantix or Champix):ti,ab,kw 1182
#6 (drug* or pharm*):ti 15323
#7 #3 or #4 or #5 or #6 17791
#8 #1 and #2 and #7 Publication Year from 2012 to 2014, in Trials 11

#### Database: Medline

Ovid MEDLINE(R) without Revisions <1996 to August Week 1 2014>

Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <August 14, 2014>

Ovid MEDLINE(R) Daily Update <August 14, 2014>

---------------------------------------------------------------------------------

1. Pregnancy/ (306774)
2. Pregnant women/ (2284)
3. Prenatal care/ (11476)
4. Perinatal care/ (2682)
5. Postnatal care/ (2484)
6. Postpartum period/ (8090)
7. Peripartum period/ (333)
8. Maternal Health Services/ (5284)
9. Pregnancy complications/ (31416)
10. Puerperal Disorders/ (3628)
11. pregnan$.ti,ab. (210464)
12. prenatal.ti,ab. (43895)
13. pre natal.ti,ab. (528)
14. perinatal.ti,ab. (32454)
15. peri natal.ti,ab. (103)
16. antenatal.ti,ab. (16549)
17. ante natal.ti,ab. (237)
18. antepartum.ti,ab. (2505)
19. ante partum.ti,ab. (219)
20. postnatal.ti,ab. (52436)
21. post natal.ti,ab. (3484)
22. postpartum.ti,ab. (23067)
23. post partum.ti,ab. (4670)
24. new mother$.ti,ab. (825)
25. puerperal.ti,ab. (1782)
26. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 (429666)
27. “Tobacco Use Disorder”/ (6738)
28. Smoking/ (73210)
29. “Tobacco Use Cessation”/ (723)
30. Smoking Cessation/ (17952)
31. smoking.ti,ab. (114959)
32. smoker$.ti,ab. (45894)
33. tobacco.ti,ab. (52031)
34. nicotine.ti,ab. (20548)
35. cigarette$.ti,ab. (33842)
36. 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 (188107)
37. “Tobacco Use Cessation Products”/ (603)
38. Nicotinic Agonists/ (5531)
39. Bupropion/ (2050)
40. Benzazepines/ (4838)
41. Quinoxalines/ (5408)
42. nicotine replacement therap$.ti,ab. (1739)
43. (nicotine adj3 (patch$ or gum$ or nasal spray$ or lozenge$)).ti,ab. (1502)
44. Bupropion.ti,ab. (2638)
45. Zyban.ti,ab. (115)
46. Varenicline.ti,ab. (899)
47. Chantix.ti,ab. (45)
48. Champix.ti,ab. (33)
49. (drug$ or pharm$).ti. (261302)
50. 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 (279019)
51. 26 and 36 and 50 (725)
52. “Tobacco Use Disorder”/dt [Drug Therapy] (736)
53. 26 and 52 (27)
54. 51 or 53 (730)
55. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ or meta-analysis as topic/ (177894)
56. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt. (502141)
57. Random$.ti,ab. (583977)
58. control groups/ or double-blind method/ or single-blind method/ (97302)
59. clinical trial$.ti,ab. (180675)
60. controlled trial$.ti,ab. (106233)
61. meta analy$.ti,ab. (60992)
62. 55 or 56 or 57 or 58 or 59 or 60 or 61 (1070505)
63. 54 and 62 (89)
64. limit 63 to (english language and yr=“2012 -Current”) (22)

#### Database: PsycINFO <1806 to August Week 2 2014>

---------------------------------------------------------------------------------

1. Pregnancy/ (15766)
2. Expectant Mothers/ (532)
3. Prenatal Care/ (1297)
4. Perinatal Period/ (1743)
5. Postnatal Period/ (3654)
6. pregnan$.ti,ab,id. (33146)
7. prenatal.ti,ab,id. (13783)
8. pre natal.ti,ab,id. (181)
9. perinatal.ti,ab,id. (6862)
10. peri natal.ti,ab,id. (55)
11. antenatal.ti,ab,id. (2103)
12. ante natal.ti,ab,id. (40)
13. antepartum.ti,ab,id. (203)
14. ante partum.ti,ab,id. (9)
15. postnatal.ti,ab,id. (13564)
16. post natal.ti,ab,id. (717)
17. postpartum.ti,ab,id. (7864)
18. post partum.ti,ab,id. (818)
19. puerperal.ti,ab,id. (431)
20. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 (60200)
21. tobacco smoking/ (22978)
22. smoking cessation/ (9199)
23. Smokeless tobacco/ (562)
24. (smoking or smoker$ or tobacco or nicotine or cigarette$).ti,ab,id. (48166)
25. 21 or 22 or 23 or 24 (48286)
26. Drug Therapy/ (108330)
27. Bupropion/ (792)
28. nicotine replacement therap$.ti,ab,id. (915)
29. (nicotine adj3 (patch$ or gum$ or nasal spray$ or lozenge$)).ti,ab,id. (1104)
30. Bupropion.ti,ab,id. (1686)
31. Zyban.ti,ab,id. (43)
32. Varenicline.ti,ab,id. (421)
33. Chantix.ti,ab,id. (27)
34. Champix.ti,ab,id. (13)
35. (drug$ or pharm$).ti. (51426)
36. 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 (147347)
37. 20 and 25 and 36 (240)
38. random$.ti,ab,id,hw. (132759)
39. placebo$.ti,ab,hw,id. (31321)
40. controlled trial$.ti,ab,id,hw. (21428)
41. clinical trial$.ti,ab,id,hw. (24164)
42. meta analy$.ti,ab,hw,id. (19063)
43. treatment outcome clinical trial.md. (27525)
44. 38 or 39 or 40 or 41 or 42 or 43 (187717)
45. 37 and 44 (39)
46. limit 45 to (english language and yr=“2012 -Current”) (13)

#### Database: PubMed, publisher-supplied records

---------------------------------------------------------------------------------

Search | Query | Items found
#12 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #11 AND publisher[sb] AND English[Language] AND (“2012”[Date - Publication] : “2014”[Date - Publication]) | 8 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #4 AND #5 AND #10 | 495 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #6 OR #7 OR #8 OR #9 | 314642 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search drug*[ti] OR pharm*[ti] | 307939 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search Bupropion[tiab] OR Zyban[tiab] OR Varenicline[tiab] OR Chantix[tiab] OR Champix[tiab] | 3743 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search nicotine[tiab] AND (patch*[tiab] OR gum*[tiab] OR spray*[tiab] OR lozenge*[tiab]) | 2699 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search nicotine replacement therap*[tiab] | 1812 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search smoking[tiab] OR smoker*[tiab] OR tobacco[tiab] OR nicotine[tiab] OR cigarette*[tiab] | 237785 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search pregnan*[tiab] OR prenatal[tiab] OR “pre natal”[tiab] OR perinatal[tiab] OR “peri natal”[tiab] OR antenatal[tiab] OR “ante natal”[tiab] OR antepartum[tiab] OR “ante partum”[tiab] OR postnatal[tiab] OR “post natal”[tiab] OR postpartum[tiab] OR “post partum”[tiab] OR puerperal[tiab] | 543639 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)

### Electronic Nicotine Delivery Systems Evidence Search

#### Database: PubMed Strategy 3.1.2015

---------------------------------------------------------------------------------

Search (((e-cigarette*[Title/Abstract]) OR electronic cigarette*[Title/Abstract]) OR electric nicotine delivery[Title/Abstract]) OR electronic nicotine delivery[Title/Abstract] Filters: Publication date from 2008/01/01 to 2015/12/31; English

#### Database: Cochrane Database of Systematic Reviews : Issue 5 of 12, May 2014

---------------------------------------------------------------------------------

ID | Search
#1 | electronic next cigarette*:ti,ab,kw
#2 | e next cigarette*:ti,ab,kw
#3 | electronic next nicotine next delivery:ti,ab,kw
#4 | #1 or #2 or #3 Publication Date from 2008 to 2014, in Trials
#5 | #1 or #2 or #3 in Cochrane Reviews (Reviews and Protocols)

#### Database: Scopus 5-13-2014

---------------------------------------------------------------------------------

TITLE-ABS-KEY(“e-cigarette*” OR “electronic cigarette*” or “electronic nicotine delivery”) AND (LIMIT-TO(PUBYEAR,2014) OR LIMIT-TO(PUBYEAR,2013) OR LIMIT-TO(PUBYEAR,2012) OR LIMIT-TO(PUBYEAR,2011) OR LIMIT-TO(PUBYEAR,2010) OR LIMIT-TO(PUBYEAR,2009) OR LIMIT-TO(PUBYEAR,2008) ) AND ( LIMIT-TO(LANGUAGE,“English” ) )

Appendix B Table 1 Inclusion and Exclusion Criteria

Category | Include | Exclude
Study design | Systematic reviews, including review-of-reviews, with or without meta-analysis A review will be considered “systematic” if it: 1) includes a clear statement of the purpose of the review; 2) describes the search strategy; 3) indicates the criteria used to select studies for inclusion; and 4) presents the findings relevant to the main purpose of the review, including those that did not favor the intervention. Systematic reviews that include experimental and/or observational study designs will be included
Aim | Tobacco cessation in current tobacco users, regardless of readiness to quit | - Primary prevention of tobacco use; - Tobacco harm–reduction strategies; - Relapse prevention interventions
Condition | Current use of any tobacco product, including, but not limited to: cigarettes, pipes, cigars, cigarillos, little cigars, bidis, kreteks, tobacco (including chew, snuff [including snus], and dissolvable tobacco in the form of strips, sticks, or lozenges), or smoking tobacco through a hookah or waterpipe
Population | Adults (age ≥18 years), including pregnant women and individuals with mental health conditions, who are current smokers Includes reviews that focus on specific primary care–relevant subgroups (e.g., young adults; older adults; specific racial/ethnic groups; lesbian, gay, bisexual, and transgender individuals; veterans; low-income; low education; substance users) | Reviews in which >50% of the included studies focus on:; - Children and adolescents; - Partners; - Providers; - Psychiatric inpatients; - Other nonmental health comorbid conditions (e.g., chronic obstructive pulmonary disease, cardiovascular conditions, cancer, HIV)
Interventions | Primary care–relevant tobacco cessation interventions, including behavioral interventions and/or pharmacotherapy, with or without referral Examples include:; - Advice and counseling (including technology- and web-based services); - Self-help materials (including technology and web-based services); - Referral to quitlines; - Complementary and alternative therapies (e.g., acupuncture, hypnosis); - Exercise interventions; - Nicotine replacement therapy (gum, inhaler, lozenge, nasal spray, patch); - Bupropion (Zyban®); - Varenicline tartrate (Chantix®); - Electronic nicotine delivery systems (ENDS) or electronic cigarettes^*^ | - System-level interventions; - Broad public health initiatives (e.g., mass media, community-wide); - Medications that are not approved by the U.S. Food and Drug Administration as first-line tobacco cessation agents (e.g., clonidine, nortriptyline, selective serotonin reuptake inhibitors, anxiolytics, benzodiazepines, beta-blockers, opioid antagonists/naltrexone)
Setting | Any setting applicable to primary care | Reviews limited to studies that take place in worksites, specialty care, or other settings not applicable to primary care
Comparators | - No intervention; - Usual care; - Waitlist; - Attention control (e.g., similar in format and intensity, but intervention on a different content area); - Minimal intervention (no more than a single brief contact [i.e., <5 minutes] per year or brief written materials, such as pamphlets); - Active intervention (i.e., more than a single brief contact per year or brief written materials)
Outcome assessment | Based on self-report or biochemically validated reports (e.g., expired carbon monoxide; cotinine measured in saliva, urine, or blood; cotinine–creatinine ratio; thiocyanate) | Population-based smoking rates (i.e., not based on study sample, but on underlying population)
Outcomes | KQ 1: Health and other outcomes Health outcomes:; - All-cause mortality; - Tobacco-related mortality; - Tobacco-related morbidity (including, but not limited to: cancer, asthma, cardiovascular disease, chronic bronchitis, or other respiratory disorders); - Perinatal morbidity/mortality; - Dental/oral health; - Quality of life as measured by validated scales; Other outcomes:; ▪ Health care utilization; KQ 2: Behavioral outcomes; ▪ Tobacco cessation/tobacco abstinence (continuous abstinence or point prevalence abstinence); KQ 3: Adverse events; ▪ Serious treatment-related harms at any time point after the intervention began; ▪ Weight gain; ▪ Emotional distress (e.g., worsening of symptoms such as depression, anxiety, psychosis; loss of associates or friends); ▪ Adverse events associated with medications; ▪ Paradoxical increase in tobacco use; ▪ Demoralization due to failed quit attempt | Reviews that only report:; - Smoking/tobacco reduction (based on frequency/quantity only); - Reduction in withdrawal symptoms; - Attitudes, knowledge, or beliefs related to tobacco use; - Intentions to change behavior; - Intervention participation/compliance
Outcome assessment timing | KQs 1, 2: ≥6-month followup after quit date/start of intervention KQ 3: Harms reported at any point after quit date | <6-month followup after quit date/start of intervention
Study geography | Reviews that do not exclusively take place in nondeveloped countries (http://hdr.undp.org/en/statistics) Developed countries: Andorra, Argentina, Australia, Austria, Barbados, Belgium, Brunei Darussalam, Canada, Chile, Croatia, Cyprus, Czech Republic, Denmark, Estonia, Finland, France, Germany, Greece, Hong Kong, Hungary, Iceland, Ireland, Israel, Italy, Japan, Korea, Latvia, Liechtenstein, Lithuania, Luxembourg, Malta, Netherlands, New Zealand, Norway, Poland, Portugal, Qatar, Seychelles, Singapore, Slovakia, Slovenia, Spain, Sweden, Switzerland, United Arab Emirates, United Kingdom, United States | Reviews in which >50% of included studies take place in countries with a Human Development Index below “Very High”
Publication language | English | Any language other than English
Publication date | 2009 to present | Reviews published before 2009
Quality rating | Fair or good | Poor

* The review of ENDS or e-cigarette evidence did not adopt the review-of-review approach given the emerging nature of the technology. The specific criteria for inclusion and exclusion of these studies are outlined in narrative form.

Appendix B Table 2 Adapted AMSTAR Quality Rating Tool

1. Was an ‘a priori’ design provided? The research question and inclusion criteria should be established before the conduct of the review and inclusion criteria should be clearly stated. | □ Yes □ No
2a. Was there dual study selection? There should be at least two study selectors/full-text reviewers and a consensus procedure for disagreements should be in place. | □ Yes □ No
2b. Was there dual data extraction? There should be at least two data extractors and a consensus procedure for disagreements should be in place. | □ Yes □ No
3. Was a comprehensive literature search performed? At least two electronic sources should be searched. The report must include years and databases used (e.g., Central, EMBASE, and MEDLINE). Key words and/or MESH terms must be stated and where feasible the search strategy should be provided. All searches should be supplemented by consulting current contents, reviews, textbooks, specialized registers, or experts in the particular field of study, and by reviewing the references in the studies found. Give “mostly” if there is no mention of search terms, date, or supplemental searches. | □ Yes □ Mostly □ No
[struck: 4. Was the status of publication (i.e. grey literature) used as an inclusion criterion?] [struck: The authors should state that they searched for reports regardless of their publication type. The authors should state whether or not they excluded any reports (from the systematic review), based on their publication status, language etc.]
5a. Was a list of studies included provided? A list of included studies should be provided. | □ Yes □ No
5b. Was a list of excluded studies provided? A list of excluded studies should be provided. | □ Yes □ No
6. Were the characteristics of the included studies provided? In an aggregated form such as a table, data from the original studies should be provided on the participants, interventions and outcomes. The ranges of characteristics in all the studies analyzed (e.g., age, race, sex, relevant socioeconomic data, disease status, duration, severity, or other diseases) should be reported. | □ Yes □ Mostly □ No
7. Was the scientific quality of the included studies assessed and documented? ‘A priori methods of assessment should be provided (e.g., for effectiveness studies if the author(s) chose to include only randomized, double-blind, placebo controlled studies, or allocation concealment as inclusion criteria); for other types of studies alternative items will be relevant. | □ Yes □ No
8. Was the scientific quality of the included studies used appropriately in formulating conclusions? The results of the methodological rigor and scientific quality should be considered in the analysis and the conclusions of the review, and explicitly stated in formulating recommendations. Give “no” if only mentioned as a potential limitation but not discussed in terms of how it may or may not affect conclusions or interpretation. | □ Yes □ No
9. Were the methods used to combine the findings of studies appropriate? For pooled results, a test should be done to ensure the studies were combinable, to assess their homogeneity (i.e., Chi-squared test for homogeneity, I-squared). If heterogeneity exists a random effects model should be used and/or the clinical appropriateness of combining should be taken into consideration (i.e., is it sensible to combine)? | □ Yes □ No □ Not applicable
10. Was the likelihood of publication bias assessed? An assessment of publication bias should include a combination of graphical aids (e.g., funnel plot, other available tests) and/or statistical tests (e.g., Egger regression test). | □ Yes □ No □ Not applicable
11a. Were potential conflicts of interest/source(s) of support of the systematic review stated? Source(s) of systematic review support should be clearly acknowledged. | □ Yes □ No
11b. Were potential conflicts of interest/source(s) of support of the included studies stated? Source(s) of included studies support should be clearly acknowledged. Give “not applicable” if review only includes behavioral interventions and conflict of interest is not of big concern. | □ Yes □ No □ Not applicable
Are there other quality issues of concern? List other issues that cause you to question the trustworthiness of the review.

Appendix B Figure 1 Literature Flow Diagram: Systematic Reviews

* Two reviews included both adults and pregnant women

✝ Reviews can be counted in multiple intervention areas

Appendix B Figure 1 is a flow chart that summarizes the search and selection of systematic reviews. There were 1,141 citations identified through literature databases. After duplicates were removed, 638 unique citations were screened at the title/abstract stage. The full-text of 114 systematic reviews was examined for inclusion in one or more of the three populations of interest, including adults, pregnant women and individuals with mental health conditions.

Appendix B Figure 2 Literature Flow Diagram: Primary Evidence on Electronic Nicotine Delivery Systems

Appendix B Figure 2 is a flow chart that summarizes the search and selection of primary evidence on electronic nicotine delivery systems (ENDS). There were 1,161 citations identified through literature databases. After duplicates were removed, 766 unique citations were screened at the title/abstract stage. The full-text of 25 articles was examined for the discussion on ENDS.

Appendix B Figure 3 Literature Flow Diagram: Primary Evidence on Pharmacotherapy in Pregnant Women

Appendix B Figure 3 is a flow chart that summarizes the search and selection of primary evidence on pharmacotherapy in pregnant women. There were 54 citations identified through literature databases. After duplicates were removed, 31 unique citations were screened at the title/abstract stage. The full-text of 9 articles was examined for the discussion on pharmacotherapy in pregnant women.