# 2009 USPSTF Clinical Summary: Counseling and Interventions to Prevent Tobacco Use and Tobacco-Caused Disease in Adults and Pregnant Women

Population | Adults Age ≥18 Years | Pregnant Women of Any Age
Recommendation | Ask about tobacco use. Provide tobacco cessation interventions to those who use tobacco products. | Ask about tobacco use. Provide augmented pregnancy-tailored counseling for women who smoke.
Recommendation | Grade: A | Grade: A
Counseling | The “5-A” framework provides a useful counseling strategy:; 1. Ask about tobacco use.; 2. Advise to quit through clear personalized messages.; 3. Assess willingness to quit.; 4. Assist to quit.; 5. Arrange follow-up and support.; Intensity of counseling matters: brief one-time counseling works; however, longer sessions or multiple sessions are more effective. Telephone counseling “quit lines” also improve cessation rates.
Pharmacotherapy | Combination therapy with counseling and medications is more effective than either component alone. FDA-approved pharmacotherapy includes nicotine replacement therapy, sustained-release bupropion, and varenicline. | The USPSTF found inadequate evidence to evaluate the safety or efficacy of pharmacotherapy during pregnancy.
Implementation | Successful implementation strategies for primary care practice include:; - Instituting a tobacco user identification system.; - Promoting clinician intervention through education, resources, and feedback.; - Dedicating staff to provide treatment, and assessing the delivery of treatment in staff performance evaluations.
Relevant Recommendations from the USPSTF | Recommendations on other behavioral counseling topics are available at http://www.uspreventiveservicestaskforce.org.

Abbreviations: FDA = U.S. Food and Drug Administration; USPSTF = U.S. Preventive Services Task Force.