# References

1 Dube C, Rostom A, Lewin G, Tsertsvadze A, Barrowman N, Code C, Sampson M, Moher D, Force USPST. The use of aspirin for primary prevention of colorectal cancer: a systematic review prepared for the U.S. Preventive Services Task Force. Ann Intern Med. 2007;146(5):365-75. [pmid: 17339622].
2 Rostom A, Dube C, Lewin G, Tsertsvadze A, Barrowman N, Code C, Sampson M, Moher D, U. S. Preventive Services Task Force. Nonsteroidal anti-inflammatory drugs and cyclooxygenase-2 inhibitors for primary prevention of colorectal cancer: a systematic review prepared for the U.S. Preventive Services Task Force. Ann Intern Med. 2007;146(5):376-89. [pmid: 17339623].
3 U. S. Preventive Services Task Force. Routine aspirin or nonsteroidal anti-inflammatory drugs for the primary prevention of colorectal cancer: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2007;146(5):361-4. [pmid: 17339621].
4 Risio M. The natural history of adenomas. Best Pract Res Clin Gastroenterol. 2010;24(3):271-80. [pmid: 20510828].
5 Winawer SJ, Zauber AG, Ho MN, O'Brien MJ, Gottlieb LS, Sternberg SS, Waye JD, Schapiro M, Bond JH, Panish JF, Ackroyd F, Shike M, Kurtz RC, Hornsby-Lewis L, Gerdes H, Stewart ET, The National Polyp Study Workgroup. Prevention of colorectal cancer by colonoscopic polypectomy. N Engl J Med. 1993;329(27):1977-81. [pmid: 8247072].
6 American Cancer Society. Cancer Facts & Figures 2014. Atlanta, GA. American Cancer Society. 2014. Document No.: 500814.
7 Siegel R, Ma J, Zou Z, Jemal A. Cancer statistics, 2014. CA Cancer J Clin. 2014;64(1):9-29. [pmid: 24399786].
8 Murtaugh MA, Ma K-N, Caan BJ, Slattery ML. Association of fluids from beverages with risk of rectal cancer. Nutr Cancer. 2004;49(1):25-31. [pmid: 15456632].
9 Edwards BK, Ward E, Kohler BA, Eheman C, Zauber AG, Anderson RN, Jemal A, Schymura MJ, Lansdorp-Vogelaar I, Seeff LC, van Ballegooijen M, Goede SL, Ries LA. Annual report to the nation on the status of cancer, 1975-2006, featuring colorectal cancer trends and impact of interventions (risk factors, screening, and treatment) to reduce future rates. Cancer. 2010;116(3):544-73. [pmid: 19998273].
10 Mariotto AB, Yabroff KR, Shao Y, Feuer EJ, Brown ML. Projections of the cost of cancer care in the United States: 2010-2020. J Natl Cancer Inst. 2011;103(2):117-28. [pmid: 21228314].
11 Sturmer T, Buring JE, Lee IM, Kurth T, Gaziano JM, Glynn RJ. Colorectal cancer after start of nonsteroidal anti-inflammatory drug use. Am J Med. 2006;119(6):494-502. [pmid: 16750963].
12 Siegel R, Desantis C, Jemal A. Colorectal cancer statistics, 2014. CA Cancer J Clin. 2014;64(2):104-17. [pmid: 24639052].
13 Roy HK, Bianchi LK. Differences in colon adenomas and carcinomas among women and men: potential clinical implications. JAMA. 2009;302(15):1696-7. [pmid: 19843905].
14 Nguyen SP, Bent S, Chen YH, Terdiman JP. Gender as a risk factor for advanced neoplasia and colorectal cancer: a systematic review and meta-analysis. Clin Gastroenterol Hepatol. 2009;7(6):676-81.e1-3. [pmid: 19514116].
15 Surveillance, Epidemiology, and End Results Program. SEER Stat Fact Sheets: Colon and Rectum Cancer. Bethesda, MD. National Institutes of Health. [cited December 21 2014]; Available from: http://seer.cancer.gov/statfacts/html/colorect.html.
16 Regula J, Rupinski M, Kraszewska E, Polkowski M, Pachlewski J, Orlowska J, Nowacki MP, Butruk E. Colonoscopy in colorectal-cancer screening for detection of advanced neoplasia. N Engl J Med. 2006;355(18):1863-72. [pmid: 17079760].
17 Brenner H, Hoffmeister M, Arndt V, Haug U. Gender differences in colorectal cancer: implications for age at initiation of screening. Br J Cancer. 2007;96(5):828-31. [pmid: 17311019].
18 Lieberman D. Race, gender, and colorectal cancer screening. Am J Gastroenterol. 2005;100(12):2756-8. [pmid: 16393231].
19 Yeh RK, Chen J, Williams JL, Baluch M, Hundley TR, Rosenbaum RE, Kalala S, Traganos F, Benardini F, del Soldato P, Kashfi K, Rigas B. NO-donating nonsteroidal antiinflammatory drugs (NSAIDs) inhibit colon cancer cell growth more potently than traditional NSAIDs: a general pharmacological property?. Biochemical Pharmacology. 2004;67(12):2197-205. [pmid: 15163551].
20 Agrawal S, Bhupinderjit A, Bhutani MS, Boardman L, Nguyen C, Romero Y, Srinivasan R, Figueroa-Moseley C. Committee of Minority Affairs and Cultural Diversity, American College of Gastroenterology. Colorectal cancer in African Americans. Am J Gastroenterol. 2005;100(3):515-23. discussion 4. [pmid: 15743345].
21 Ulrich CM, Bigler J, Sparks R, Whitton J, Sibert JG, Goode EL, Yasui Y, Potter JD. Polymorphisms in PTGS1 (=COX-1) and risk of colorectal polyps. Cancer Epidemiology, Biomarkers & Prevention. 2004;13(5):889-93.
22 Larsson SC, Orsini N, Wolk A. Diabetes mellitus and risk of colorectal cancer: a meta-analysis. J Natl Cancer Inst. 2005;97(22):1679-87. [pmid: 16288121].
23 Yuhara H, Steinmaus C, Cohen SE, Corley DA, Tei Y, Buffler PA. Is diabetes mellitus an independent risk factor for colon cancer and rectal cancer?. Am J Gastroenterol. 2011;106(11):1911-21. quiz 22. [pmid: 21912438].
24 Butterworth AS, Higgins JP, Pharoah P. Relative and absolute risk of colorectal cancer for individuals with a family history: a meta-analysis. Eur J Cancer. 2006;42(2):216-27. [pmid: 16338133].
25 Johns LE, Houlston RS. A systematic review and meta-analysis of familial colorectal cancer risk. Am J Gastroenterol. 2001;96(10):2992-3003. [pmid: 11693338].
26 Taylor DP, Burt RW, Williams MS, Haug PJ, Cannon-Albright LA. Population-based family history-specific risks for colorectal cancer: a constellation approach. Gastroenterology. 2010;138(3):877-85. [pmid: 19932107].
27 Burt RW. Colon cancer screening. Gastroenterology. 2000;119(3):837-53. [pmid: 10982778].
28 Lynch PM. Does regular use of aspirin reduce the risk of colorectal cancer?. Nat Clin Pract Oncol. 2006;3(4):186-7. [pmid: 16596142].
29 Huang CS, Farraye FA, Yang S, O'Brien MJ. The clinical significance of serrated polyps. Am J Gastroenterol. 2011;106(2):229-40. quiz 41. [pmid: 21045813].
30 Snover DC. Update on the serrated pathway to colorectal carcinoma. Hum Pathol. 2011;42(1):1-10. [pmid: 20869746].
31 O'Brien MJ, Winawer SJ, Zauber AG, Gottlieb LS, Sternberg SS, Diaz B, Dickersin GR, Ewing S, Geller S, Kasimian D, et al., The National Polyp Study. Patient and polyp characteristics associated with high-grade dysplasia in colorectal adenomas. Gastroenterology. 1990;98(2):371-9. [pmid: 2403953].
32 Cappell MS. Pathophysiology, clinical presentation, and management of colon cancer. Gastroenterol Clin North Am. 2008;37(1):1-24. v. [pmid: 18313537].
33 Pino MS, Chung DC. The chromosomal instability pathway in colon cancer. Gastroenterology. 2010;138(6):2059-72. [pmid: 20420946].
34 Rizk P, Barker N. Gut stem cells in tissue renewal and disease: methods, markers, and myths. Wiley Interdiscip Rev Syst Biol Med. 2012;4(5):475-96. [pmid: 22644962].
35 Muto T, Kamiya J, Sawada T, Konishi F, Sugihara K, Kubota Y, Adachi M, Agawa S, Saito Y, Morioka Y, et al. Small “flat adenoma” of the large bowel with special reference to its clinicopathologic features. Dis Colon Rectum. 1985;28(11):847-51. [pmid: 4053897].
36 Lau PC, Sung JJ. Flat adenoma in colon: two decades of debate. J Dig Dis. 2010;11(4):201-7. [pmid: 20649732].
37 Leggett B, Whitehall V. Role of the serrated pathway in colorectal cancer pathogenesis. Gastroenterology. 2010;138(6):2088-100. [pmid: 20420948].
38 Noffsinger AE, Hart J. Serrated adenoma: a distinct form of non-polypoid colorectal neoplasia?. Gastrointest Endosc Clin N Am. 2010;20(3):543-63. [pmid: 20656251].
39 Arends MJ. Pathways of colorectal carcinogenesis. Appl Immunohistochem Mol Morphol. 2013;21(2):97-102. [pmid: 23417071].
40 Jasperson KW, Tuohy TM, Neklason DW, Burt RW. Hereditary and familial colon cancer. Gastroenterology. 2010;138(6):2044-58. [pmid: 20420945].
41 National Cancer Institute. PDQ® Genetics of Colorectal Cancer. Bethesda, MD. 2013. [updated 2/28/2013; cited 4/27/2013]; Available from: http://cancer.gov/cancertopics/pdq/genetics/colorectal/HealthProfessional.
42 Anderson JC. Risk factors and screening for colorectal cancer. Anderson Kahi, editor. Colorectal cancer screening. New York. Humana Press. 2011.
43 Newcomb PA, Storer BE, Marcus PM. Cigarette smoking in relation to risk of large bowel cancer in women. Cancer Res. 1995;55(21):4906-9. [pmid: 7585528].
44 Chao A, Thun MJ, Jacobs EJ, Henley SJ, Rodriguez C, Calle EE. Cigarette smoking and colorectal cancer mortality in the cancer prevention study II. J Natl Cancer Inst. 2000;92(23):1888-96. [pmid: 11106680].
45 Paskett ED, Reeves KW, Rohan TE, Allison MA, Williams CD, Messina CR, Whitlock E, Sato A, Hunt JR. Association between cigarette smoking and colorectal cancer in the Women's Health Initiative. J Natl Cancer Inst. 2007;99(22):1729-35. [pmid: 18000222].
46 Leufkens AM, Van Duijnhoven FJ, Siersema PD, Boshuizen HC, Vrieling A, Agudo A, Gram IT, Weiderpass E, Dahm C, Overvad K, Tjonneland A, Olsen A, Boutron-Ruault MC, Clavel-Chapelon F, Morois S, Palli D, Grioni S, Tumino R, Sacerdote C, Mattiello A, Herman S, Kaaks R, Steffen A, Boeing H, Trichopoulou A, Lagiou P, Trichopoulos D, Peeters PH, van Gils CH, van Kranen H, Lund E, Dumeaux V, Engeset D, Rodriguez L, Sanchez MJ, Chirlaque MD, Barricarte A, Manjer J, Almquist M, van Guelpen B, Hallmans G, Khaw KT, Wareham N, Tsilidis KK, Straif K, Leon-Roux M, Vineis P, Norat T, Riboli E, Bueno-de-Mesquita HB. Cigarette smoking and colorectal cancer risk in the European Prospective Investigation into Cancer and Nutrition study. Clin Gastroenterol Hepatol. 2011;9(2):137-44. [pmid: 21029790].
47 Giovannucci E. An updated review of the epidemiological evidence that cigarette smoking increases risk of colorectal cancer. Cancer Epidemiol Biomarkers Prev. 2001;10(7):725-31. [pmid: 11440957].
48 Moore LL, Bradlee ML, Singer MR, Splansky GL, Proctor MH, Ellison RC, Kreger BE. BMI and waist circumference as predictors of lifetime colon cancer risk in Framingham Study adults. Int J Obes Relat Metab Disord. 2004;28(4):559-67. [pmid: 14770200].
49 Pischon T, Lahmann PH, Boeing H, Friedenreich C, Norat T, Tjonneland A, Halkjaer J, Overvad K, Clavel-Chapelon F, Boutron-Ruault MC, Guernec G, Bergmann MM, Linseisen J, Becker N, Trichopoulou A, Trichopoulos D, Sieri S, Palli D, Tumino R, Vineis P, Panico S, Peeters PH, Bueno-de-Mesquita HB, Boshuizen HC, Van Guelpen B, Palmqvist R, Berglund G, Gonzalez CA, Dorronsoro M, Barricarte A, Navarro C, Martinez C, Quiros JR, Roddam A, Allen N, Bingham S, Khaw KT, Ferrari P, Kaaks R, Slimani N, Riboli E. Body size and risk of colon and rectal cancer in the European Prospective Investigation Into Cancer and Nutrition (EPIC). J Natl Cancer Inst. 2006;98(13):920-31. [pmid: 16818856].
50 Larsson SC, Wolk A. Obesity and colon and rectal cancer risk: a meta-analysis of prospective studies. Am J Clin Nutr. 2007;86(3):556-65. [pmid: 17823417].
51 Wang Y, Jacobs EJ, Patel AV, Rodriguez C, McCullough ML, Thun MJ, Calle EE. A prospective study of waist circumference and body mass index in relation to colorectal cancer incidence. Cancer Causes Control. 2008;19(7):783-92. [pmid: 18322811].
52 Wei EK, Giovannucci E, Wu K, Rosner B, Fuchs CS, Willett WC, Colditz GA. Comparison of risk factors for colon and rectal cancer. Int J Cancer. 2004;108(3):433-42. [pmid: 14648711].
53 Ferrari P, Jenab M, Norat T, Moskal A, Slimani N, Olsen A, Tjonneland A, Overvad K, Jensen MK, Boutron-Ruault MC, Clavel-Chapelon F, Morois S, Rohrmann S, Linseisen J, Boeing H, Bergmann M, Kontopoulou D, Trichopoulou A, Kassapa C, Masala G, Krogh V, Vineis P, Panico S, Tumino R, van Gils CH, Peeters P, Bueno-de-Mesquita HB, Ocke MC, Skeie G, Lund E, Agudo A, Ardanaz E, Lopez DC, Sanchez MJ, Quiros JR, Amiano P, Berglund G, Manjer J, Palmqvist R, Van Guelpen B, Allen N, Key T, Bingham S, Mazuir M, Boffetta P, Kaaks R, Riboli E. Lifetime and baseline alcohol intake and risk of colon and rectal cancers in the European prospective investigation into cancer and nutrition (EPIC). Int J Cancer. 2007;121(9):2065-72. [pmid: 17640039].
54 Thygesen LC, Wu K, Gronbaek M, Fuchs CS, Willett WC, Giovannucci E. Alcohol intake and colorectal cancer: a comparison of approaches for including repeated measures of alcohol consumption. Epidemiology. 2008;19(2):258-64. [pmid: 18300715].
55 Giovannucci E, Ascherio A, Rimm EB, Colditz GA, Stampfer MJ, Willett WC. Physical activity, obesity, and risk for colon cancer and adenoma in men. Ann Intern Med. 1995;122(5):327-34. [pmid: 7847643].
56 Martinez ME, Giovannucci E, Spiegelman D, Hunter DJ, Willett WC, Colditz GA. Leisure-time physical activity, body size, and colon cancer in women. Nurses' Health Study Research Group. J Natl Cancer Inst. 1997;89(13):948-55. [pmid: 9214674].
57 Wolin KY, Yan Y, Colditz GA, Lee IM. Physical activity and colon cancer prevention: a meta-analysis. Br J Cancer. 2009;100(4):611-6. [pmid: 19209175].
58 Graser A, Stieber P, Nagel D, Schafer C, Horst D, Becker CR, Nikolaou K, Lottes A, Geisbusch S, Kramer H, Wagner AC, Diepolder H, Schirra J, Roth HJ, Seidel D, Goke B, Reiser MF, Kolligs FT. Comparison of CT colonography, colonoscopy, sigmoidoscopy and faecal occult blood tests for the detection of advanced adenoma in an average risk population. Gut. 2009;58(2):241-8. [pmid: 18852257].
59 Levin B, Lieberman DA, McFarland B, Andrews KS, Brooks D, Bond J, Dash C, Giardiello FM, Glick S, Johnson D, Johnson CD, Levin TR, Pickhardt PJ, Rex DK, Smith RA, Thorson A, Winawer SJ, American Cancer Society Colorectal Cancer Advisory G, Force USM-ST, American College of Radiology Colon Cancer C. Screening and surveillance for the early detection of colorectal cancer and adenomatous polyps, 2008: a joint guideline from the American Cancer Society, the US Multi-Society Task Force on Colorectal Cancer, and the American College of Radiology. Gastroenterology. 2008;134(5):1570-95. [pmid: 18384785].
60 U. S. Preventive Services Task Force. Screening for colorectal cancer: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2008;149(9):627-37. [pmid: 18838716].
61 Rex DK, Johnson DA, Anderson J.C., Schoenfeld P.S., Burke C.A., Inadomi J.M. American College of Gastroenterology Guidelines for Colorectal Cancer Screening 2008. Am J Gastroenterol. 2008.
62 Davila RE, Rajan E, Baron TH, Adler DG, Egan JV, Faigel DO, Gan SI, Hirota WK, Leighton JA, Lichtenstein D, Qureshi WA, Shen B, Zuckerman MJ, VanGuilder T, Fanelli RD, Standards of Practice Committee ASfGE. ASGE guideline: colorectal cancer screening and surveillance. Gastrointest Endosc. 2006;63(4):546-57. [pmid: 16564851].
63 Cooper K, Squires H, Carroll C, Papaioannou D, Booth A, Logan RF, Maguire C, Hind D, Tappenden P. Chemoprevention of colorectal cancer: systematic review and economic evaluation. Health Technol Assess. 2010;14(32):1-206.
64 Bresalier RS, Sandler RS, Quan H, Bolognese JA, Oxenius B, Horgan K, Lines C, Riddell R, Morton D, Lanas A, Konstam MA, Baron JA. Cardiovascular events associated with rofecoxib in a colorectal adenoma chemoprevention trial. N Engl J Med. 2005;352(11):1092-102. [pmid: 15713943].
65 Juni P, Nartey L, Reichenbach S, Sterchi R, Dieppe PA, Egger M. Risk of cardiovascular events and rofecoxib: cumulative meta-analysis. Lancet. 2004;364(9450):2021-9. [pmid: 15582059].
66 Weingarten MA, Zalmanovici A, Yaphe J. Dietary calcium supplementation for preventing colorectal cancer and adenomatous polyps. Cochrane Database Syst Rev. 2008;(1):CD003548. [pmid: 18254022].
67 Wu K, Willett WC, Fuchs CS, Colditz GA, Giovannucci EL. Calcium intake and risk of colon cancer in women and men. J Natl Cancer Inst. 2002;94(6):437-46. [pmid: 11904316].
68 Grau MV, Baron JA, Sandler RS, Wallace K, Haile RW, Church TR, Beck GJ, Summers RW, Barry EL, Cole BF, Snover DC, Rothstein R, Mandel JS. Prolonged effect of calcium supplementation on risk of colorectal adenomas in a randomized trial. J Natl Cancer Inst. 2007;99(2):129-36. [pmid: 17227996].
69 Baron JA, Beach M, Mandel JS, van Stolk RU, Haile RW, Sandler RS, Rothstein R, Summers RW, Snover DC, Beck GJ, Bond JH, Frankl H, Pearson L, Greenberg ER. Calcium supplements for the prevention of colorectal adenomas. N Engl J Med. 1999;340(2):101-7. [pmid: 9887161].
70 Bonithon-Kopp C, Kronborg O, Giacosa A, Rath U, Faivre J. Calcium and fibre supplementation in prevention of colorectal adenoma recurrence: a randomised intervention trial. The Lancet. 2000;356(9238):1300-6.
71 Bond JH. Polyp guideline: diagnosis, treatment, and surveillance for patients with colorectal polyps. Practice Parameters Committee of the American College of Gastroenterology. Am J Gastroenterol. 2000;95(11):3053-63. [pmid: 11095318].
72 Giovannucci E. Epidemiology of vitamin D and colorectal cancer. Anticancer Agents Med Chem. 2013;13(1):11-9. [pmid: 23094917].
73 Wactawski-Wende J, Kotchen JM, Anderson GL, Assaf AR, Brunner RL, O'Sullivan MJ, Margolis KL, Ockene JK, Phillips L, Pottern L, Prentice RL, Robbins J, Rohan TE, Sarto GE, Sharma S, Stefanick ML, Van Horn L, Wallace RB, Whitlock E, Bassford T, Beresford SA, Black HR, Bonds DE, Brzyski RG, Caan B, Chlebowski RT, Cochrane B, Garland C, Gass M, Hays J, Heiss G, Hendrix SL, Howard BV, Hsia J, Hubbell FA, Jackson RD, Johnson KC, Judd H, Kooperberg CL, Kuller LH, LaCroix AZ, Lane DS, Langer RD, Lasser NL, Lewis CE, Limacher MC, Manson JE, Women's Health Initiative Investigators. Calcium plus vitamin D supplementation and the risk of colorectal cancer. N Engl J Med. 2006;354(7):684-96. [pmid: 16481636].
74 National Cancer Institute. Vitamin D and cancer rrevention: strengths and limits of the evidence. Rockville, MD. National Institutes of Health. 2010. [updated June 16, 2010; cited May 1 2013]; Available from: http://www.cancer.gov/cancertopics/factsheet/prevention/vitamin-D.
75 U.S. Preventive Services Task Force. Recommendation summary: Vitamin supplementation to prevent cancer and CVD: Counseling. Rockville, MD. U.S. Preventive Services Task Force. 2014. [updated February 2014; cited December 23 2014]; Available from: http://www.uspreventiveservicestaskforce.org/uspstf/uspsvita.htm.
76 Reddy BS, Rao CV, Rivenson A, Kelloff G. Inhibitory effect of aspirin on azoxymethane-induced colon carcinogenesis in F344 rats. Carcinogenesis. 1993;14(8):1493-7. [pmid: 8353834].
77 Mereto E, Frencia L, Ghia M. Effect of aspirin on incidence and growth of aberrant crypt foci induced in the rat colon by 1,2-dimethylhydrazine. Cancer Lett. 1994;76(1):5-9. [pmid: 8124666].
78 Craven PA, DeRubertis FR. Effects of aspirin on 1,2-dimethylhydrazine-induced colonic carcinogenesis. Carcinogenesis. 1992;13(4):541-6. [pmid: 1315625].
79 Algra AM, Rothwell PM. Effects of regular aspirin on long-term cancer incidence and metastasis: a systematic comparison of evidence from observational studies versus randomised trials. Lancet Oncol. 2012;13(5):518-27. [pmid: 22440112].
80 Bosetti C, Rosato V, Gallus S, Cuzick J, La Vecchia C. Aspirin and cancer risk: a quantitative review to 2011. Ann Oncol. 2012;23(6):1403-15. [pmid: 22517822].
81 Dube C, Rostom A, Lewin G, Tsertsvadze A, Barrowman N, Code C, Sampson M, Moher D, U. S. Preventive Services Task Force. The use of aspirin for primary prevention of colorectal cancer: a systematic review prepared for the U.S. Preventive Services Task Force. Ann Intern Med. 2007;146(5):365-75. [pmid: 17339622].
82 Ye X, Fu J, Yang Y, Chen S. Dose-risk and duration-risk relationships between aspirin and colorectal cancer: a meta-analysis of published cohort studies. PLoS One. 2013;8(2):e57578. [pmid: 23451245].
83 Rothwell PM, Fowkes FGR, Belch JFF, Ogawa H, Warlow CP, Meade TW. Effect of daily aspirin on long-term risk of death due to cancer: analysis of individual patient data from randomised trials. Lancet. 2011;377(9759):31-41. [pmid: 21144578].
84 Rothwell PM, Price JF, Fowkes FG, Zanchetti A, Roncaglioni MC, Tognoni G, Lee R, Belch JF, Wilson M, Mehta Z, Meade TW. Short-term effects of daily aspirin on cancer incidence, mortality, and non-vascular death: analysis of the time course of risks and benefits in 51 randomised controlled trials. Lancet. 2012;379(9826):1602-12. [pmid: 22440946].
85 Rothwell PM, Wilson M, Elwin C-E, Norrving B, Algra A, Warlow CP, Meade TW. Long-term effect of aspirin on colorectal cancer incidence and mortality: 20-year follow-up of five randomised trials. Lancet. 2010;376(9754):1741-50. [pmid: 20970847].
86 Rothwell PM, Wilson M, Price JF, Belch JFF, Meade TW, Mehta Z. Effect of daily aspirin on risk of cancer metastasis: a study of incident cancers during randomised controlled trials. Lancet. 2012;379(9826):1591-601. [pmid: 22440947].
87 Thun MJ, Jacobs EJ, Patrono C. The role of aspirin in cancer prevention. Nat Rev Clin Oncol. 2012;9(5):259-67. [pmid: 22473097].
88 Alfonso L, Ai G, Spitale RC, Bhat GJ. Molecular targets of aspirin and cancer prevention. Br J Cancer. 2014;111(1):61-7. [pmid: 24874482].
89 Trinchieri G. Innate inflammation and cancer: Is it time for cancer prevention?. F1000 Med Rep. 2011;3:11. [pmid: 21876717].
90 Dannenberg AJ, Lippman SM, Mann JR, Subbaramaiah K, DuBois RN. Cyclooxygenase-2 and epidermal growth factor receptor: pharmacologic targets for chemoprevention. J Clin Oncol. 2005;23(2):254-66. [pmid: 15637389].
91 Colotta F, Allavena P, Sica A, Garlanda C, Mantovani A. Cancer-related inflammation, the seventh hallmark of cancer: links to genetic instability. Carcinogenesis. 2009;30(7):1073-81. [pmid: 19468060].
92 Berg M, Soreide K. Prevention: will an aspirin a day keep the colorectal cancer away?. Nat Rev Clin Oncol. 2011;8(3):130-1. [pmid: 21200396].
93 Thun MJ, Henley SJ, Patrono C. Nonsteroidal anti-inflammatory drugs as anticancer agents: mechanistic, pharmacologic, and clinical issues. J Natl Cancer Inst. 2002;94(4):252-66. [pmid: 11854387].
94 Chan AT, Arber N, Burn J, Chia WK, Elwood P, Hull MA, Logan RF, Rothwell PM, Schror K, Baron JA. Aspirin in the chemoprevention of colorectal neoplasia: an overview. Cancer Prev Res (Phila). 2012;5(2):164-78. [pmid: 22084361].
95 Eberhart CE, Coffey RJ, Radhika A, Giardiello FM, Ferrenbach S, DuBois RN. Up-regulation of cyclooxygenase 2 gene expression in human colorectal adenomas and adenocarcinomas. Gastroenterology. 1994;107(4):1183-8. [pmid: 7926468].
96 Brown JR, DuBois RN. COX-2: a molecular target for colorectal cancer prevention. J Clin Oncol. 2005;23(12):2840-55. [pmid: 15837998].
97 Chan AT, Ogino S, Fuchs CS. Aspirin and the risk of colorectal cancer in relation to the expression of COX-2. N Engl J Med. 2007;356(21):2131-42. [pmid: 17522398].
98 Colorectal Cancer: Can colorectal cancer be prevented?. Atlanta, GA. American Cancer Society. 2013. [updated January 17, 2013; cited April 23 2013]; Available from: http://www.cancer.org/cancer/colonandrectumcancer/detailedguide/colorectal-cancer-prevention.
99 U.S. Preventive Services Task Force. USPSTF A and B Recommendations. Rockville, MD. U.S. Preventive Services Task Force. 2010. [updated August 2010; cited April 23 2013]; Available from: http://www.ama-assn.org/resources/doc/cpt/aca-uspstf-a-and-b-recs.pdf.
100 U.S. Preventive Services Task Force. Aspirin and NSAIDS for colorectal cancer prevention. American College of Physicians. 2012. [updated 2007; cited April 23 2013]; Available from: http://www.acponline.org/mobile/cyppocketguide/aspirin_nsaids_colorectal_cancer_prevention.html.
101 Chiu LCM, Tong KF, Ooi VEC. Cytostatic and cytotoxic effects of cyclooxygenase inhibitors and their synergy with docosahexaenoic acid on the growth of human skin melanoma A-375 cells. Biomedicine & Pharmacotherapy. Suppl 2. 2005;59:S293-7. [pmid: 16507396].
102 National Institute for Health and Care Excellence. Published clinical guidelines. London. National Institute for Health and Care Excellence. 2013. [updated April 25, 2013; cited April 25 2013]; Available from: http://guidance.nice.org.uk/CG/Published.
103 Burt RW, Winawer SJ, Bond J, et al. Preventing colorectal cancer: a clinician's guide: The American Gastroenterological Association. 2004.
104 Wilcox CM, Allison J, Benzuly K, Borum M, Cryer B, Grosser T, Hunt R, Ladabaum U, Lanas A, Paulus H, Regueiro C, Sandler RS, Simon L. Consensus development conference on the use of nonsteroidal anti-inflammatory agents, including cyclooxygenase-2 enzyme inhibitors and aspirin. Clin Gastroenterol Hepatol. 2006;4(9):1082-9.e4. [pmid: 16877048].
105 National Comprehensive Cancer Network. NCCN Guidelines for Detection, Prevention & Risk Reduction: Colorectal Cancer. Fort Washington, PA. National Comprehensive Cancer Network. 2013. [cited April 25 2013]; Available from: http://www.nccn.org/professionals/physician_gls/pdf/colorectal_screening.pdf.
106 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. AHRQ Publication No. 08-05118-EF. Rockville, MD. Agency for Healthcare Quality and Research. 2008. [updated August 2011; cited May 1 2014]; Available from: http://www.uspreventiveservicestaskforce.org/uspstf08/methods/procmanual.htm.
107 Wells G, Shea B, O'Connell D, Peterson J, Welch V, Losos M, Tugwell P. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. Ottawa. Ottawa Hospital Research Institute. 2014. [cited May 20 2014]; Available from: http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp.
108 Thrombosis prevention trial: randomised trial of low-intensity oral anticoagulation with warfarin and low-dose aspirin in the primary prevention of ischaemic heart disease in men at increased risk. The Medical Research Council's General Practice Research Framework. Lancet. 1998;351(9098):233-41. [pmid: 9457092].
109 Fu R, Gartlehner G, Grant M, Shamliyan T, Sedrakyan A, Wilt TJ, Griffith L, Oremus M, Raina P, Ismaila A, Santaguida P, Lau J, Trikalinos TA. Conducting quantitative synthesis when comparing medical interventions: AHRQ and the Effective Health Care Program. Journal of Clinical Epidemiology. 2011;64(11):1187-97. [pmid: 21477993].
110 Turner RM, Bird SM, Higgins JP. The impact of study size on meta-analyses: examination of underpowered studies in Cochrane reviews. PLoS One. 2013;8(3):e59202. [pmid: 23544056].
111 Flossmann E, Rothwell PM. British Doctors Aspirin Trial, the UK-TIA Aspirin Trial. Effect of aspirin on long-term risk of colorectal cancer: consistent evidence from randomised and observational studies. Lancet. 2007;369(9573):1603-13. [pmid: 17499602].
112 Cook NR, Lee IM, Gaziano JM, Gordon D, Ridker PM, Manson JE, Hennekens CH, Buring JE. Low-dose aspirin in the primary prevention of cancer: the Women's Health Study: a randomized controlled trial. JAMA. 2005;294(1):47-55. [pmid: 15998890].
113 Cook NR, Lee IM, Zhang SM, Moorthy MV, Buring JE. Alternate-day, low-dose aspirin and cancer risk: long-term observational follow-up of a randomized trial. Ann Intern Med. 2013;159(2):77-85. [pmid: 23856681].
114 Ridker PM, Cook NR, Lee IM, Gordon D, Gaziano JM, Manson JE, Hennekens CH, Buring JE. A randomized trial of low-dose aspirin in the primary prevention of cardiovascular disease in women. N Engl J Med. 2005;352(13):1293-304. [pmid: 15753114].
115 Rexrode KM, Lee IM, Cook NR, Hennekens CH, Buring JE. Baseline characteristics of participants in the Women's Health Study. Journal of women's health & gender-based medicine. 2000;9(1):19-27.
116 Buring JE, Hennekens CH, for the Women's Health Study Research group. The Women's Health Study: Summary of the study design. Journal of Myocardial Ischemia. 1992;4:27-9.
117 Manson JE, Buring JE, Satterfield S, Hennekens CH. Baseline characteristics of participants in the Physicians' Health Study: a randomized trial of aspirin and beta-carotene in U.S. physicians. Am J Prev Med. 1991;7(3):150-4. [pmid: 1931143].
118 Physician's Health Study. Final report on the aspirin component of the ongoing Physicians' Health Study. N Engl J Med. 1989;321(3):129-35. [pmid: 2664509].
119 Hennekens CH, Buring JE, Manson JE, Stampfer M, Rosner B, Cook NR, Belanger C, LaMotte F, Gaziano JM, Ridker PM, Willett W, Peto R. Lack of effect of long-term supplementation with beta carotene on the incidence of malignant neoplasms and cardiovascular disease. N Engl J Med. 1996;334(18):1145-9. [pmid: 8602179].
120 Findings from the aspirin component of the ongoing Physicians' Health Study. N Engl J Med. 1988;318(4):262-4. [pmid: 3275899].
121 Glynn RJ, Buring JE, Manson JE, LaMotte F, Hennekens CH. Adherence to aspirin in the prevention of myocardial infarction. The Physicians' Health Study. Arch Intern Med. 1994;154(23):2649-57. [pmid: 7993148].
122 Sturmer T, Buring JE, Glynn RJ. Aspirin and nonsteroidal anti-inflammatory drugs for the primary prevention of colorectal cancer: weighing the evidence. Ann Intern Med. 2007;147(9):674. author reply -5. [pmid: 17975195].
123 Cole BF, Logan RF, Halabi S, Benamouzig R, Sandler RS, Grainge MJ, Chaussade S, Baron JA. Aspirin for the chemoprevention of colorectal adenomas: meta-analysis of the randomized trials. J Natl Cancer Inst. 2009;101(4):256-66. [pmid: 19211452].
124 Peto R, Gray R, Collins R, Wheatley K, Hennekens C, Jamrozik K, Warlow C, Hafner B, Thompson E, Norton S, et al. Randomised trial of prophylactic daily aspirin in British male doctors. British medical journal. 1988;296(6618):313-6. [pmid: 3125882].
125 Group U-TS. United Kingdom transient ischaemic attack (UK-TIA) aspirin trial: interim results. UK-TIA Study Group. British medical journal (Clinical research ed). 1988;296(6618):316-20. [pmid: 2894232].
126 Farrell B, Godwin J, Richards S, Warlow C. The United Kingdom transient ischaemic attack (UK-TIA) aspirin trial: final results. Journal of neurology, neurosurgery, and psychiatry. 1991;54(12):1044-54.
127 SALT. Swedish Aspirin Low-Dose Trial (SALT) of 75 mg aspirin as secondary prophylaxis after cerebrovascular ischaemic events. The SALT Collaborative Group. Lancet. 1991;338(8779):1345-9. [pmid: 1682734].
128 Early Treatment Diabetic Retinopathy Study Investigators. Aspirin effects on mortality and morbidity in patients with diabetes mellitus. Early Treatment Diabetic Retinopathy Study report 14. ETDRS Investigators. JAMA. 1992;268(10):1292-300. [pmid: 1507375].
129 Early Treatment Diabetic Retinopathy Study Investigators. Early Treatment Diabetic Retinopathy Study design and baseline patient characteristics. ETDRS report number 7. Ophthalmology. 1991;98(5 Suppl):741-56. [pmid: 2062510].
130 Juul-Moller S, Edvardsson N, Jahnmatz B, Rosen A, Sorensen S, Omblus R. Double-blind trial of aspirin in primary prevention of myocardial infarction in patients with stable chronic angina pectoris. The Swedish Angina Pectoris Aspirin Trial (SAPAT) Group. Lancet. 1992;340(8833):1421-5. [pmid: 1360557].
131 Ogawa H, Nakayama M, Morimoto T, Uemura S, Kanauchi M, Doi N, Jinnouchi H, Sugiyama S, Saito Y. Japanese Primary Prevention of Atherosclerosis With Aspirin for Diabetes Trial I. Low-dose aspirin for primary prevention of atherosclerotic events in patients with type 2 diabetes: a randomized controlled trial. JAMA. 2008;300(18):2134-41. [pmid: 18997198].
132 Belch J, MacCuish A, Campbell I, Cobbe S, Taylor R, Prescott R, Lee R, Bancroft J, MacEwan S, Shepherd J, Macfarlane P, Morris A, Jung R, Kelly C, Connacher A, Peden N, Jamieson A, Matthews D, Leese G, McKnight J, O'Brien I, Semple C, Petrie J, Gordon D, Pringle S, MacWalter R, Prevention of Progression of Arterial D, Diabetes Study G, Diabetes Registry G, Royal College of Physicians E. The prevention of progression of arterial disease and diabetes (POPADAD) trial: factorial randomised placebo controlled trial of aspirin and antioxidants in patients with diabetes and asymptomatic peripheral arterial disease. BMJ. 2008;337:a1840. [pmid: 18927173].
133 Fowkes FG, Price JF, Stewart MC, Butcher I, Leng GC, Pell AC, Sandercock PA, Fox KA, Lowe GD, Murray GD. Aspirin for Asymptomatic Atherosclerosis T. Aspirin for prevention of cardiovascular events in a general population screened for a low ankle brachial index: a randomized controlled trial. JAMA. 2010;303(9):841-8. [pmid: 20197530].
134 Gann PH, Manson JE, Glynn RJ, Buring JE, Hennekens CH. Low-dose aspirin and incidence of colorectal tumors in a randomized trial. J Natl Cancer Inst. 1993;85(15):1220-4. [pmid: 8331682].
135 Sturmer T, Glynn RJ, Lee IM, Manson JE, Buring JE, Hennekens CH. Aspirin use and colorectal cancer: post-trial follow-up data from the Physicians' Health Study. Ann Intern Med. 1998;128(9):713-20. [pmid: 9556464].
136 Baron JA, Cole BF, Sandler RS, Haile RW, Ahnen D, Bresalier R, McKeown-Eyssen G, Summers RW, Rothstein R, Burke CA, Snover DC, Church TR, Allen JI, Beach M, Beck GJ, Bond JH, Byers T, Greenberg ER, Mandel JS, Marcon N, Mott LA, Pearson L, Saibil F, van Stolk RU. A randomized trial of aspirin to prevent colorectal adenomas. N Engl J Med. 2003;348(10):891-9. [pmid: 12621133].
137 Kim S, Baron JA, Mott LA, Burke CA, Church TR, McKeown-Eyssen GE, Cole BF, Haile RW, Sandler RS. Aspirin may be more effective in preventing colorectal adenomas in patients with higher BMI (United States). Cancer Causes & Control. 2006;17(10):1299-304. [pmid: 17111262].
138 Grau MV, Sandler RS, McKeown-Eyssen G, Bresalier RS, Haile RW, Barry EL, Ahnen DJ, Gui J, Summers RW, Baron JA. Nonsteroidal anti-inflammatory drug use after 3 years of aspirin use and colorectal adenoma risk: observational follow-up of a randomized study. Journal of the National Cancer Institute. 2009;101(4):267-76. [pmid: 19211442].
139 Wallace K, Grau MV, Ahnen D, Snover DC, Robertson DJ, Mahnke D, Gui J, Barry EL, Summers RW, McKeown-Eyssen G, Haile RW, Baron JA. The association of lifestyle and dietary factors with the risk for serrated polyps of the colorectum. Cancer Epidemiology, Biomarkers & Prevention. 2009;18(8):2310-7.
140 Ho GYF, Xue X, Cushman M, McKeown-Eyssen G, Sandler RS, Ahnen DJ, Barry EL, Saibil F, Bresalier RS, Rohan TE, Baron JA. Antagonistic effects of aspirin and folic acid on inflammation markers and subsequent risk of recurrent colorectal adenomas. Journal of the National Cancer Institute. 2009;101(23):1650-4. [pmid: 19822838].
141 Benamouzig R, Deyra J, Martin A, Girard B, Jullian E, Piednoir B, Couturier D, Coste T, Little J, Chaussade S. Daily soluble aspirin and prevention of colorectal adenoma recurrence: one-year results of the APACC trial. Gastroenterology. 2003;125(2):328-36. [pmid: 12891533].
142 Benamouzig R, Uzzan B, Deyra J, Martin A, Girard B, Little J, Chaussade S. Association pour la Prevention par l'Aspirine du Cancer Colorectal Study G. Prevention by daily soluble aspirin of colorectal adenoma recurrence: 4-year results of the APACC randomised trial. [Erratum appears in Gut. 2012 Mar;61(3):472]. Gut. 2012;61(2):255-61. [pmid: 21890814].
143 Benamouzig R, Yoon H, Little J, Martin A, Couturier D, Deyra J, Coste T, Chaussade S, APACC Study Group Association pour la Prevention par Aspirine du Cancer Colorectal. APACC, a French prospective study on aspirin efficacy in reducing colorectal adenoma recurrence: design and baseline findings. European journal of cancer prevention : the official journal of the European Cancer Prevention Organisation. 2001;10(4):327-35.
144 Logan RFA, Grainge MJ, Shepherd VC, Armitage NC, Muir KR, UK CAP Trial Group. Aspirin and folic acid for the prevention of recurrent colorectal adenomas. Gastroenterology. 2008;134(1):29-38. [pmid: 18022173].
145 Logan RFA, Muir K.R., et al. Aspirin for the prevention of recurrent colorectal adenomas: results of the UKCAP trial. Gut. 2006;55((A90)).
146 Chan AT, Giovannucci EL, Meyerhardt JA, Schernhammer ES, Curhan GC, Fuchs CS. Long-term use of aspirin and nonsteroidal anti-inflammatory drugs and risk of colorectal cancer. JAMA. 2005;294(8):914-23. [pmid: 16118381].
147 Chan AT, Giovannucci EL, Schernhammer ES, Colditz GA, Hunter DJ, Willett WC, Fuchs CS. A prospective study of aspirin use and the risk for colorectal adenoma. Annals of Internal Medicine. 2004;140(3):157-66. [pmid: 14757613].
148 Giovannucci E, Colditz GA, Stampfer MJ, Hunter D, Rosner BA, Willett WC, Speizer FE. A prospective study of cigarette smoking and risk of colorectal adenoma and colorectal cancer in U.S. women. J Natl Cancer Inst. 1994;86(3):192-9. [pmid: 8283491].
149 Giovannucci E, Egan KM, Hunter DJ, Stampfer MJ, Colditz GA, Willett WC, Speizer FE. Aspirin and the risk of colorectal cancer in women. N Engl J Med. 1995;333(10):609-14. [pmid: 7637720].
150 Giovannucci E, Stampfer MJ, Colditz GA, Rimm EB, Trichopoulos D, Rosner BA, Speizer FE, Willett WC. Folate, methionine, and alcohol intake and risk of colorectal adenoma. J Natl Cancer Inst. 1993;85(11):875-84. [pmid: 8492316].
151 Wei EK, Colditz GA, Giovannucci EL, Fuchs CS, Rosner BA. Cumulative risk of colon cancer up to age 70 years by risk factor status using data from the Nurses' Health Study. American Journal of Epidemiology. 2009;170(7):863-72. [pmid: 19723749].
152 Chan AT, Giovannucci EL, Meyerhardt JA, Schernhammer ES, Wu K, Fuchs CS. Aspirin dose and duration of use and risk of colorectal cancer in men. Gastroenterology. 2008;134(1):21-8. [pmid: 18005960].
153 Larsson SC, Giovannucci E, Wolk A. Long-term aspirin use and colorectal cancer risk: a cohort study in Sweden. Br J Cancer. 2006;95(9):1277-9. [pmid: 17060932].
154 Calle EE, Rodriguez C, Jacobs EJ, Almon ML, Chao A, McCullough ML, Feigelson HS, Thun MJ. The American Cancer Society Cancer Prevention Study II Nutrition Cohort: rationale, study design, and baseline characteristics. Cancer. 2002;94(9):2490-501. [pmid: 12015775].
155 Garfinkel L. Selection, follow-up, and analysis in the American Cancer Society prospective studies. National Cancer Institute monograph. 1985;67:49-52. [pmid: 4047150].
156 Jacobs EJ, Thun MJ, Bain EB, Rodriguez C, Henley SJ, Calle EE. A large cohort study of long-term daily use of adult-strength aspirin and cancer incidence. J Natl Cancer Inst. 2007;99(8):608-15. [pmid: 17440162].
157 Thun MJ, Namboodiri MM, Heath CW Jr. Aspirin use and reduced risk of fatal colon cancer. N Engl J Med. 1991;325(23):1593-6. [pmid: 1669840].
158 Jacobs EJ, Newton CC, Gapstur SM, Thun MJ. Daily aspirin use and cancer mortality in a large US cohort. J Natl Cancer Inst. 2012;104(16):1208-17. [pmid: 22888140].
159 Tjonneland A, Olsen A, Boll K, Stripp C, Christensen J, Engholm G, Overvad K. Study design, exposure variables, and socioeconomic determinants of participation in Diet, Cancer and Health: a population-based prospective cohort study of 57,053 men and women in Denmark. Scandinavian journal of public health. 2007;35(4):432-41. [pmid: 17786808].
160 Friis S, Poulsen AH, Sorensen HT, Tjonneland A, Overvad K, Vogel U, McLaughlin JK, Blot WJ, Olsen JH. Aspirin and other non-steroidal anti-inflammatory drugs and risk of colorectal cancer: a Danish cohort study. Cancer Causes Control. 2009;20(5):731-40. [pmid: 19122977].
161 Brasky TM, Potter JD, Kristal AR, Patterson RE, Peters U, Asgari MM, Thornquist MD, White E. Non-steroidal anti-inflammatory drugs and cancer incidence by sex in the VITamins And Lifestyle (VITAL) cohort. Cancer Causes & Control. 2012;23(3):431-44. [pmid: 22212612].
162 White E, Patterson RE, Kristal AR, Thornquist M, King I, Shattuck AL, Evans I, Satia-Abouta J, Littman AJ, Potter JD. Vitamins And Lifestyle cohort study: study design and characteristics of supplement users. Am J Epidemiol. 2004;159(1):83-93. [pmid: 14693663].
163 Design of the Women's Health Initiative clinical trial and observational study. The Women's Health Initiative Study Group. Controlled clinical trials. 1998;19(1):61-109. [pmid: 9492970].
164 Allison M, Garland C, Chlebowski R, Criqui M, Langer R, Wu L, Roy H, McTiernan A, Kuller L, Women's Health Initiative Investigators. The association between aspirin use and the incidence of colorectal cancer in women. Am J Epidemiol. 2006;164(6):567-75. [pmid: 16847042].
165 Langer RD, White E, Lewis CE, Kotchen JM, Hendrix SL, Trevisan M. The Women's Health Initiative Observational Study: baseline characteristics of participants and reliability of baseline measures. Annals of epidemiology. 2003;13(9 Suppl):S107-21. [pmid: 14575943].
166 Hays J, Hunt JR, Hubbell FA, Anderson GL, Limacher M, Allen C, Rossouw JE. The Women's Health Initiative recruitment methods and results. Annals of epidemiology. 2003;13(9 Suppl):S18-77. [pmid: 14575939].
167 Chlebowski RT, Wactawski-Wende J, Ritenbaugh C, Hubbell FA, Ascensao J, Rodabough RJ, Rosenberg CA, Taylor VM, Harris R, Chen C, Adams-Campbell LL, White E, Women's Health Initiative I. Estrogen plus progestin and colorectal cancer in postmenopausal women. N Engl J Med. 2004;350(10):991-1004. [pmid: 14999111].
168 Sutcliffe P, Connock M, Gurung T, Freeman K, Johnson S, Ngianga-Bakwin K, Grove A, Gurung B, Morrow S, Stranges S, Clarke A. Aspirin in primary prevention of cardiovascular disease and cancer: a systematic review of the balance of evidence from reviews of randomized trials. PLoS ONE. [Electronic Resource]. 2013;8(12):e81970. [pmid: 24339983].
169 Sutcliffe P, Connock M, Gurung T, Freeman K, Johnson S, Kandala NB, Grove A, Gurung B, Morrow S, Clarke A. Aspirin for prophylactic use in the primary prevention of cardiovascular disease and cancer: a systematic review and overview of reviews. Health Technology Assessment (Winchester, England). 2013;17(43):1-253.
170 Thun MJ, Calle EE, Namboodiri MM, Flanders WD, Coates RJ, Byers T, Boffetta P, Garfinkel L, Heath CW Jr. Risk factors for fatal colon cancer in a large prospective study. J Natl Cancer Inst. 1992;84(19):1491-500. [pmid: 1433333].
171 Huang WK, Chiou MJ, Yu KH, Lin YC, Yang TS, Chen JS, Kuo CF, See LC. The association between low-dose aspirin use and the incidence of colorectal cancer: a nationwide cohort study. Aliment Pharmacol Ther. 2013;38(4):432-9. [pmid: 23799975].
172 Christen WG, Glynn RJ, Chew EY, Buring JE. Low-dose aspirin and medical record-confirmed age-related macular degeneration in a randomized trial of women. Ophthalmology. 2009;116(12):2386-92. [pmid: 19815293].
173 Christen WG, Glynn RJ, Ajani UA, Schaumberg DA, Chew EY, Buring JE, Manson JE, Hennekens CH. Age-related maculopathy in a randomized trial of low-dose aspirin among US physicians. Arch Ophthalmol. 2001;119(8):1143-9. [pmid: 11483080].
174 Duffy D, Kelly E, Trang A, Whellan D, Mills G. Aspirin for cardioprotection and strategies to improve patient adherence. Postgraduate medicine. 2014;126(1):18-28. [pmid: 24393748].
175 de Gaetano G, Collaborative Group of the Primary Prevention Project. Low-dose aspirin and vitamin E in people at cardiovascular risk: a randomised trial in general practice. Collaborative Group of the Primary Prevention Project. Lancet. 2001;357(9250):89-95. [pmid: 11197445].
176 Cook NR, Cole SR, Buring JE. Aspirin in the primary prevention of cardiovascular disease in the Women's Health Study: effect of noncompliance. European journal of epidemiology. 2012;27(6):431-8. [pmid: 22699516].
177 Silagy CA, McNeil JJ, Donnan GA, Tonkin AM, Worsam B, Campion K. The PACE pilot study: 12-month results and implications for future primary prevention trials in the elderly. (Prevention with low-dose Aspirin of Cardiovascular disease in the Elderly). Journal of the American Geriatrics Society. 1994;42(6):643-7. [pmid: 8201151].
178 Waeber B, Leonetti G, Kolloch R, McInnes GT. Compliance with aspirin or placebo in the Hypertension Optimal Treatment (HOT) study. Journal of hypertension. 1999;17(7):1041-5. [pmid: 10419079].
179 Effect of aspirin alone and aspirin plus dipyridamole in early diabetic retinopathy. A multicenter randomized controlled clinical trial. The DAMAD Study Group. Diabetes. 1989;38(4):491-8. [pmid: 2647556].
180 Nelson MR, Reid CM, Ames DA, Beilin LJ, Donnan GA, Gibbs P, Johnston CI, Krum H, Storey E, Tonkin A, Wolfe R, Woods R, McNeil JJ. Feasibility of conducting a primary prevention trial of low-dose aspirin for major adverse cardiovascular events in older people in Australia: results from the ASPirin in Reducing Events in the Elderly (ASPREE) pilot study. Med J Aust. 2008;189(2):105-9. [pmid: 18637782].
181 Brighton TA, Eikelboom JW, Mann K, Mister R, Gallus A, Ockelford P, Gibbs H, Hague W, Xavier D, Diaz R, Kirby A, Simes J, Investigators A. Low-dose aspirin for preventing recurrent venous thromboembolism. N Engl J Med. 2012;367(21):1979-87. [pmid: 23121403].
182 Aspirin in coronary heart disease. The Coronary Drug Project Research Group. Circulation. 1980;62(6 Pt 2):V59-62. [pmid: 7002353].
183 Cote R, Battista RN, Abrahamowicz M, Langlois Y, Bourque F, Mackey A. Lack of effect of aspirin in asymptomatic patients with carotid bruits and substantial carotid narrowing. The Asymptomatic Cervical Bruit Study Group. Annals of internal medicine. 1995;123(9):649-55. [pmid: 7574219].
184 Stroke Prevention in Atrial Fibrillation Study. Final results. Circulation. 1991;84(2):527-39. [pmid: 1860198].
185 Sato H, Ishikawa K, Kitabatake A, Ogawa S, Maruyama Y, Yokota Y, Fukuyama T, Doi Y, Mochizuki S, Izumi T, Takekoshi N, Yoshida K, Hiramori K, Origasa H, Uchiyama S, Matsumoto M, Yamaguchi T, Hori M, Japan Atrial Fibrillation Stroke Trial G. Low-dose aspirin for prevention of stroke in low-risk patients with atrial fibrillation: Japan Atrial Fibrillation Stroke Trial. Stroke; a journal of cerebral circulation. 2006;37(2):447-51.
186 Secondary prevention in non-rheumatic atrial fibrillation after transient ischaemic attack or minor stroke. EAFT (European Atrial Fibrillation Trial) Study Group. Lancet. 1993;342(8882):1255-62. [pmid: 7901582].
187 A randomized, controlled trial of aspirin in persons recovered from myocardial infarction. JAMA. 1980;243(7):661-9. [pmid: 6985998].
188 Persantine and aspirin in coronary heart disease. The Persantine-Aspirin Reinfarction Study Research Group. Circulation. 1980;62(3):449-61.
189 European Stroke Prevention Study 2. Efficacy and safety data. Journal of the neurological sciences. Suppl. 1997;151:S1-77. [pmid: 9276859].
190 Wei L, Fahey T, MacDonald TM. Adherence to statin or aspirin or both in patients with established cardiovascular disease: exploring healthy behaviour vs. drug effects and 10-year follow-up of outcome. British journal of clinical pharmacology. 2008;66(1):110-6. [pmid: 18492127].
191 Bower AB, Grau SL, Taylor VA. Over-the-counter vs. prescription medications: are consumer perceptions of the consequences of drug instruction non-compliance different?. Int J Consum Stud. 2013;37(2):228-33.
192 Mills EJ, Wu P, Alberton M, Kanters S, Lanas A, Lester R. Low-dose aspirin and cancer mortality: a meta-analysis of randomized trials. Am J Med. 2012;125(6):560-7. [pmid: 22513195].
193 Harris RP, Helfand M, Woolf SH, Lohr KN, Mulrow CD, Teutsch SM, Atkins D, Methods Work Group, USPSTF. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
194 Hull MA, Sandell AC, Montgomery AA, Logan RF, Clifford GM, Rees CJ, Loadman PM, Whitham D. A randomized controlled trial of eicosapentaenoic acid and/or aspirin for colorectal adenoma prevention during colonoscopic surveillance in the NHS Bowel Cancer Screening Programme (The seAFOod Polyp Prevention Trial): study protocol for a randomized controlled trial. Trials. 2013;14(1):237. [pmid: 23895505].