# Abbreviations

AAA: Aspirin for Asymptomatic Atherosclerosis
ABI: ankle brachial index
ACBS: Asymptomatic Cervical Bruit Study
ACM: all-cause mortality
ACP: American College of Physicians
AE: adverse event
AFPP: Aspirin/Folate Polyp Prevention
AHRQ: Agency for Healthcare Research and Quality
AMA: American Medical Association
AMIS: Aspirin Myocardial Infarction Study
APACC: Association pour la Prevention par l'Aspirine de Cancer Colorectal
ARR: absolute risk reduction
ASA: acetylsalicylic acid
ASPIRE: Aspirin to Prevent Recurrent Venous Thromboembolism
ASPREE: ASPirin in Reducing Events in the Elderly
BMD: British Medical Doctors Trial
BMI: body mass index
CCT: controlled clinical trial
CDPA: Coronary Drug Project Aspirin study
CG: control group
CI: confidence interval
cm: centimeter
COX: cyclooxygenase
CPSII: Cancer Prevention Study II
CQ(s): contextual question(s)
CRC: colorectal cancer
CVD: cardiovascular disease
DAMAD: Males and females with diabetic and diabetic retinopathy
EAFT: European Atrial Fibrillation Study
EPA: eicosapentaenoic acid
EPC: Evidence-based Practice Center
ERK: Extracellular-signal-regulated kinase
ESPS-2: European Stroke Prevention Study 2
ETDRS: Early Treatment Diabetic Retinopathy Study
FAP: familial adenomatous polyposis
g: gram
GI: gastrointestinal
HOT: Hypertension Optimal Treatment study
HPFS: Health Professionals Followup Study
HR: hazard ratio
IG: intervention group
IHD: ischemic heart disease
IKK: IκB kinase
IPD: individual patient data
IQR: interquartile range
ISRCTN Register: World Health Organization International Clinical Trials Registry Platform, Current Controlled Trials
JAST: Japan Atrial Fibrillation Stroke Trial
JPAD: Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes
KQ(s): key question(s)
MAP: MYH-associated polyposis
mg: milligram
MI: myocardial infarction
mm: millimeter
mo: month
NA: not applicable
NHS: Nurses' Health Study
NR: not reported
NSAIDs: nonsteroidal anti-inflammatory drugs
OR: odds ratio
PACE: Prevention with Low-dose Aspirin of Cardiovascular disease in the Elderly
PARIS: Persantine-Aspirin Reinfarction Study
PHS: Physicians' Health Study
POPADAD: Prevention of Progression of Arterial Disease and Diabetes
PPP: Primary Prevention Project
qd: daily
qod: every other day
RAO: retinal artery occlusion
RCT(s): randomized controlled trial(s)
RR: relative risk
SALT: Swedish Aspirin Low-dose Trial
SAPAT: Swedish Angina Pectoris Aspirin Trial
SD: standard deviation
SEER: Surveillance, Epidemiology, and End Results Program
SPAF: Stroke Prevention Atrial Fibrillation study
SSRIs: selective serotonin reuptake inhibitors
TIA: transient ischemic attack
TPT: Thrombosis Prevention Trial
ukCAP: United Kingdom Colorectal Adenoma Prevention trial
UK-TIA: United Kingdom Transient Ischaemic Attack
U.S.: United States
USPSTF: U.S. Preventive Services Task Force
VITAL: VITamins and Lifestyle
WHI: Women's Health Initiative
WHS: Women's Health Study
yrs: years