# Discussion

## Summary of Evidence

Table 10 presents our summary of benefits and harms across all KQs.

Table 10 Summary of Evidence

Key Question | Number of Studies (k) Design | Major Limitations | Consistency | Applicability | Overall Quality | Summary of Findings
KQ1/3. All-cause mortality and colorectal cancer mortality | General population All-cause mortality k=11 RCT k=1 Cohort | Limited data on late-onset risk (≥10 years after aspirin initiation). Limited direct comparisons of dose, frequency, and duration. | Consistent evidence for early risk (0 to 10 years after initiation of aspirin); 9 of 10 showed reduced risk with aspirin use. | RCT populations included primary and secondary CVD prevention patients and varied considerably in risk of all-cause mortality. | Good | Small benefit of aspirin on all-cause mortality within 10 years of starting treatment. Data on longer-term effects or comparing effects in subgroups were sparse.
KQ1/3. All-cause mortality and colorectal cancer mortality | General population CRC mortality k=8 RCT^*^ k=1 Cohort | Trial-level data not available for early and late risk of CRC mortality, (pooled results only). Long-term data not available from WHS or PHS. Limited direct comparisons of dose, frequency, and duration. | Consistent evidence on longterm cumulative risk from four studies; all showed aspirin reduced CRC mortality risk. | RCT participants were mostly male. Populations included primary and secondary CVD prevention. Studies conducted in United Kingdom, but likely applicable to United States. | Good | Evidence suggests aspirin reduces long-term CRC mortality ∼33 percent with an induction period of ∼10 years. Limited data suggest no effect on CRC mortality within 5 to 10 years of starting aspirin. Suggestion of greater risk reduction with longer duration of aspirin use but not higher dose. Data comparing effects in subgroups were sparse.
KQ1/3. All-cause mortality and colorectal cancer mortality | Persons with a prior adenoma All-cause mortality k=3 RCT | Few studies, short followup, small number of events. Limited direct comparisons of dose, frequency, and duration. | Limited available data appeared somewhat consistent. Too few studies and events for formal analysis. | Good applicability to persons with recent adenoma removal and polyp-free. | Good | Aspirin does not appear to reduce all-cause mortality in persons with a prior adenoma over a 3- to 4-year period. Data comparing effects over a longer followup period or in subgroups were lacking.
KQ1/3. All-cause mortality and colorectal cancer mortality | Persons with a prior adenoma CRC mortality k=0 | No data. | NA | NA | NA | NA
KQ4. Colorectal cancer incidence | General population k=6 RCT k=7 cohort | Trial-level data not available for one of the pooled estimates for long-term cumulative CRC risk. Limited direct comparisons of dose, frequency, and duration. | Evidence that aspirin reduces CRC incidence after 10-year latency and long-term cumulative risk was consistent across included trials. | Study populations included primary and secondary CVD prevention patients. | Good | Evidence suggests aspirin reduces long-term CRC incidence ∼20 to 24 percent with an induction period of ∼10 years. Limited evidence of differences in effect by dose, frequency, or duration. Data comparing effects in subgroups were lacking.
KQ4. Colorectal cancer incidence | Persons with a prior adenoma k=3 RCT | Few studies, short follow-up, small number of events. | In one study, aspirin users had lower risk than controls; in the other study, placebo group had lower risk. Data for third study not available separately from pooled data across three trials. | Applicable to persons with recent adenoma removal and polyp-free. | Good | Limited data did not suggest an association between aspirin use and CRC incidence over the short term (3 to 4 years) in persons with adenoma history.
KQ5. Colorectal adenoma incidence | General population k=1 cohort | Limited to one retrospective cohort study. | NA | Limited. Cohort members were all women and majority white. | Fair | A single cohort study reported a reduced risk of at least one distal adenoma with aspirin use.
KQ5. Colorectal adenoma incidence | Persons with a prior adenoma k=3 RCT | Few studies, short followup. | Not consistent across doses or followup times. | Applicable to persons with recent adenoma removal and polyp free. | Good | Some suggestion of reduced risk with over a 3- to 4-year period with low-dose aspirin (81 or 160 mg/day). Two RCTs suggested reduced risk of adenoma recurrence with 160 or 300 mg/day aspirin after 1 year (at followup colonoscopy), but effect of 300 or 325 mg/day over a 3- to 4-year period was unclear.
KQ7. Harms | Gastrointestinal bleeding k=12 RCT k=1 cohort | Small number of severe and fatal events. | Consistent increase in gastrointestinal bleeding risk in patients assigned to differing aspirin doses. Relative risk estimates for fatal gastrointestinal bleeding not consistent across four studies that reported them. | RCTs restricted to patients without contraindications to aspirin. | Fair | Evidence of increased risk of any gastrointestinal bleeding and serious gastrointestinal bleeding with aspirin use but not fatal gastrointestinal bleeding.
KQ7. Harms | Intracranial bleeding k=12 RCT | Definition not consistent across studies; small number of events. | Consistent increase in intracranial bleeding risk in patients assigned different aspirin doses. | RCTs restricted to patients without contraindications to aspirin. | Fair | Data suggest increased intracranial bleeding risk with aspirin.
KQ7. Harms | Hemorrhagic stroke k=11 RCT | RCTs restricted to patients without contraindications to aspirin. | Consistent increased risk of hemorrhagic stroke in patients assigned to aspirin. | RCTs restricted to patients without contraindications to aspirin. | Good | Consistent evidence suggested aspirin increased risk of hemorrhagic stroke.
KQ7. Harms | Age-related macular degeneration | See Evidence Synthesis for Aspirin for Prevention of All Cancers

* Includes WHS, which reported findings but did not provide data

Abbreviations: CRC = colorectal cancer; CVD = cardiovascular disease; KQ = key question; mg = milligram; NA = not applicable; PHS = Physicians' Health Study; RCT=randomized controlled trial; WHS = Women's Health Study

### Outcomes in Patients Selected in the General Population

#### Colorectal Cancer Incidence and Colorectal Cancer Mortality

We identified 11 RCTs and seven cohort studies reporting on aspirin and CRC outcomes or ACM in the general population. In these studies, aspirin appeared to reduce the risk of both CRC incidence and CRC mortality. Timing of aspirin use was important: the effect of aspirin use on these endpoints did not appear until approximately 10 years after treatment initiation. The observed latency in the effect did not necessarily correspond to duration of aspirin use. In fact, we did not find evidence that 10 years of use was absolutely required to achieve an effect on CRC incidence and CRC mortality. Many of the studies that reported an effect of aspirin on CRC incidence and mortality had average scheduled treatment durations of approximately 5 years. Thus, the observed lag in effect is probably not solely a function of longer duration of use. The latency in effect is consistent with the hypothesis that aspirin reduces adenoma development and progression into carcinoma over a period of many years. However, we could not evaluate this hypothesis directly: we were unable to find any RCTs and found only a single cohort study that reported the effect of aspirin on adenoma development in persons without a prior adenoma. Data from the cohort study were consistent with an impact on reduced adenoma incidence, but limited to a single population (women).

Although duration of use is unlikely to explain the latency in effect of aspirin on CRC incidence and CRC mortality entirely, we cannot rule out an association between duration of use and magnitude of effect. While there was some indirect evidence of an effect of duration of aspirin use, the only direct evidence supporting the potential importance of duration of use came from a single RCT111 and several cohort studies.160,161 Since most of the included studies had a scheduled duration of 5 years,83,85,111,135 we can draw only limited conclusions about short durations of use. We did not find evidence on a minimum required duration of use to prevent CRC incidence or CRC mortality.

All RCT data on aspirin and late or long-term risk of CRC mortality came from studies of daily aspirin use at 75 to 1,200 mg/day for primary and secondary CVD prevention.83,85 Point estimates were similar across the studies during comparable time intervals and did not suggest a difference by dose at or above 75 mg/day. However, only one trial reporting long-term CRC mortality (TPT) evaluated a low-dose (≤ 325 mg/day) aspirin intervention in a population without pre-existing CVD and no long-term studies of CRC mortality included women without pre-existing CVD. Data on late effects or long-term effects were not available from the two large U.S. primary prevention studies (WHS and PHS). Thus, when thinking about these results, carefully considering to whom they would be applied is crucial. In contrast, data on the association between CRC incidence and aspirin use were available from studies of daily and alternate-day aspirin use, thus more completely representing the primary CVD prevention population.113,135 Results were consistent across studies.

#### All-Cause Mortality

There was a small reduction in ACM within a 10-year interval from randomization. Point estimates were similar across 11 RCTs with varied doses and frequency of aspirin use (summary RR, 0.94 [95% CI, 0.89 to 0.99]). Average age at entry for the RCTs was 50 to 60 years. Although statistically significant, the upper confidence interval was near 1.0, possibly reflecting variations in effect by the doses and durations tested, as well as the studies included; for example, the RCTs included studies of primary and secondary prevention of CVD.83

We posit that aspirin's effect on ACM was smaller than its effect on CRC mortality for several reasons. First, we note that most of the ACM data were collected within 10 years of treatment initiation, when we did not observe an effect on CRC incidence or CRC mortality. Second, CRC mortality is only one component of ACM. Lack of an effect or an increase in other causes of death could outweigh a reduction in risk of CRC mortality.

### Outcomes in Persons With a Prior Adenoma

We found three RCTs (two good quality, one fair quality) of aspirin in persons with a prior adenoma who were adenoma-free at baseline.136,142,144 Two trials provided evidence of a reduced risk of adenoma recurrence with low-dose aspirin (81 to 160 mg/day) over three to four years.136 Two showed a reduced risk of 1-year adenoma recurrence with doses of 160 mg/day or 300 mg/day.123 Evidence for adenoma prevention with 300 to 325 mg/day over three to four years was inconsistent.

Data on CRC incidence and ACM were available from all three trials over the 3- to 4-year followup period. Event numbers were very low, but did not suggest differences between aspirin and placebo groups. Followup time points would not be sufficient to detect an impact on these outcomes if they were delayed 10 years, as was observed in the general population. None of the studies reported on CRC mortality.

### Harms

We found evidence that aspirin increases the incidence of gastrointestinal bleeding (any and serious), intracranial bleeding, and hemorrhagic stroke. Evidence for fatal gastrointestinal bleeding was less consistent across studies. However, many of our analyses were limited by low event rates. As described below in the Limitations section, the harms literature considered for this review was a subset of all available evidence, as it was limited to studies that also reported on CRC outcomes. A comprehensive review of harms of aspirin is included in a concurrent systematic evidence review prepared for the USPSTF.

## Other Systematic Reviews

Several other systematic reviews have been conducted on aspirin and CRC prevention, including the review conducted for the USPSTF in 2007.^81^ In this section, we compare and contrast our findings and propose explanations for noted differences between reviews. We limit our discussions to reviews published since 2007, as earlier reviews had access to a smaller body of literature. As described below, the primary reasons for differences are: 1) our review focused on people without high-risk genetic conditions (e.g., FAP, Lynch syndrome) or CRC; 2) our review focused on RCTs and cohort studies, primarily to fill evidence gaps on duration, frequency, and dose; and 3) our review had access to more recent data.

### 2007 Review for the USPSTF

In 2007, Dube and colleagues conducted a systematic evidence review for the USPSTF on aspirin for CRC prevention.81 They found limited and inconsistent evidence on aspirin and CRC mortality. Low-dose aspirin (100 mg or 325 mg every other day) did not decrease CRC incidence. There was fair evidence that high-dose use reduced CRC incidence; however, Dube and colleagues reported good evidence that aspirin reduced adenoma risk. At the time of the prior review, no RCTs had reported on CRC mortality. Since the publication of that review, Flossman and colleagues111 and Rothwell and colleagues83,85,86 published data on CRC outcomes during long-term followup using several trials of aspirin for CVD prevention, though these analyses included high-dose interventions and populations with preexisting CVD. Short-term CRC mortality data were available from the followup of seven studies by Rothwell and colleagues.83,85 However, for CRC incidence, we were also able to include longer-term followup from WHS.113 These data enabled us to look at CRC risk by followup period, which was not possible in 2007. Our observation of a lack of an early onset effect (0 to 10 years) of aspirin on CRC incidence was consistent with the Dube and colleagues' report on data available in 2007. The additional data permitted us to examine a potentially longer lag in the effect of aspirin on CRC incidence.

The 2007 Dube and colleagues review81 found evidence that aspirin reduced the risk of colorectal adenomas. We did not find strong evidence for this risk reduction. Dube and colleagues included PHS but we did not since PHS reported on all polyps but not specifically on adenomas. Our review also included 4-year, full-trial data from APACC, which was not available in 2007.^142^ Finally, ukCAP was published since the prior review.144 Based on these new findings, we did not find consistent evidence of a reduced risk of adenoma associated with aspirin use, but we could also not rule out the possibility of reduced risk.

### Meta-Analyses by Rothwell and Colleagues

Flossman and colleagues111 and Rothwell and colleagues83-85 published four IPD meta-analyses relevant to our systematic review. We identified only two RCTs (WHS and PHS) that were not included in at least one of the Rothwell analyses; thus, our results are fairly similar to the Rothwell and colleagues' reports.

In 2007, Flossman and colleagues published long-term followup data for CRC incidence from two RCTs of daily aspirin for CVD prevention (BMD and UK-TIA) covering 300 mg/day, 500 mg/day, and 1,200 mg/day doses.111 Subsequently, Rothwell and colleagues expanded this work to examine both CRC incidence and CRC mortality in these studies plus two other studies of low dose (75 mg/day) aspirin (SALT and TPT).85 In 2011, Rothwell and colleagues pooled individual patient data to study ACM (eight trials) and CRC mortality (six studies);83 these results were included in our review. Where results from individual trials were available, we included trial-level data. Otherwise, we recorded pooled estimates as reported. The results from Rothwell and colleagues were very influential on our review. They were the only data source for CRC mortality,83,85 although Cook and colleagues reported there was no early effect on CRC mortality in WHS (no data provided by randomization group).112 For CRC incidence, we also included data from PHS and WHS, which studied alternate-day aspirin use. Our findings were generally similar to Flossman and colleagues111 and Rothwell and colleagues83-85 and complementary, because they provide some evidence of consistency of effect by gender (through inclusion of WHS) and alternate-day aspirin use.

In 2012, Rothwell and colleagues performed a meta-analysis on cancer incidence and mortality using data from 51 trials of daily aspirin.84 Data were from 34 trials with in-trial (duration unspecified) CRC mortality data, from which Rothwell and colleagues computed OR, 0.58 (95% CI, 0.38 to 0.89) for the association between aspirin use and CRC death. We excluded these results in our review because we could not identify which 34 studies were selected to generate the computed OR and whether they all met our inclusion criteria. Nevertheless, the results of this meta-analysis are important because they provide different information to the previous Rothwell and colleagues reports,83,85 which were the sole sources of data on CRC mortality we identified in our systematic review. The 2012 Rothwell report focused on the effects of aspirin during the trial period (in contrast to the earlier report, which examined extended follow-up). Most of the trials had mean treatment periods less than five years. Thus, the data from Rothwell and colleagues in 2012^84^ suggest that the effect of aspirin on CRC mortality may occur earlier than previously thought, i.e., effects may manifest within 10 years after initiation of aspirin.

### Cooper 2010 Health Technology Assessment

As part of the United Kingdom Health Technology Assessment program, Cooper and colleagues prepared a systematic review on chemoprevention of CRC.63 Aspirin was one of the included agents. Their review of RCTs in the general population, i.e., “individuals at no increased risk of colorectal cancer” yielded four studies: WHS, PHS, BMD, and UK-TIA. These four studies were also included in our review. Qualitatively, our results were similar to the Cooper and colleagues 2010 review, which reported no reduction in risk of incident CRC with followup ≤10 years (pooled RR, 1.01 [95% CI, 0.84 to 1.21]). They reported a reduced risk of CRC during long-term followup in the higher-dose aspirin studies (pooled RR, 0.74 [95% CI, 0.57 to 0.97]), especially during 10 to 19 years of followup (pooled RR, 0.61 [95% CI, 0.43 to 0.88]). Rothwell and colleagues85 reported a similar finding for long-term followup when data from two very low dose (75 mg/day) trials were included.

Cooper and colleagues also reviewed the literature on RCTs of aspirin use in “intermediate-risk” persons, i.e., those with a prior adenoma (three studies) or CRC (one study). They reported a pooled RR for any adenoma recurrence (across the four studies) of 0.79 (95% CI, 0.68 to 0.92). Our review differed from Cooper and colleagues in two important ways. First, we excluded studies of patients with a prior CRC, for which the point estimate contributing to the Cooper meta-analysis was RR, 0.61 (95% CI, 0.44 to 0.86) and contributed a weight of 15.1 percent to the pooled estimate. Second, the results from the APACC trial that Cooper and colleagues included were from one year, whereas ours were from four years. APACC observed a benefit at one year but not four years for combined aspirin groups. Thus, the differences between our findings and those in Cooper and colleagues can be explained by differences in data sources.

### 2013 Health Technology Assessment Review

In their 2013 Health Technology Assessment systematic review, Sutcliffe and colleagues synthesized results from RCTs, systematic reviews, and meta-analyses published since 2008 and report results similar to ours. Using Sutcliffe and colleagues reference list168,169 we identified one systematic review we had not already retrieved,192 but no additional sources of primary data. The main contribution of the review by Sutcliffe and colleagues to our report was that it provided an attributable risk (risk difference) of CRC deaths averted with aspirin, as reported in our results section (34 to 36 per 100,000 person-years).

### Cole 2009

In 2009, Cole and colleagues published an individual meta-analysis using patient data from AFPP, APACC, and ukCAP, along with an aspirin RCT in people treated for CRC.123 They concluded that aspirin reduces the risk of colorectal adenomas in people with prior lesions. We included some of their results for KQs 4 and 5. However, not all of their findings were pertinent to our review, because they included a study in people with a personal history of CRC; this is the primary explanation for differences in our conclusions and the conclusions of Cole and colleagues.

### Systematic Reviews of Observational Studies

Two recent systematic reviews80,82 assessed the evidence on aspirin and CRC incidence from observational studies and a third review79 compared results from observational studies to RCTs. In general, the reviews were consistent, supporting a reduced risk of CRC with aspirin use. Combining case control and cohort studies, Bosetti and colleagues reported a pooled RR of 0.73 (95% CI, 0.67 to 0.79) for regular aspirin use (one or two tablets per week) and 0.66 (95% CI, 0.57 to 0.77) for daily aspirin use. They noted significant heterogeneity and some evidence of publication bias. Estimates of risk according to time since aspirin use were not provided; however, a slightly stronger reduction in risk was suggested for aspirin use ≥5 years compared to use less than 5 years. In addition, risk reduction was stronger for regular/high-dose (300 to 500 mg) compared to low-dose (∼100 mg) aspirin use.

In 2013, Ye and colleagues published a systematic review of cohort studies of aspirin and CRC risk, focusing on risk associated with different doses and durations of use.82 Our review included four of the five studies they included on dose. Of the nine studies they included for duration, we included seven. And, of the nine overlapping but not identical studies that they examined for frequency of use, we also included seven. We excluded studies because they were nested case-control studies or were missing information on dose. In general, Ye and colleagues found greater CRC risk reduction with higher doses, longer use, and more frequent aspirin use; however, these associations were not linear. People who used aspirin seven times per week had a reduced risk of CRC (RR, 0.82 [95% CI, 0.78 to 0.87]). The RR associated with 75 mg/day increment of aspirin was 0.90 (95% CI, 0.86 to 0.94) compared to 0.80 (95% CI, 0.74 to 0.88) for 325 mg/day and a similar estimate for 650 mg/day. This finding was consistent with our observations for cohort studies but not RCTs.

Algra and Rothwell performed a systematic review published in 2012 to meta-analyze and compare results on the association between aspirin and CRC incidence from RCTs (N=6), “standard” cohort studies (N=11), nested case-control studies (N=6), and case-control studies (N=26).79 Across all study designs, associations between aspirin and CRC based on pooled results were significant. The pooled OR estimate from case-control studies (0.67, [95% CI, 0.60 to 0.74]) was more similar to RCTs (OR, 0.58 [95% CI, 0.44 to 0.78]) than the estimate from cohort studies (OR, 0.85 [95% CI, 0.82 to 0.89]) or nested case-control studies (OR, 0.87 [95% CI, 0.75 to 1.00]). The authors attributed this finding to more detailed data collection on exposure in case-control studies. Nevertheless, their overall conclusion was that observational data provided results similar to RCT data.

## Limitations of the Review and Future Research Needs

Our review has several limitations based on scope, methods, and the available data.

### Scope

Because the review was conducted for the USPSTF, we limited our review to primary prevention of CRC in average-risk or intermediate-risk persons. We did not include persons with a history of CRC or known high-risk genetic conditions. There is a body of literature on the effectiveness of aspirin on CRC prevention in high-risk persons, but reviewing it was not within our scope based on our target audience. We also did not focus on short-term aspirin use (<1 year) or attempt to systematically address the benefit of aspirin combined with other interventions (pharmacological or otherwise).

### Methods

We followed rigorous systematic review and meta-analysis approaches; however, several elements of our approach warrant discussion. We undertook this review in parallel with two concurrent reviews for the USPSTF (Aspirin for the Primary Prevention of Cardiovascular Events, and Aspirin Use in Adults: Total Cancer, All-Cause Mortality and Harms). Therefore, in our review, we obtained data on ACM and harms of aspirin only from studies that reported on CRC outcomes. Thus, our findings should be considered to come from a specific body of literature focused on CRC. For ACM and aspirin harms, this review should be interpreted alongside other aspirin topic reviews.

For KQ 5 (adenoma incidence), we included only studies with pathologically confirmed outcomes. We excluded studies with self-report of any polyp type (e.g., PHS, WHS). We might have excluded some relevant data, but these data would not have directly informed our KQ of adenoma incidence and could be biased because of errors in self-report.

Excluding retrospective cohort studies and case-control studies may have influenced our results, primarily by excluding subgroups that may not have been well-represented in trials. However, our inclusion of prospective cohort studies offered some protection against this. Furthermore, as described above, a recent systematic review of observational studies and trials produced findings similar to those in this report.

### Available Data

Data for our review came primarily from three sources: 1) long-term followup of trials of aspirin for CVD prevention; 2) two U.S. trials of aspirin for CVD and cancer prevention; 3) trials of aspirin for adenoma recurrence; and 4) prospective cohort studies. All included studies were of fair-to-good quality and had many strengths. Although not necessarily a limitation, all CRC mortality data and much CRC incidence and ACM data were collected as part of followup studies of CVD trials by Flossman and colleagues and Rothwell and colleagues.83,85,111 No long-term data on CRC mortality were available from WHS or PHS for us to include in a meta-analysis.

The CRC data from the studies included by Rothwell (e.g., BMD, UK-TIA) are therefore not completely independent in the way they were collected and analyzed. This factor is not likely to affect the validity of the results, but is an important note about the size and variability of the literature. Our review yielded important information. However, data were insufficient to adequately address the following questions:

- Does the effect of aspirin on CRC incidence and mortality in average risk persons differ if use is daily or every other day?
- What is the effect of aspirin on CRC incidence and mortality in persons without a prior adenoma?
- Does aspirin reduce the risk of adenoma incidence in persons without a prior adenoma?
- Does aspirin reduce the long-term risk of all-cause or CRC-specific mortality in people with a history of adenoma?
- Does aspirin reduce the long-term risk of CRC incidence in people with a prior adenoma?
- Does the effect of aspirin on CRC incidence and mortality differ by age, sex, race, comorbidities, family history of cancer, or screening history?
- How long do the preventive effects of aspirin on CRC incidence and mortality last after aspirin is discontinued?
- Is there an optimal dose of aspirin for CRC prevention?

Disentangling the effects of recency and duration of aspirin use is inherently difficult. Recency has two dimensions: time since first use and time since last use. These can confound each another and both may be confounded by duration of use. For example, a person cannot have a long duration of use without a long time since first use; however the reverse is possible. We could not always assess the independent effects of these various components of timing of use. However, the consistency across studies in the timing of effect relative to first use (and across different durations of use) provides some assurance that the observed association with time since first use was not completely confounded by duration. Exposure misclassification presents another challenge in understanding the effects of recency and duration of use. In RCTs, participants may not have followed the study protocol (or may have used aspirin during followup after the active intervention) and in cohort studies they may not have recalled or reported their use accurately. Both scenarios could affect interpretation of recency and duration of use results.

## Applicability of Findings to Clinical Practice

In considering whether our findings are applicable to clinical practice in the U.S., we must address at least two important questions: 1) Are the trial populations representative of the U.S. population? And, in particular, how would findings apply to a population taking aspirin for CVD primary prevention? 2) Is aspirin persistence and adherence likely to differ in clinical practice compared to trials? Both questions address whether the benefits seen in trials are likely to be realized in practice.

Representativeness of trial populations is important if effectiveness or harms differ by subgroups (e.g., sex, race, comorbidities). The trials included in our systematic review were primarily among people who were white and did not have contraindications to aspirin, and with the exception of WHS, most trials were primarily in men. We did not find many direct comparisons of effects across subgroups defined by sex, race, or comorbidities, but the limited data we had comparing results across studies with different populations did not suggest differences by sex or CVD comorbidities. However, we did not have any data on potential differences in effect by race. This does not mean findings cannot be extrapolated to different racial and ethnic groups if we assume similar biological mechanisms of aspirin's effects, but we found no data supporting or refuting this assumption.

Adherence and persistence of aspirin use will likely influence effectiveness in clinical practice. The lowest persistence data from our review was from a single observational study using electronic dispensing data and suggested just over 50 percent persistence in the first year of use190 versus 80 to 92 percent reported in RCTs. As part of our analysis for our CQ, we found adherence and persistence levels to be highly consistent across studies regardless of population, country, or prevention target (i.e., adenoma recurrence, cancer prevention, primary CVD prevention, and secondary CVD prevention). Few trials required a run-in phase, suggesting that participants were not selected specifically for ability to comply. Ideally, one could obtain information on persistence from cohort studies in the general population. However, most cohort studies do not have data permitting analysis of persistence. Most present results according to duration of use, which is not the same as persistence. Short-term users may be current users who started recently as opposed to people who started in the past and discontinued. In sum, we have very little evidence on whether persistence and adherence in clinical practice are similar to trials.

Another important consideration for clinical practice is the timing of aspirin's benefits on CRC prevention. The available data suggested a latency of approximately 10 years from initiation of use. Therefore, benefits are not likely to be realized in people not expected to survive at least 10 years.

## Conclusion

Our systematic review provides evidence that aspirin reduces the risk of CRC incidence and CRC mortality in average-risk people, with an apparent time to preventive effect of approximately 10 years. Evidence suggests the risk reduction can be attained with 75 mg/day; however, data on duration of use or persistence of effect after discontinuation were limited. However, the applicability of longer-term effects on CRC mortality may be limited, given the paucity of studies including women, low-dose interventions, and populations without preexisting cardiovascular disease.

To date, few studies have examined whether aspirin prevents adenoma incidence in an average-risk population. However, some evidence suggests that using low-dose aspirin over a short time is associated with reduced risk of adenoma recurrence among people with a prior adenoma. Additional data on long-term effects on CRC incidence and CRC mortality in persons with a history of adenoma were lacking, as were results on CRC mortality from PHS and WHS. Despite the apparent protective effect of aspirin on CRC incidence and CRC mortality, data on ACM more than 10 years after initiation were sparse. Data on the effect of aspirin within 10 years of initiation were available and suggested that aspirin does not appear to have a strong effect on ACM within this period and that its use is associated with risks such as intracranial bleeding, gastrointestinal bleeding, and hemorrhagic stroke.

Based on the evidence gaps identified in our review, important directions for future research are to: 1) assess potential differences in subgroups, including demographic characteristics, lifestyle factors, and biomarkers; and 2) determine how long CRC prevention benefits persist after different durations of use and intervals from initiation. Data on potential differences in effects by subgroup and length of benefits may have important implications for clinical practice.