# Results

## Literature Search

Our literature searched yielded 865 unique abstracts; 149 met the criteria for full-text review (Appendix A Figure 2). We identified 14 RCTs and seven cohort studies of fair or good quality addressing KQ 1/3 (N=16), KQ 4 (N=16), KQ 5 (N=4), and KQ 7 (N=15). Included were 11 RCTs in the general population (i.e., persons selected without consideration of adenoma history) (Appendix D Table 1). None of these RCTs excluded patients based on their adenoma history so we presume the studies represent a mix of persons with and without past adenomas; however, these data were not reported. We identified three RCTs in patients with prior adenomas (Appendix D Table 2). Results on CRC outcomes and ACM from these 11 trials (all testing daily aspirin) were presented in IPD and study-level meta-analyses by Flossman and colleagues111 and Rothwell and colleagues.83,85 In addition, we identified two other RCTs of alternate-day aspirin for CVD and cancer primary prevention (Women's Health Study [WHS]112-116 and Physicians' Health Study [PHS]117-122). We also report results from an IPD meta-analysis by Cole and colleagues pooling colorectal adenoma and CRC incidence outcomes for the three RCTs conducted among persons with a prior adenoma.123 We identified seven eligible cohort studies addressing at least one of the KQs (Appendix D Table 3). All were in the general population (i.e., persons with a past adenoma were not specifically sampled or excluded) and all had at least one exposure group that met the threshold for frequency of aspirin use (daily or alternate day) for one of the KQs.

## Overall Body of Evidence

We included 14 RCTs (eight good quality, six fair quality) and seven prospective cohort studies (one good quality, six fair quality) assessing the effect of aspirin on CRC mortality, ACM, CRC incidence, and colorectal adenoma incidence. Characteristics of the included studies are in Appendix D Tables 1, 2, and 3.

Among the 11 trials that provided data on the general population (Appendix D Table 1), nine were CVD prevention studies among primary (six trials) and secondary prevention (three trials) populations that Flossman and colleagues111 and Rothwell and colleagues83,85 followed for CRC outcomes. They included RCTs of daily aspirin use for which data on CRC incidence or mortality could be obtained. In the 2010 report, Rothwell and colleagues included studies in the United Kingdom and Sweden with ≥1000 participants and a median scheduled duration of at least two and a half years.85 The report by Rothwell and colleagues in 2011 required a mean or median scheduled trial treatment period of at least four years and a range extending beyond five years.83 As all were fair or good quality, we included all aspirin versus placebo studies from their reports:

- British Medical Doctors trial (BMD) (fair quality) randomized 5,139 men (mean age: 61.6 years) to 500 mg/day vs. no aspirin. Participants assigned to aspirin were permitted to take 300 mg/day enteric-coated aspirin if requested. Median duration of treatment was 6.0 (range: 5.0 to 6.0) years.124
- UK Transient Ischaemic Attack (UK-TIA) trial (good quality) randomized 2,449 British men and women with recent transient ischemic attack (TIA) or minor ischemic stroke (mean age: 60.3 years) to 300 mg/day aspirin, 1,200 mg/day of aspirin, or placebo. Median duration of treatment was 4.4 (range: 1.0 to 7.1) years.125,126
- Thrombosis Prevention Trial (TPT) (good quality) randomized 5,085 men (mean age: 57.5 years) in a 2 × 2 factorial design to 75 mg/day aspirin vs. placebo and warfarin vs. placebo. Median duration of treatment was 6.9 (range: 4.3 to 8.6) years.108
- Swedish Aspirin Low-dose Trial (SALT) (good quality) randomized 1,363 Swedish men and women with a recent TIA, minor stroke, or retinal artery occlusion (mean age: 66.9 years) to 75 mg/day aspirin vs. placebo. Median duration of treatment was 2.7 (range: 1.0 to 5.3) years.127
- Early Treatment Diabetic Retinopathy Study (ETDRS) (good quality) randomized 3,711 men and women with diabetes with certain categories of diabetic retinopathy (mean age: 51 years) to 650 mg/day of aspirin vs. placebo. Median duration of treatment was 5.0 (range: 4.0 to 9.0) years.128,129
- Swedish Angina Pectoris Aspirin Trial (SAPAT) (fair quality) randomized 2,035 Swedish men and women with chronic stable angina pectoris without prior myocardial infarction (mean age: 67 years) to 75 mg/day aspirin vs. placebo. Median duration of treatment was 4.2 (range: 1.9 to 6.3) years.130
- Japanese Primary Prevention of Atherosclerosis With Aspirin for Diabetes (JPAD) (fair quality) randomized 2,539 Japanese men and women with type 2 diabetes but without a history of atherosclerotic disease (mean age: 64.5 years) to aspirin (patient choice of 81 or 100 mg/day) vs. no recommendation to take aspirin. Median duration of treatment was 4.4 (3.0 to 5.4) years.131
- Prevention of Progression of Arterial Disease and Diabetes (POPADAD) (fair quality) randomized 1,276 Scottish men and women with diabetes and asymptomatic peripheral arterial disease (mean age: 60.3 years) to 100 mg/day of aspirin vs. placebo. Median duration of treatment was 6.7 (4.5 to 8.6) years.132
- Aspirin for Asymptomatic Atherosclerosis (AAA) (fair quality) randomized 3,350 Scottish men and women with no history of vascular disease and with low ankle brachial index (mean age: 62.0 years) to 100 mg/day of aspirin vs. placebo. Median duration of treatment was 8.2 (6.7 to 10.5) years.133

The studies were conducted in Europe, the United Kingdom, Japan, and North America. All were studies of daily aspirin use with doses ranging from 75 mg/day to 1,200 mg/day with six studies of 75 mg/day to 100 mg/day aspirin, one each of 300 mg/day, 500 mg/day, or 625 mg/day, and one study with both 300 mg/day and 1,200 mg/day arms. The majority of participants were men in most studies, including several studies restricted to men.

Flossman and colleagues111 ascertained long-term (∼20-year followup) CRC incidence data (good quality) on participants from the BMD and UK-TIA trials (N=7,588) and used individual patient data for their analyses. Subsequently, Rothwell and colleagues85 analyzed long-term CRC incidence data (fair quality) and CRC mortality data (good quality) from participants in the BMD, UK-TIA, TPT, SALT studies (N=14,033) and presented results from both study-level and IPD meta-analyses. In 2011, Rothwell and colleagues83 (good quality) reported on ACM in participants from eight of the trials (all except SALT) (N=25,570) and CRC mortality from BMD, UK-TIA, TPT, JPAD, POPADAD, and AAA (N=19,824). ACM data were reported by trial, while CRC mortality data were reported separately by trial for some analyses and pooled for others.

We identified two additional RCTs providing data on CRC incidence that did not meet Flossman and colleagues' and Rothwell and colleagues' inclusion criteria related to frequency of use (i.e., daily use). WHS112-116 (good quality) and PHS117-122,134,135 (good quality) were both conducted among U.S. health professionals to determine whether aspirin reduces the risk of CVD or cancer. WHS randomized 39,876 women in the United States (mean age: 54.6 years) to 100 mg of alternate day aspirin vs. placebo (2 × 2 factorial with vitamin E) for approximately 10 years. Followup extended for a median of 17.5 (range: 10.4 to 18.8) years. PHS randomized 22,071 male doctors (mean age: 53.2 years) to 325 mg of aspirin every other day vs. placebo (2 × 2 factorial with beta carotene). The aspirin part of trial was terminated after an average of five years because of a significant decrease in myocardial infarction incidence in the aspirin arms; however, participants were followed for CRC incidence and ACM for a mean of 12 years. Both WHS and PHS studies provided data on CRC incidence and ACM, but not on CRC mortality.

None of the 11 trials in the general population reported on adenoma incidence. Only WHS and PHS planned to study cancer outcomes as primary aims. However, followup by Flossman and colleagues111 and Rothwell and colleagues83,85 for CRC outcomes in CVD trials was based on national cancer registry data and therefore likely to be complete and unbiased by exposure status. The main limitation was with incidence data from the SALT trial, which was limited to fatal cancers. The original CVD trials were good quality (UK-TIA, TPT, SALT, ETDRS, PHS, and WHS) or fair quality (BMD, SAPAT, JPAD, POPADAD, and AAA). Studies were classified as fair based on unblinded exposure (BMD and JPAD), low adherence to treatment (BMD, POPADAD, and AAA), or missing information (AAA, JPAD, and SAPAT).

Three of the 14 identified RCTs focused on patients with a prior adenoma who were adenoma free at baseline (Appendix D Table 2). These studies were conducted in France, the United Kingdom, Canada, and the United States. All studies required removal of all polyps at a baseline colonoscopy, and all had protocols with scheduled followup colonoscopies at 3 to 4 years after randomization. Doses ranged from 81 mg/day to 325 mg/day. The primary weakness of these studies was limited followup.

The Aspirin/Folate Polyp Prevention (AFPP) Study123,136-140 (good quality) was conducted among 1,121 U.S. men and women with a prior adenoma (either ≥1 adenomas in the 3 months before recruitment, ≥1 adenomas removed in the 16 months before recruitment and a lifetime history of ≥2 adenomas, or an adenoma ≥1 cm removed in the 16 months before recruitment) and with confirmation of no remaining polyps in the three months before recruitment. Patients were randomized to 81 mg/day of aspirin, 325 mg/day of aspirin, or placebo in a factorial design with folate vs. placebo. The protocol called for a followup colonoscopy 34 to 40 months after the qualifying colonoscopy; more than 95 percent of participants in each group completed followup examinations.

The Association pour la Prevention par l'Aspirine du Cancer Colorectal (APACC)123,141-143 study (fair quality) was conducted among 272 French men and women who had undergone a colonoscopy with adequate bowel preparation and visualized cecum, had ≥3 adenomas or ≥1 adenoma 6 millimeters or larger, and removal of all polyps in the three months before study entry. Participants were randomized to 160 mg/day of aspirin, 300 mg/day of aspirin, or placebo. The protocol specified followup colonoscopies at 1 and 4 years. We assigned the study a fair quality rating in part because only 73 percent of participants in the aspirin group and 63 percent in the placebo group received a 4-year colonoscopy (the primary timepoint for the outcome); however, at 1 year, 90 percent were followed in the intervention groups and 85 percent in the placebo group.

The United Kingdom Colorectal Adenoma Prevention trial (ukCAP)123,144,145 was a good-quality RCT performed among 945 British men and women with a colorectal adenoma ≥0.5 cm that was removed in the 6 months before recruitment (or earlier if they also had ≥1 adenoma removed in the 6 months before randomization). Participants were randomized to either 300 mg/day of aspirin or placebo in a 2 × 2 factorial design with folate. Approximately 91 percent of both intervention and control participants received followup colonoscopies.

Adenomas during followup were diagnosed by pathologists per study protocol. All trials looked at advanced lesions in addition to the main outcome of any adenoma. Advanced lesions were defined by size, percent villous, or presence of severe dysplasia. The definition of advanced lesions differed slightly across studies, mostly about including CRC in the advanced lesions category.

We identified seven cohort studies to supplement data from RCTs on information about duration, dose, and recency of aspirin use. All had at least one exposure group that met the threshold for frequency of aspirin use (daily or alternate day) at ≥75 mg/day. Cohort studies varied in terms of characteristics of populations followed and methods of ascertaining aspirin use.

- Nurses' Health Study (NHS)146-151 (fair quality) enrolled U.S. women nurses aged 35 to 55 years in 1976. Aspirin use was assessed by baseline survey (including questions about past use) in 1980 and then every two years. Women were followed for CRC through June 2000 (N=82,911 eligible for CRC analyses).
- Health Professionals Followup Study (HPFS)152 (fair quality) recruited U.S. men health professionals (mean age: 54 years) in 1986 (N=47,363 eligible for CRC analyses). Aspirin use was assessed by baseline survey. Patients were followed for up to 18 years.
- A study by Larsson and colleagues pooled data from the Swedish Mammography Cohort and the Cohort of Swedish Men, collecting outcomes on CRC from 1997 to 2005 (fair quality).153 Analyzed were 74,250 participants with a mean age at cohort entry of 60.6 years. Data on aspirin use was collected at a baseline survey. Participants were followed for a mean of 7.2 years.
- The Cancer Prevention Study II (CPSII) (N=662,424 included in analysis) and the Nutrition Cohort subset (N=146,113 and N=100,139 included in CRC incidence and mortality analyses, respectively) (fair quality)154-158 were initiated in 1982 and 1992, respectively. The mean age in CPSII was 57 years at recruitment in 1982. Aspirin use was assessed at CPSII cohort entry and again in 1992-1993 when the Nutrition Cohort was initiated, and approximately every two years thereafter. Participants in the Nutrition Cohort analyses were followed for up to 16 years.
- The Danish Diet, Cancer, and Health Study (fair quality) was conducted in 1995 to 2006 (N=51,053 included in analyses).159,160 The mean age of participants was 56.2 years. Aspirin use was assessed in a baseline survey and then from prescription records during followup. Participants were followed for a mean of 9.4 years.
- The VITamins And Lifestyle (VITAL) study (fair quality) was conducted in Washington State beginning in 2000.^161,162^ Participants averaged 61 years of age at cohort entry (N=64,847 included in analyses). Aspirin use was ascertained on a baseline survey. Median followup time was 7 years.
- The WHI Observational Cohort163-167 (good quality) included 91,574 women in CRC analyses. Average age at entry was 63.5 years. Aspirin use was assessed with baseline and 3-year followup questionnaires. Women were followed for an average of 6.4 years.

Cohort studies supplemented RCTs by providing additional data on frequency, dose, duration, and timing of use. In general, the quality of the cohort studies was fair. A main limitation was that several studies assessed exposure only at baseline with a lengthy recall period. In addition, some studies had analytic concerns including handling of potential confounders, exclusion (rather than censoring) of participants who did not complete followup surveys, and lack of clarity around analytic strategies for time-varying confounders. Making valid comparisons across cohort studies and between cohort studies and RCTs was limited based on differences in how exposure to aspirin was assessed and categorized. For many of the cohort studies we did not use the overall reported RR estimates, which included as aspirin users persons who did not meet our minimum use criteria.

Where possible for all outcomes, we emphasize the combined induction and latency period (i.e., the time between initiation of use and the appearance of the outcome effect, hereafter referred to as the “latency period”). In general, the included studies did not provide much data stratified by race, gender, or comorbidities. However, we were able to make some indirect comparisons in RR estimates across studies that differed in included populations, but found little direct evidence for different subgroups.

## KQs 1 and 3 Does Regular Aspirin Use Reduce Colorectal Cancer Mortality or All-Cause Mortality in Adults Without a History of Colorectal Cancer, Familial Adenomatous Polyposis, or Lynch Syndrome?

### Summary of Results

We stratified study results by whether or not participant adenoma history was considered. In people selected without consideration of adenoma history (i.e., general population) we analyzed available data from 11 RCTs with 88,877 individuals from primary CVD or cancer prevention or secondary CVD prevention populations receiving 75 mg to 1,200 mg aspirin daily or every other day. The results were consistent with a small ACM risk reduction in the first 10 years after randomization (summary RR, 0.94 [95% CI, 0.89 to 0.99]) (Table 1, Figure 2); data on longer-term followup were sparse. In contrast, aspirin (75 to 1200 mg per day) was associated with an approximately 33 percent reduced long-term cumulative risk of CRC mortality (k=4 trials, N=14,033, 240 CRC deaths). Risk reduction occurred after a latent period of approximately 10 years since first use (Table 2, Figure 3). Risk reduction appeared greater with increasing duration of use, but not dose. Two cohort studies supplemented information from RCTs.

Table 1 Effect of Aspirin on All-Cause Mortality in Randomized, Controlled Trials, Overall and by Followup Period

Study | Treatment Group | Early Onset Risk (0 to 10^†^ Years) | | Long-Term Cumulative Risk (0 to 20 Years)
Study | Treatment Group | Events/N (%) | Relative Risk Estimate (95% CI) | Events/N (%) | Relative Risk Estimate (95% CI)
WHS112-114 | 100 mg qod | 609/19,934 (3.1%)^*^ | RR, 0.95 (0.85 to 1.06) | 1,744/19,934 (8.7)^*^ | HR, 1.00 (0.94 to 1.07)\|\|
WHS112-114 | Placebo | 642/19,942 (3.2%)^*^ | RR, 0.95 (0.85 to 1.06) | 1,728/19,942 (8.7)^*^ | HR, 1.00 (0.94 to 1.07)\|\|
PHS118 | 325 mg qod | 217/11,037 (2.0%)^*^ | RR, 0.96 (0.80 to 1.14) | NR | NR
PHS118 | Placebo | 227/11,034 (2.1%)^*^ | RR, 0.96 (0.80 to 1.14) | NR | NR
BMD83 | 500 mg/day | 270/3,429 (7.9%)^*^ | OR, 0.88 (0.72 to 1.09) | IG: NR^‡^ CG: NR^‡^ | HR, 0.96 (0.90 to 1.02)
BMD83 | Control (no placebo) | 151/1,710 (8.8%)^*^ | OR, 0.88 (0.72 to 1.09) | IG: NR^‡^ CG: NR^‡^ | HR, 0.96 (0.90 to 1.02)
UK-TIA83 | 300 or 1200 mg/day | 221/1,621 (13.6%)^*^ | OR, 0.90 (0.70 to 1.14) | IG: NR^‡^ CG: NR^‡^ | HR, 0.96 (0.90 to 1.02)
UK-TIA83 | Placebo | 122/814 (15.0%)^*^ | OR, 0.90 (0.70 to 1.14) | IG: NR^‡^ CG: NR^‡^ | HR, 0.96 (0.90 to 1.02)
TPT83 | 75 mg/day | 216/2,545 (8.5%)^*^ | OR, 1.06 (0.87 to 1.29) | IG: NR^‡^ CG: NR^‡^ | HR, 0.96 (0.90 to 1.02)
TPT83 | Placebo | 205/2,540 (8.1%)^*^ | OR, 1.06 (0.87 to 1.29) | IG: NR^‡^ CG: NR^‡^ | HR, 0.96 (0.90 to 1.02)
SALT85 | 75 mg/day | 61/676 (9.0%)^*^ | NR | NR | NR
SALT85 | Placebo | 69/684 (10.1%)^*^ | NR | NR | NR
ETDRS83 | 650 mg/day | 340/1,856 (18.3%)^*^ | OR, 0.91 (0.77 to 1.08) | NR | NR
ETDRS83 | Placebo | 366/1,855 (19.7%)^*^ | OR, 0.91 (0.77 to 1.08) | NR | NR
SAPAT83 | 75 mg/day | 82/1,009 (8.1%)^*^ | OR, 0.77 (0.57 to 1.04) | NR | NR
SAPAT83 | Placebo | 106/1,026 10.3%)^*^ | OR, 0.77 (0.57 to 1.04) | NR | NR
JPAD83 | 81 or 100 mg/day^§^ | 33/1,262 (2.6%)^*^ ¶ | OR, 0.88 (0.55 to 1.40) | NR | NR
JPAD83 | Placebo | 38/1,277 (3.0%)^*^ | OR, 0.88 (0.55 to 1.40) | NR | NR
POPADAD83 | 100 mg/day | 94/638 (14.7%)^*^ | OR, 0.92 (0.68 to 1.25) | NR | NR
POPADAD83 | Placebo | 101/638 (15.8%)^*^ | OR, 0.92 (0.68 to 1.25) | NR | NR
AAA83 | 100 mg/day | 176/1,675 (10.5%)^*^ | OR, 0.94 (0.76 to 1.17) | NR | NR
AAA83 | Placebo | 186/1,675 (11.1%)^*^ | OR, 0.94 (0.76 to 1.17) | NR | NR

* Calculated

† Variable follow-up by trial duration, in-trial results

‡ Minimum 5 years scheduled duration of intervention; included BMD, UKTIA, and TPT.83 Combined N=10,502. Total events, events by group, and denominators by group not reported

§ Dose not randomized

|| Median follow-up in WHS was 17.5 years

¶ 34 events reported in main trial131

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; BMD = British Medical Doctors trial; CG = control group; CI = confidence interval; ETDRS = Early Treatment Diabetic Retinopathy Study; HR = hazard ratio; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis With Aspirin for Diabetes; mg = milligrams; NR = not reported; OR = odds ratio; PHS = Physicians' Health Study; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; qod = every other day; RR = relative risk; SALT = Swedish Aspirin Low-dose Trial ; SAPAT = Swedish Angina Pectoris Aspirin Trial; TPT = Thrombosis Prevention Trial; UK-TIA = UK Transient Ischaemic Attack trial; WHS = Women's Health Study

Figure 2 Effect of Aspirin on Early Risk (0 to 10 years) of All-Cause Mortality

Note: Differences from point estimates or 95% confidence intervals reported in studies are due to use of different statistical programs, and are minor and of no clinical or statistical significance

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ABI = ankle brachial index; BMD = British Medical Doctors trial; CI = confidence interval; CG = control group; ETDRS = Early Treatment Diabetic Retinopathy Study; IG = intervention group; IHD = ischemic heart disease; JPAD = Japanese Primary Prevention of Atherosclerosis With Aspirin for Diabetes; mg = milligram; MI = myocardial infarction; PHS = Physicians' Health Study; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; RAO = retinal artery occlusion; RR = relative risk; SALT = Swedish Aspirin Low-dose Trial; SAPAT = Swedish Angina Pectoris Aspirin Trial; TIA = transient ischemic attack; TPT = Thrombosis Prevention Trial; UK-TIA = United Kingdom Transient Ischaemic Attack trial; WHS = Women's Health Study; yrs = years

This figure is a forest plot of the relative risk of early all-cause mortality

Table 2 Effect of Aspirin on Colorectal Cancer Mortality in Randomized, Controlled Trials, Overall and by Followup Period

Study | Treatment Group^§^ | Early Onset Risk (0 to 10 Years) | | Late Onset Risk (10 to 20 Years) | | Long-Term Cumulative Risk (0 to 20+ Years)^‡^
Study | Treatment Group^§^ | Events/N (%) | Relative Risk Estimate (95 % CI) | Events/N (%) | Relative Risk Estimate (95% CI) | Events/N (%) | Relative Risk Estimate (95% CI)
WHS112 | 100 mg qod | Total: 65 IG: NR CG: NR | Reported as “no difference” | NR | | NR
WHS112 | Placebo | Total: 65 IG: NR CG: NR | Reported as “no difference” | NR | | NR
PHS | 325 mg qod | NR | | NR | | NR
PHS | Placebo | NR | | NR | | NR
BMD83,85 | 500 mg/day | IG: NR^†^ CG: NR^†^ | HR, 0.79 (0.49 to 1.26)^†^ | IG: NR^†^ CG: NR^†^ | HR, 0.51 (0.35 to 0.74)^†^ | IG: 59/3,429 (1.7%)^*^ | OR, 0.73 (0.49 to 1.10)
BMD83,85 | Control (no placebo) | IG: NR^†^ CG: NR^†^ | HR, 0.79 (0.49 to 1.26)^†^ | IG: NR^†^ CG: NR^†^ | HR, 0.51 (0.35 to 0.74)^†^ | CG: 40/1,710 (2.3%)^*^ | OR, 0.73 (0.49 to 1.10)
UK-TIA83,85 | 1,200 mg/day | IG: NR^†^ CG: NR^†^ | HR, 0.79 (0.49 to 1.26)^†^ | IG: NR^†^ CG: NR^†^ | HR, 0.51 (0.35 to 0.74)^†^ | IG: 11/821 (1.3%)^*^ | OR, 0.68 (0.31 to 1.47)
UK-TIA83,85 | 300 mg/day | IG: NR^†^ CG: NR^†^ | HR, 0.79 (0.49 to 1.26)^†^ | IG: NR^†^ CG: NR^†^ | HR, 0.51 (0.35 to 0.74)^†^ | IG: 8/811 (1.0%)^*^ | OR, 0.50 (0.21 to 1.17)
UK-TIA83,85 | Placebo | IG: NR^†^ CG: NR^†^ | HR, 0.79 (0.49 to 1.26)^†^ | IG: NR^†^ CG: NR^†^ | HR, 0.51 (0.35 to 0.74)^†^ | CG: 16/817 (2.0%)^*^ | OR, 0.50 (0.21 to 1.17)
TPT83,85 | 75 mg/day | IG: NR^†^ CG: NR^†^ | HR, 0.79 (0.49 to 1.26)^†^ | IG: NR^†^ CG: NR^†^ | HR, 0.51 (0.35 to 0.74)^†^ | IG: 34/2,545 (1.3%)^*^ | OR, 0.61 (0.40 to 0.94)
TPT83,85 | Placebo | IG: NR^†^ CG: NR^†^ | HR, 0.79 (0.49 to 1.26)^†^ | IG: NR^†^ CG: NR^†^ | HR, 0.51 (0.35 to 0.74)^†^ | CG: 55/2,540 (2.2%)^*^ | OR, 0.61 (0.40 to 0.94)
SALT85 | 75 mg/day | NR | | NR | | IG: 7/676 (1.0%)^*^ | OR, 0.71 (0.27 to 1.86)
SALT85 | Placebo | NR | | NR | | CG: 10/684 (1.5%)^*^ | OR, 0.71 (0.27 to 1.86)

* Calculated

† Minimum 5 years scheduled duration of intervention; included BMD, UKTIA, and TPT.83 Combined N=10,502. Total events by group, and denominators by group not reported

‡ Reported in Rothwell 2010^85^

§ Median scheduled treatment duration was: 6.0 years (BMD), 4.4 years (UK-TIA), 6.9 years (TPT), and 2.7 years (SALT)

Abbreviations: BMD = British Medical Doctors trial; CG = control group; CI = confidence interval; HR=hazard ratio; IG = intervention group; mg = milligram; NR = not reported; OR = odds ratio; PHS = Physicians' Health Study; qod = every other day; SALT = Swedish Aspirin Low-dose Trial; TPT = Thrombosis Prevention Trial; UK-TIA = UK Transient Ischaemic Attack trial; WHS = Women's Health Study

Figure 3 Effect of Aspirin on Long-Term Risk (0 to ≥20 Years) of Colorectal Cancer Mortality

Note: Differences from point estimates or 95% confidence intervals reported in studies are due to use of different statistical programs, and are minor and of no clinical or statistical significance

Abbreviations: BMD = British Medical Doctors trial; CG = control group; CI = confidence interval; IG = intervention group; IHD = ischemic heart disease; mg = milligram; RAO = retinal artery occlusion; RR = relative risk; SALT = Swedish Aspirin Low-dose Trial; TIA = transient ischemic attack; TPT = Thrombosis Prevention Trial; UK-TIA = United Kingdom Transient Ischaemic Attack; yrs = years

This figure is a forest plot of the relative risk of long-term colorectal cancer mortality

Aspirin use and ACM data in persons with a prior adenoma were based on two good-quality and one fair-quality RCTs of 2,332 persons randomized to between 81 mg/day and 325 mg/day of aspirin. Overall, in persons with a prior adenoma, aspirin did not appear to reduce ACM over 3 to 4 years, but data were sparse (Table 3, Figure 4). No data were available on CRC mortality in persons with a past adenoma.

Table 3 Effect of Aspirin on 3- to 4-Year All-Cause Mortality From Randomized, Controlled Trials of Persons With a Prior Adenoma

Study | Treatment Group | Death During Followup, Events/N (%) | Relative Risk Estimate (95% CI)
APACC142 | 160 mg/day | 0/140 (0%) | NR
APACC142 | 300 mg/day | 0/140 (0%) | NR
APACC142 | Placebo | 1/132 (0.8%) | NR
ukCAP144 | 300 mg/day | 12/472 (2.5%)^*^ | NR
ukCAP144 | Placebo | 11/467 (2.4%)^*^ | NR
AFPP136 | 81 mg/day | 3/377 (0.8%) | NR
AFPP136 | 325 mg/day | 4/372 (1.1%) | NR
AFPP136 | Placebo | 3/372 (0.8%) | NR

* Calculated

Abbreviations: AFPP = Aspirin/Folate Polyp Prevention Study; APACC = Association pour la Prevention par l'Aspirine du Cancer Colorectal (APACC) study; CI = confidence interval; mg = milligrams; NR = not reported; ukCAP = United Kingdom Colorectal Adenoma Prevention trial

Figure 4 Effect of Aspirin on 3- to 4-Year Risk of All-Cause Mortality in Persons With a Prior Adenoma

Abbreviations: AFPP = Aspirin/Folate Polyp Prevention study; APACC = Association pour la Prevention par l'Aspirine du Cancer Colorectal study; CG = control group; CI = confidence interval; IG = intervention group; mg = milligram; OR = odds ratio; ukCAP = United Kingdom Colorectal Adenoma Prevention trial; yrs = years

This figure is a forest plot of the relative risk of all-cause mortality among persons with a prior adenoma

### Detailed Findings: Aspirin and All-Cause Mortality in the General Population

#### Included Studies and Main Results

Included were 11 RCTs (six good quality, five fair quality) that were primary or secondary CVD prevention studies (two also included cancer as a primary outcome) (Table 1, Figure 2). The RCTs were WHS, PHS, BMD, UK-TIA, TPT, ETDRS, SAPAT, JPAD, POPADAD, AAA, and SALT. Study-level ACM results for all studies except WHS, PHS, and SALT were reported by Rothwell and colleagues.83

Point estimates across trials were similar, and most were in the direction of a small, beneficial effect on ACM (summary RR, 0.94, [95% CI, 0.89 to 0.99]). Very few included studies had followup longer than 10 years, and few studies used dosages other than those considered low dosage (≤325 mg daily). Limited data suggested no variation according to dose or duration studied or followup length.

Rothwell and colleagues83 presented data for in-trial ACM for 25,570 participants from eight trials of primary and secondary CVD prevention (the same trials as we include minus WHS, PHS, and SALT); median trial duration was 4.2 years in SAPAT to 8.2 years in AAA. Aspirin dosages were 75 mg/day to 1,200 mg/day. At the person-level, the shortest scheduled duration of aspirin use was 1.0 year (UK-TIA) and the longest was 10.5 years (AAA). The average age of participants was 59.8 years and 29.4 percent were women. Rothwell and colleagues reported a pooled odds ratio (OR) of 0.92 (95% CI, 0.85 to 1.00) from a study-level meta-analysis on ACM and aspirin use. In an IPD meta-analysis of 10,502 persons from BMD, UK-TIA, and TPT with a scheduled intervention duration ≥5 years, Rothwell and colleagues found no definite impact on ACM (HR, 0.96 [95% CI, 0.90 to 1.02]) over a 20-year followup.83

#### All-Cause Mortality and Recency of Aspirin Use

##### Time Since First Use

Data on aspirin and ACM were available according to followup period, defined as the average time since randomization. We divided followup periods into early onset risk (within 10 years of randomization), late onset risk (10 to 20 years after randomization), and long-term cumulative risk (from randomization to ≥20 years). All 11 RCTs presented data on early onset risk of ACM, although length of followup differed slightly by trial (Table 1, Figure 2). The summary RR estimate across the trials was 0.94 (95% CI, 0.89 to 0.99). No RCTs provided data on late onset risk of ACM. However, WHS results and pooled results from BMD, UK-TIA, and TPT suggested no reduction in long-term cumulative (0- to 20-year) risk (Table 1). The literature search did not identify cohort studies with data on the association between recency of aspirin use and ACM.

##### Time Since Last Use

None of the studies reported on an association between risk of ACM and time since last aspirin use.

#### All-Cause Mortality and Aspirin Dose and Frequency

RR estimates were similar across studies that varied by dose or frequency of use (Table 1, Figure 2). Thus, indirect evidence did not suggest a difference in effect according to dose or use frequency. UK-TIA was the only study that randomized patients to different doses of aspirin and placebo. The original UK-TIA study reported a slightly lower ACM risk in the two aspirin arms compared to placebo (1,200 mg/day aspirin: 13.7%; 300 mg/day aspirin: 13.5%; placebo: 15.0%; p-value not reported).126

One cohort study reported on the association between aspirin use and ACM. NHS reported age-standardized mortality rates by number of standard aspirin tablets per week.146 Number of tablets per week does not have a definitive correspondence with frequency of use; however, we assume that increasing number of tablets per week is related to increased frequency of use. Although no RRs or p-values for trend were presented, no clear association was suggested between tablets per week and mortality rates: 3.86 per 1,000 person-years for 0 tablets/week, 2.70 per 1,000 person-years for 0.5 to 1.5 tablets/week, 3.05 per 1,000 person-years for 2 to 5 tablets/week, 3.36 per 1,000 person-years for 6 to 14 tablets/week, and 4.20 per 1,000 person-years for more than 14 tablets/week.

#### All-Cause Mortality and Duration of Aspirin Use

None of the RCTs compared the effect of different scheduled durations of aspirin use on ACM. However, RR estimates for ACM risk reductions in PHS, WHS, and Rothwell and colleagues studies were similar even though intervention lengths differed across studies: 5-year median in PHS, 10-year median in WHS, and 1.0- to 10.5-year range in CVD prevention studies reported by Rothwell and colleagues. Thus, indirect evidence did not suggest a difference in effect according to duration of aspirin use. However, it is important to note that the scheduled duration of use may not have been equal to the actual duration. The literature search did not identify cohort studies with additional data on the association between duration of aspirin use and ACM.

#### All-Cause Mortality: Effect Modification by Age, Sex, Race, and Comorbidities

None of the studies provided within-trial comparisons on differences in the effect of aspirin use on ACM according to age, race, or comorbidities. ETDRS presented 5-year RRs for aspirin use by gender, which were similar in men (RR, 0.94 [95% CI, 0.73 to 1.22]) and women (RR, 0.88 [95% CI, 0.65 to 1.17]).128 In UK-TIA, the percent of men who died during followup was slightly lower in the intervention groups than the placebo group (1,200 mg/day aspirin: 14.5%; 300 mg/day aspirin: 14.8%; placebo: 17.0%; p-value not reported); however, the same trend was not apparent in women (1,200 mg/day aspirin: 11.7%; 300 mg/day: 9.9%; placebo: 10.0%; p-value not reported).126 RR estimates were similar across studies limited to men (PHS) vs. women (WHS).

RR estimates were similar across the CVD prevention studies that enrolled patients with different comorbidities, i.e., recent TIA or minor ischemic stroke (UK-TIA, SALT), diabetes (JPAD, ETDRS, POPADAD), angina pectoris (SAPAT), low ankle brachial index (AAA), or high risk of ischemic heart disease (TPT). The literature search did not identify cohort studies with additional data on differences in the association between aspirin use and ACM by age, sex, race, or comorbidities.

### Detailed Findings: Aspirin and Colorectal Cancer Mortality in the General Population

#### Included Studies and Main Results

Rothwell and colleagues85 presented data on the association between long-term cumulative (0 to 20+ years) risk of CRC mortality and aspirin use from four primary or secondary CVD prevention RCTs (three good quality, one fair quality): BMD, UK-TIA, TPT, and SALT (N=14,033) (Table 2, Figure 3). They reported a pooled OR, 0.66 (95% CI, 0.51 to 0.85). Using the Mantel-Haenszel method, we obtained similar results: RR, 0.67 (95% CI, 0.52 to 0.86). In addition, Rothwell and colleagues83 pooled individual patient data from BMD, UK-TIA, TPT, JPAD, POPADAD, and AAA to provide additional information on CRC mortality risk by followup period (N=19,824). They did not observe a statistically significant effect on CRC mortality during the first 5 years after randomization (HR, 0.78 [95% CI, 0.39 to 1.56]), but did observe an effect during ≥5 years of in-trial followup (HR, 0.41 [95% CI, 0.17 to 1.00]).83 Limited data suggested that duration of use but not dose was related to the magnitude of risk reduction. Based on data from Rothwell and colleagues, Sutcliffe and colleagues168,169 computed the number of CRC deaths that could be averted by aspirin use as 34 to 36 per 100,000 person-years.

PHS did not report on CRC mortality. WHS reported only that there were a total of 65 deaths due to CRC during the trial period in both arms of the study combined and that there was “no difference” between the groups.112

#### CRC Mortality and Recency of Aspirin Use

##### Time Since First Use

Data on aspirin and CRC mortality were available according to followup period, defined as average time since randomization. As before, we divided followup periods into early onset risk (within 10 years of randomization), late onset risk (10 to 20 years after randomization), and long-term cumulative risk (from randomization to 20+ years). Data from BMD, UK-TIA, TPT, and SALT (N=14,033) suggested a reduced risk in long-term CRC mortality (pooled OR, 0.66 [95% CI, 0.51 to 0.85]; p-heterogeneity, 0.84) (Table 2, Figure 3).85 Using individual patient data, Rothwell and colleagues restricted analysis to persons in the BMD, UK-TIA, and TPT trials with ≥5 years scheduled intervention duration.83 The effect of aspirin on CRC mortality was apparent 10 to 20 years after randomization (HR, 0.51 [95% CI, 0.35 to 0.74]), but not before (HR, 0.79 [95% CI, 0.49 to 1.26]). The OR for the long-term cumulative risk (0 to 20 years) of CRC mortality was 0.60 (95% CI, 0.45 to 0.81) for ≥5 years scheduled intervention. Based on individual patient data from BMD, UK-TIA, TPT, JPAD, POPADAD, and AAA (N=19,824), Rothwell and colleagues did not observe an effect of aspirin on CRC mortality during the first 5 years after randomization (HR, 0.78 [95% CI, 0.39 to 1.56]), but did observe an effect during ≥5 years of in-trial followup (HR, 0.41 [95% CI, 0.17 to 1.00]).83 WHS reported no effect (data not shown) during the first 10 years of followup112 but did not report on late or long-term risk of CRC mortality.

The SALT study, which had the shortest average intended duration of use (median 2.7 years) among the trials we examined, reported a long-term OR of CRC death of 0.71 (95% CI, 0.27 to 1.86).85 Though not statistically significant, this finding suggests that latency may not be completely confounded by duration, i.e., there appears to be a long-term effect even with three years of use.

The CPSII Nutrition Cohort provided some evidence that even recent aspirin use may reduce the risk of CRC mortality. Compared to nonusers, current daily aspirin users for less than five years had a lower risk of death due to CRC in the analysis using updated (time-varying) exposure information (RR, 0.62 [95% CI, 0.42 to 0.93]), but not in the analysis using baseline exposure data (RR, 0.85 [95% CI, 0.63 to 1.15]).

##### Time Since Last Use

None of the studies reported on the association between risk of CRC mortality and time since last aspirin use.

#### CRC Mortality and Aspirin Dose and Frequency of Use

Rothwell and colleagues85 performed a study-level meta-analysis of CRC mortality by dose in BMD (500 mg/day), UK-TIA (300 and 1,200 mg/day), TPT (75 mg/day), and SALT (75 mg/day).85 They found no significant effect of higher doses (500 to 1,200 mg/day) on the long-term cumulative risk of CRC mortality (OR, 0.72 [95% CI, 0.50 to 1.03]; N=6,777). However, they reported a significant reduction in long-term cumulative CRC mortality risk for lower dose aspirin (75 to 300 mg/day), (OR, 0.60 [95% CI, 0.42 to 0.86]; N=8,073). The HR for colon cancer mortality was 0.61 (95% CI, 0.38 to 0.98) for 75 mg/day when data from SALT and TPT were pooled (N=6,445). In the one trial that randomized patients to two different aspirin doses (UK-TIA, 300 mg/day and 1200 mg/day), there was a suggestion of effect with both doses (300 mg/day: OR, 0.50 [95% CI, 0.21 to 1.17]; 1200 mg/day: OR, 0.68 [95% CI, 0.31 to 1.47]), but neither was statistically significant.85

All included RCTs randomized patients to daily aspirin use and could not, therefore, compare daily to alternate-day use. The CPSII cohort study reported a significant trend for reduced CRC mortality risk with increasing frequency of aspirin use in the past year;170 however, the most frequent category of use was ≥16 times per month for at least one year and could not provide information for comparing daily and alternate-day use.

#### CRC Mortality and Duration of Aspirin Use

Rothwell and colleagues85 observed a significant association between scheduled duration of aspirin use and mortality reduction (p=0.04; RR not reported) using individual patient data from BMD, UK-TIA, SALT, and TPT (n=14,033); however, the magnitude of the association was not reported for the overall population studied. Among persons randomized to 75 mg/day to 300 mg/day of aspirin, the risk reduction was slightly greater when persons with less than five years scheduled duration (37%) were excluded (RR, 0.48 [95% CI, 0.30 to 0.77]; 20-year absolute risk reduction [ARR], 1.76% [95% CI, 0.61to 2.91]) than when all subjects were analyzed (RR, 0.61 [95% CI, 0.43 to 0.87]; 20-year ARR, 1.36% [95% CI, 0.44 to 2.28]). These findings suggested a possible association between longer duration of aspirin use and greater risk reduction. In contrast, the CPSII Nutrition Cohort study presented similar RR estimates for current daily use less than five years and for currently daily use of five or more years: RR, 0.85 [95% CI, 0.63 to 1.15] and RR, 0.86 [95% CI, 0.61 to 1.22] respectively in the analysis of aspirin use at baseline; and RR, 0.62 [95%, CI 0.42-0.93] and RR, 0.64 [95% CI, 0.42 to 0.98] respectively in the analysis using updated aspirin information.

#### CRC Mortality: Effect Modification by Age, Sex, Race, and Comorbidities

None of the studies provided information on differences in the effect of aspirin use on CRC mortality according to age, sex, race, or comorbidities. The majority of participants in the CVD prevention studies were men (100% in BMD and TPT, 73% in UK-TIA, 65.8% in SALT, 56.5% in ETDRS, 54.6% in JPAD, and 44.1% in POPADAD) and many had cardiovascular risk factors making them eligible for the CVD prevention studies. The only additional information available from cohort studies identified in this search was from the CPSII cohort. Thun and colleagues reported that RRs for colon cancer mortality for aspirin use ≥16 times per month for at least one year compared to nonuse were similar among men (RR, 0.58 [95% CI, 0.36 to 0.93]) and women (RR, 0.61 [95% CI, 0.38 to 0.97]).157

### Detailed Findings: Aspirin and All-Cause Mortality in Patients With a Prior Adenoma

We identified three RCTs evaluating 81 to 325 mg aspirin per day in persons with a prior adenoma (Appendix D Table 2): APACC,141-143 ukCAP,144,145 and AFPP (n=2332).136 All required removal of all polyps at a baseline colonoscopy and all had protocols for scheduled followup colonoscopies at three to four years after randomization. All three RCTs reported the number of deaths from any cause during followup (Table 3, Figure 4). Two studies (ukCAP and AFPP) had more deaths in the aspirin group than the placebo group, but the reverse was observed in APACC. Because of the small number of studies and heterogeneity we did not pool results. Our search did not identify any cohort studies with additional evidence on the association between aspirin use and ACM among persons with a prior adenoma.

### Detailed Findings: Aspirin and Colorectal Cancer Mortality in Patients With a Prior Adenoma

We did not identify any RCTs or cohort studies reporting on aspirin use and CRC mortality among persons with a prior colorectal adenoma.

## KQ 4 Does Regular Aspirin Use Reduce the Incidence of Colorectal Cancer in Adults Without a History of Colorectal Cancer, Familial Adenomatous Polyposis, or Lynch Syndrome?

### Summary of Results

We identified six RCTs that reported on the association between risk of CRC incidence and aspirin use in the general population (N=75,980) (Table 4). Data from four trials (N=69,535) suggested that aspirin does not affect the risk of CRC within the first 10 years after initiation of use (Figure 5). Data from three RCTs (N= 47,464) suggested that daily or alternate daily aspirin at 100 mg to 1,200 mg decreased risk of CRC incidence by approximately 40 percent (summary RR, 0.60 [95% CI, 0.47 to 0.76]) after a latency of approximately 10 years (Figure 6). Based on data from five trials, the latent effect of aspirin on CRC incidence resulted in an approximately 20 to 24 percent reduction in long-term cumulative risk (Table 4). Data did not suggest a difference in effect by dose and suggestion of an effect for duration of use came from a limited body of evidence. Data on dosage, frequency, formulation, or duration were also limited due to latency of effect analyses requiring at least 10 years of followup. Additional data from seven prospective cohort studies in the general population addressed questions about variations in effect by timing, dose, and duration of aspirin use, and patient characteristics. Data on aspirin use and CRC incidence in people with a prior adenoma were sparse (three trials) and represented only short-term (less than 5 years) followup and did not provide sufficient information on the effect of aspirin use on CRC incidence.

Table 4 Effect of Aspirin on Colorectal Cancer Incidence in Randomized, Controlled Trials, by Followup Period

Study^§^ | Early Onset Risk (0 to 12 Years)^†^ | | Late Onset Risk (10 to 19 Years) | | Long-Term Cumulative Risk (0 to 20+ Years)^‡^
| Events/N (%) | Relative Risk Estimate (95% CI) | Events/N (%) | Relative Risk Estimate (95% CI) | Events/N (%) | Relative Risk Estimate (95% CI)
WHS113 | IG: 144/19,934 (0.7%) | HR, 0.96 (0.76 to 1.20) | IG: 58/19,934 (0.3%) | HR, 0.58 (0.42 to 0.80) | IG: 202/19,934 (1.0%) | HR, 0.80 (0.67 to 0.97)
WHS113 | CG: 150/19,942 (0.8%) | HR, 0.96 (0.76 to 1.20) | CG: 99/19,942 (0.5%)^*^ | HR, 0.58 (0.42 to 0.80) | CG: 249/19,942 (1.2%) | HR, 0.80 (0.67 to 0.97)
PHS135 | IG: 173/11,037 (1.6%)^*^ | RR, 1.03 (0.83 to 1.28) | NR | NR | NR | NR
PHS135 | CG: 168/11,034 (1.5%)^*^ | RR, 1.03 (0.83 to 1.28) | NR | NR | NR | NR
BMD111 | IG: 28/3,429 (0.8%)^*^ | HR, 0.82 (0.45 to 1.49) | IG: 50/3,429 (1.5%)^*^ | HR, 0.64 (0.42 to 0.97) | IG: 92/3,429 (2.7%)^*^ | HR, 0.70 (0.51 to 0.97)
BMD111 | CG: 17/1,710 (1.0%)^*^ | HR, 0.82 (0.45 to 1.49) | CG: 38/1,710 (2.2%)^*^ | HR, 0.64 (0.42 to 0.97) | CG: 64/1,710 (3.7%)^*^ | HR, 0.70 (0.51 to 0.97)
UK-TIA111 | IG: 18/1,632 (1.1%)^*^ | HR, 1.14 (0.49 to 2.61) | IG: 15/1,632 (0.9%)^*^ | HR, 0.51 (0.25 to 1.00) | IG: 37/1,632 (2.3%)^*^ | HR, 0.82 (0.49 to 1.38)
UK-TIA111 | CG: 8/817 (1.0%)^*^ | HR, 1.14 (0.49 to 2.61) | CG: 15/817 (1.8%)^*^ | HR, 0.51 (0.25 to 1.00) | CG: 23/817 (2.8%)^*^ | HR, 0.82 (0.49 to 1.38)
BMD, UK-TIA, TPT, SALT85 | NR | NR | NR | NR | Total=397/14,033 (2.8%)^*^ | HR, 0.76 (0.63 to 0.94)
BMD, UK-TIA, TPT, SALT85 | NR | NR | NR | NR | Total=397/14,033 (2.8%)^*^ | HR, 0.76 (0.63 to 0.94)

* Calculated

† 0 to 9 years in BMD and UK-TIA, 0 to 10 years in WHS, 0 to 12 years in PHS

‡ Median follow-up in WHS was 17.5 years

§ Median scheduled treatment duration was: 10.1 years (WHS), 6.0 years (BMD), 4.4 years (UK-TIA), 6.9 years (TPT), and 2.7 years (SALT). The mean scheduled treatment duration was 5.0 years in PHS.

Abbreviations: BMD = British Medical Doctors trial; CG = control group; CI = confidence interval; HR = hazard ratio; IG = intervention group; NR = not reported; PHS = Physicians' Health Study; RR = relative risk; SALT = Swedish Aspirin Low-dose Trial; TPT = Thrombosis Prevention Trial; UK-TIA = UK Transient Ischaemic Attack trial; WHS = Women's Health Study

Figure 5 Effect of Aspirin on Early Risk (0 to 12 Years) of Colorectal Cancer Incidence

Note: Differences from point estimates or 95% confidence intervals reported in studies are due to use of different statistical programs, and are minor and of no clinical or statistical significance

Abbreviations: BMD = British Medical Doctors trial; CG = control group; CI = confidence interval; IG = intervention group; mg = milligram; PHS = Physicians' Health Study; RR = relative risk; TIA = transient ischemic attack; UK-TIA = United Kingdom Transient Ischaemic Attack; WHS = Women's Health Study; yrs = years

This figure is a forest plot of the relative risk of early colorectal cancer incidence

Figure 6 Effect of Aspirin on Late Risk (10 to 19 Years) of Colorectal Cancer Incidence

Note: Differences from point estimates or 95% confidence intervals reported in studies are due to use of different statistical programs, and are minor and of no clinical or statistical significance

Abbreviations: BMD = British Medical Doctors trial; CG = control group; CI = confidence interval; IG = intervention group; mg = milligram; RR = relative risk; TIA = transient ischemic attack; UK-TIA = United Kingdom Transient Ischaemic Attack; WHS = Women's Health Study; yrs = years

This figure is a forest plot of the relative risk of late colorectal cancer incidence

### Detailed Findings: Aspirin and Colorectal Cancer Incidence in the General Population

Six RCTs (five good quality, one fair quality) representing 75,980 individuals provided data on the effect of regular aspirin use on invasive CRC incidence in the general population (Table 4). Pooled results from individual patient data from four of these trials (BMD, UK-TIA, TPT, and SALT) were reported in publications by Flossman and colleagues111 (BMD and UK-TIA) and Rothwell and colleagues (all four).85 Study-level estimates were also available for BMD and UK-TIA. Aspirin dosages in the trials included in the Flossman and colleagues and Rothwell and colleagues analyses ranged from 75 mg/day to 1,200 mg/day taken daily. The median scheduled duration of aspirin use across trials was 6.0 years (range 1.0 to 8.5 years) and some participants were followed for more than 20 years. Most participants were men (92%), and the average age at study entry was 60.4 years.85 In addition, WHS112-116 and PHS117-122 both reported on the association between CRC incidence and alternate-day aspirin use. WHS randomized women (mean age 54.6 years) to 100 mg of aspirin every other day vs. placebo for approximately 10 years with followup for a median of 17.5 years. PHS randomized men (mean age 53.2 years) to 325 mg of aspirin every other day vs. placebo for approximately 5 years with a mean followup of 12 years. WHS and Rothwell's pooled analysis of BMD, UK-TIA, TPT, and SALT reported on risk of proximal and distal colon cancers separately (Appendix D Table 4). Both suggested that aspirin decreased the risk of proximal but not distal colon cancer.

We also identified six fair-quality and one good-quality prospective cohort studies to address questions about variations in effect by timing, dose, and duration of aspirin use and patient characteristics (Appendix D Table 3). All included cohort studies had at least one exposure group that met the threshold for frequency of aspirin use (daily or alternate day). Two studies were conducted among health care professionals in the United States (NHS and HPFS). Two were regional or national cohort studies in the U.S. general population (VITAL and CPS II Nutrition Cohort). The WHI observational cohort consisted of women who were ineligible or unwilling to participate in the clinical trial. Two additional studies were population-based international cohorts (Denmark160 and Sweden153). Most of the cohorts were established in the 1980s and 1990s and had a mean or median followup time of approximately 10 years; several cohort studies asked about past aspirin use (before baseline) and could therefore examine longer durations of use. Average age at cohort entry was generally 45 to 65 years old.

#### CRC Risk and Recency of Aspirin Use

##### Time Since First Use

Based on four trials (WHS, PHS, BMD, and UK-TIA; combined N=69,535), no effect of aspirin was seen on early risk of CRC (within approximately 10 years of treatment initiation) (summary RR, 0.99 [95% CI, 0.85 to 1.15]) (Table 4, Figure 5). Three RCTs (BMD, UK-TIA, and WHS, combined N= 47,464) suggested that aspirin reduced the risk of CRC incidence by about 40 percent starting approximately 10 years after initiation of use (Table 4, Figure 6), with reported HRs ranging from 0.51 to 0.64 across the three studies (summary RR, 0.60 [95% CI, 0.47 to 0.76]). Point estimates were similar in these three studies, even though scheduled duration of use was longer in WHS, suggesting that the apparent latent effect is not completely due to long duration of use. Risk of CRC overall was reduced in trials with long-term followup (17 to 20+ years). The estimate in WHS (HR, 0.80 [95% CI, 0.67 to 0.97]) was similar to Rothwell and colleagues' estimate based on individual patient data from BMD, UK-TIA, TPT, and SALT (HR, 0.76 [95% CI, 0.63 to 0.94]) (Table 4, Figure 7). We did not pool results from WHS and Rothwell since there were only two point estimates.

Figure 7 Effect of Aspirin on Long-Term Risk (0 to ≥20 Years) of Colorectal Cancer Incidence

Note: Relative risk estimates and confidence intervals from Rothwell and colleagues85 are presented in this figure because the raw number of events was not available. Trials included in the pooled result from Rothwell and colleagues were: British Medical Doctors trial, UK Transient Ischaemic Attack study, Swedish Aspirin Low-dose Trial, and Thrombosis Prevention Trial

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; mg = milligram; RCT = randomized controlled trial; RR = relative risk; WHS = Women's Health Study; yrs = years

This figure is a forest plot of the relative risk of long-term colorectal cancer incidence

Flossman and colleagues analyzed CRC risk by followup interval (based on the BMD and UK-TIA trials; combined N=7,588). Their results suggested that the effect of aspirin on CRC waned after 14 years since first use. Risk of CRC incidence was reduced after 10 to 14 years of followup (HR, 0.51 [95% CI, 0.29 to 0.90]), but not after 15 to 19 years (HR, 0.70 [95% CI, 0.43 to 1.14) or ≥20 years (HR, 0.90 [95% CI, 0.42 to 1.95]). However, whether these results were influenced by duration of aspirin use or time since last use is unclear. In the two trials included in the Flossman report, 15 years after first use would have been approximately 10 years on average since last on-trial use.

Data from cohort studies provided little additional information on the timing of the preventive effect of aspirin on CRC incidence. NHS was the only cohort study to examine different followup periods independent of use duration. Similar to the RCT results, Chan and colleagues observed a trend toward reduced CRC risk with increasing number of tablets per week for aspirin use 11 to 20 years in the past but not for more recent use (i.e., in the past 10 years) in their multivariate adjusted analyses.146

##### Time Since Last Use

None of the trials provided data on CRC risk relative to time since last regular aspirin use. Two cohort studies presented analyses on time since last use;152,160 however, neither study could estimate associations between time since last aspirin use and CRC risk for daily or alternate day users specifically.

##### Aspirin Dose and Frequency of Use

RCT evidence of aspirin use ≥75 mg daily or every other day did not suggest a difference in effect by aspirin dose. Rothwell and colleagues85 conducted preplanned analyses of aspirin dose and observed similar effects on CRC incidence whether restricting to patients randomized to 75 or 300 mg/day (N=8,073) (HR, 0.75 [95% CI, 0.56 to 0.97]) or overall (HR, 0.76 [95% CI, 0.63 to 0.94]) including people randomized to 500 mg/day and 1,200 mg/day. In the two studies (TPT and SALT) that randomized patients to 75 mg/day of aspirin (N=6,445) the point estimate for the HR for colon cancer was similar but not statistically significant (HR, 0.76 [95% CI, 0.52 to 1.10]).85 Additionally, WHS reported a long-term protective effect with very low dose aspirin (100 mg on alternate days) (HR, 0.80 [95% CI, 0.67 to 0.97]). These results suggested low-dose aspirin (≤325 mg daily) can reduce the long-term risk of CRC incidence and that higher doses may not be necessary to achieve an effect.

WHS and PHS studied alternate-day use while Rothwell and colleagues85 examined daily use. None of the studies directly compared daily vs. alternate-day use. RR estimates for the long-term cumulative effect of aspirin on CRC incidence were similar in WHS (alternate-day use) and Rothwell and colleagues (daily use). PHS did not provide estimates of long-term effects.

Three cohort studies provided RR estimates according to reported number of pills per week, which we used as a surrogate for frequency of use. NHS146 and HPFS152 both reported on the risk of CRC among persons using different numbers of 325 mg aspirin tablets per week (0.5 to 1.5, 2 to 5, 6 to 14, more than14 tablets) (Appendix D Table 5). These categories do not map clearly into daily vs. alternate-day use. While it is reasonable to assume that individuals taking 6 to 14 tablets/week and more than 14 tablets per week were daily users, not everyone in the 2 to 5 tablet/week group would be an alternate-day user. Both studies suggested a trend toward reduced CRC risk with increasing tablets/week; however, we could not directly compare daily to alternate-day users. Analyses were not adjusted for duration or time since first use. Data from a study of Swedish cohorts also presented results for groups that could approximate daily users (>6 tablets/week) vs. alternate day users (2 to 6 tablets per week).153 The same limitations that applied to NHS and HPFS apply to these data. VITAL also reported on low use (<4 days/week or <4 years) versus high use (≥4 days/week and ≥4 years), but we did not include these data since frequency and duration of use could not be separated.161

Three cohort studies presented CRC risk according to daily aspirin dose. The observational component of the WHI study found no association with <325 mg/day, ≥325 mg/day, or quartiles of daily dose (data not shown).164 In a Danish study of prescription aspirin use, Friis and colleagues did not observe a significant reduction in CRC risk with either 75 to 100 mg or 150 mg tablets (data not shown).160 These findings were among prescription aspirin users, whom we assumed were daily or alternate day users. VITAL also did not observe a greater risk reduction in regular-strength vs. low-dose aspirin users.161 In men, high use (≥4 days per week and ≥4 years) of regular-strength and low-dose aspirin was associated with reduced CRC risk (HR, 0.55 [95% CI, 0.33 to 0.91] and HR, 0.55 [95% CI, 0.33 to 0.92] respectively). In women, a reduced risk of CRC was limited to high use of low-dose aspirin (HR, 0.55 [95% CI, 0.31 to 0.97]) and low use (< 4 days per week or <4 years) of regular-strength aspirin (HR, 0.53 [95% CI, 0.29 to 0.96]). Interpretation of these results is limited by the fact that they are not stratified by time since first use or duration of aspirin use.

In summary, although findings across RCTs and cohort studies are not entirely consistent, evidence suggests a reduced risk of CRC incidence with daily or alternate-daily use of at least 75 mg of aspirin. Overall, data did not suggest differences in effect by dose. Data directly comparing daily to alternate-day use were sparse.

#### CRC Risk and Duration of Aspirin Use

The reports by Rothwell and colleagues85 and Flossman and colleagues111 were the only analyses of RCTs to provide evidence on the effect of duration of aspirin use. Duration of aspirin use was inferred, generally reflecting intended rather than actual duration. We primarily report the results from Rothwell and colleagues85 rather than Flossman and colleagues111 because the study populations overlapped but Rothwell and colleagues85 included more studies. Their primary analysis included four RCTs with a median scheduled aspirin duration use of 6.0 years (range 1.0 to 8.5 years). In secondary analyses, they restricted to persons with scheduled durations ≥5 years (N=10,533). The HR in the secondary analysis (HR, 0.68 [95% CI, 0.54 to 0.87]) was fairly similar to the analysis for all scheduled durations (HR, 0.76 [95% CI, 0.63 to 0.94]). However, in one of the included RCTs, scheduled duration varied from one to seven years and treatment and scheduled duration interacted, with a greater effect for longer duration of use (p-interaction=0.009 with duration as a continuous variable; p-interaction=0.004 for duration dichotomized at five years.)111

Several cohort studies presented risk according to aspirin duration. NHS,146 HPFS,152 and Larsson and colleagues153 all observed decreased risk with increased duration of use; however, they did not restrict analyses to daily or alternate-day users. Thus, we do not present results from these three studies, as they may have included persons who used aspirin infrequently (e.g., two times per week). In contrast, WHI focused on daily use. Allison and colleagues reported on duration categories in 1-year increments from 0.1 to ≥5 years (0 years, 0.1 to 0.9 years, 1 to 1.9 years, 2 to 2.9 years, 3 to 3.9 years, 4 to 4.9 years, and ≥5 years), and in 5-year increments from one to >20 years (0 years, 1 to 5 years, 5.1 to 10 years, 10.1 to ≤20 years, and >20 years).164 They did not observe significant trends, either with small increments between zero to five years or larger increments greater than five years. The CPSII Nutrition Cohort study reported an association with current daily use ≥5 years (RR, 0.68 [95% CI, 0.52 to 0.90]) but not with current daily use <5 years (RR, 0.85 [95% CI, 0.72 to 1.00]).156 In the Friis and colleagues report, CRC incidence after ≥5 years of consistent use was reduced (RR, 0.68 [95% CI, 0.34 to 1.34]); however, no reduction in risk was seen for any aspirin users compared to nonusers (RR, 0.93 [95% CI, 0.77 to 1.12]).160 Finally, in the VITAL study, most subgroups who used aspirin for <4 years or <4 days per week did not have a reduced risk compared to nonusers, although risk was reduced for those who used aspirin for ≥4 years and ≥4 days per week (except for regular-strength aspirin in women). However, as noted above, frequency of use and duration of use could not be disentangled.161

In summary, limited data suggest that CRC risk associated with aspirin use is related to duration of daily or alternate-day use. Further, between-study differences complicate comparisons of intended duration of use. Finally, the latency of CRC risk reduction with aspirin use complicates analyses of duration and further limits the applicability of data on duration of use.

#### CRC Incidence: Effect Modification by Age, Sex, Race, and Comorbidities

##### Age

None of the studies provided information on differences in the effect of aspirin use on CRC incidence according to age.

##### Sex

Indirect data from RCTs did not suggest that sex modifies the effect of aspirin on CRC incidence. WHS was conducted in women, while PHS was conducted in men and 92 percent of persons in the four trials reported by Rothwell and colleagues were men.85 Consequently, none of the RCTs provides a direct comparison of risk estimates in men versus women. The point estimates for aspirin effects were similar in WHS (women), PHS (men), and Rothwell and colleagues (primarily men). While these comparisons may be confounded by other between-study differences, the studies tended to confirm each other.

Three cohort studies provided limited additional information on the association between aspirin use and CRC risk by sex; however, none of the studies reported statistically significant differences in the observed associations. The VITAL study observed some differences in men compared to women. High use (≥4 days/week and ≥4 years use) of regular-strength aspirin was associated with a reduced risk of CRC in men (HR, 0.55 [95% CI, 0.33 to 0.91]) but not in women (HR, 0.84 [95% CI, 0.49 to 1.07]); however, the interaction was not significant (p=0.32).161 In the CPSII Nutrition Cohort, the association between CRC risk and current daily aspirin use of ≥5 years was significant in women (RR, 0.45 [95% CI, 0.24 to 0.86]) but not in men (RR, 0.76 [95% CI, 0.55 to 1.04]); however the difference was not statistically significant (p-interaction not reported).156 Findings of difference could also be due to multiple comparisons and chance.

##### Race

None of the RCTs or cohort studies stratified results by race. Rothwell and colleagues85 and PHS135 did not report the racial distribution of participants; however, based on the countries of origin, the majority of participants were likely white. In WHS, 94.8 percent of participants were white.115 Among the cohort studies, many did not report race;153,160,171 in those that did, nearly all participants (>90%) were white (NHS, HPFS, VITAL, and CPSII Nutrition Cohort),146,152,156,161 except in WHI (83.4% white).164

##### Comorbidities

None of the RCTs or cohort studies stratified results by comorbidities. Many comorbidities of interest were not reported. WHS and PHS excluded persons with CVD and some other chronic diseases, while Rothwell and colleagues85 included data from both primary and secondary CVD prevention studies.

##### Baseline Cancer Risk

Studies of patients with a prior adenoma are described below. None of the included RCTs stratified by baseline CRC risk. One cohort study (NHS) examined the association between aspirin use and CRC incidence according to first-degree family history of CRC. Point estimates were very similar: RR, 0.76 (95% CI, 0.57 to 1.02) for women with a family history and RR, 0.78 (95% CI, 0.67 to 0.90) for women without a family history (p-interaction not reported).146

### Detailed Findings: Aspirin and Colorectal Cancer Incidence in Patients With a Prior Adenoma

In an IPD meta-analysis, Cole and colleagues reported pooled cumulative CRC incidence percentages across ukCAP, AFPP, and APACC (N=2332).123 They found that CRC incidence in aspirin groups across the three trials was 0.54 percent compared to 0.62 percent in the control groups (p=0.81) during the 3- to 4-year study followup periods. No additional information on incidence was presented.

More detailed results were available from the ukCAP144,145 and AFPP136 trials (Table 5, Figure 8). Both ukCAP and AFPP randomized patients to daily aspirin use with doses ranging from 81 mg to 325 mg for intended durations of 3 to 4 years. Only persons who received the followup colonoscopy were included in the ukCAP analysis (90.8%) but all randomized participants in AFPP were included (N=1,121). In the ukCAP study, CRC incidence appeared lower in the aspirin group than the placebo group (0.7 vs. 1.7%; p-value not reported) (Table 5). In contrast, in AFPP, more persons in the aspirin groups developed CRC than in the control group (0.5% in the 81 mg/day aspirin group and 0.8% in the 325 mg/day aspirin group vs. 0.3% in the control group); however, differences across the three groups were not statistically significant (p=0.71). Because of the small number of studies and inconsistent findings we did not pool results.

Table 5 Effect of Aspirin on 3- to 4-Year Incidence of Colorectal Cancer in Randomized, Controlled Trials of Persons With a Prior Adenoma

Study | Treatment Group | Colorectal Cancer Incidence Events/N (%) | Relative Risk Estimate (95% CI) p-value
ukCAP144 | 300 mg/day | 3/434 (0.7%)^*^ | NR
ukCAP144 | Placebo | 7/419 (1.7%)^*^ | NR
AFPP136 | 81 mg/day | 2/377 (0.5%)^*^ | NR p-value: 0.71 for difference among three groups
AFPP136 | 325 mg/day | 3/372 (0.8%)^*^ | NR p-value: 0.71 for difference among three groups
AFPP136 | Placebo | 1/372 (0.3%)^*^ | NR p-value: 0.71 for difference among three groups

* Calculated

Abbreviations: AFPP = Aspirin/Folate Polyp Prevention Study; CI = confidence interval; mg = milligram; NR = not reported; ukCAP = United Kingdom Colorectal Adenoma Prevention trial

Figure 8 Effect of Aspirin on 3- to 4-Year Risk of Colorectal Cancer Incidence in Persons With a Prior Adenoma

Abbreviations: AFPP = Aspirin/Folate Polyp Prevention study; CG = control group; CI = confidence interval; IG = intervention group; mg = milligram; RR = relative risk; ukCAP = United Kingdom Colorectal Adenoma Prevention trial; yrs = years

This figure is a forest plot of the relative risk colorectal cancer incidence among persons with a prior adenoma

Our search did not identify eligible cohort studies that examined the risk of CRC in relation to aspirin use among persons with a prior adenoma.

## KQ 5 Does Regular Aspirin Use Reduce the Incidence of Colorectal Adenoma in Adults Without a History of Colorectal Cancer, Familial Adenomatous Polyposis, or Lynch Syndrome?

### Summary of Results

For this KQ, we focused on colorectal adenomas specifically, not polyps in general. We did not find consistent evidence demonstrating reduced risk of colorectal adenoma incidence with aspirin use. Evidence for persons selected without consideration of adenoma history was limited to a single cohort study that found a statistically significant reduced risk of at least one distal adenoma (32 to 43%) with use of aspirin that was at least every other day, daily, or multiple times per day. Three RCTs (N=2,338 randomized) were conducted in persons with a prior adenoma. Data from an IPD meta-analysis of these studies by Cole and colleagues suggested a reduced risk of adenoma over a 3- to 4-year period with 81 or 160 mg/day of aspirin (RR, 0.83 [95% CI, 0.71 to 0.96]);123 however, the effect of 300 or 325 mg/day over a 3- to 4-year period was unclear.

### Detailed Results: Aspirin and Adenoma in the General Population

For KQ 5, we did not identify any RCTs of aspirin in the general population. WHS and PHS reported on polyp incidence in general (assessed via self-report) and were therefore excluded because they did not report specifically on adenoma incidence. Two cohort studies (NHS and HPFS) reported on the association between aspirin use and adenoma incidence in the general population, but HPFS was excluded for this KQ because the exposed category (regular aspirin users) was not restricted to daily or alternate-day users. In contrast, the NHS reported on the risk of ≥1 distal adenoma (<60 cm from anus) by number of 325 mg tablets per week.147 As before, we assumed that persons who used 6 to 14 or more than 14 tablets per week were using aspirin at least every other day. Adenomas were ascertained by self-report followed by blinded medical record review by study physicians to determine histology. Chan and colleagues reported a reduced risk of adenoma incidence associated with 6 to 14 tablets/week (RR, 0.68 [95% CI, 0.55 to 0.84]) and more than14 tablets/week (RR, 0.57 [95% CI, 0.42 to 0.77]) of aspirin. Duration of followup was not specified, but RRs were adjusted for duration of aspirin use. In stratified analyses, the risk reduction associated with tablets per week appeared stronger for women reporting short-term (≤5 years) aspirin use compared to women reporting long-term aspirin use (>5 years): the RR for more than 14 tablets/week was 0.36 (95% CI, 0.19 to 0.71) among short-term users and 0.52 (95% CI, 0.38 to 0.72) for long-term users. RRs were attenuated when limited to nurses reporting regular use on three surveys compared to nonregular users on three consecutive surveys (6 to 14 tablets/week: RR, 0.80 [95% CI, 0.59 to 1.10]; more than 14 tablets/week: RR, 0.59 [95% CI, 0.38 to 0.92]).

### Detailed Results: Aspirin and Adenoma Incidence in Patients With a Prior Adenoma

Three RCTs (two good quality, one fair quality) assessed the effect of aspirin on colorectal adenoma incidence among persons with a prior adenoma: APACC, ukCAP, and AFPP. In addition to the trial reports, we also examined an IPD meta-analysis by Cole and colleagues in 2009.^123^ We did not identify any cohort studies addressing KQ 5 for persons with a prior adenoma.

All three RCTs required that participants recently had an adenoma removed with none remaining. The average age of participants was 57 to 58 years in all three studies; women constituted 30 to 43.1 percent of the study populations. All trials reported on adenoma incidence and advanced lesions at 3 to 4 years (Table 6). In addition, APACC reported on adenomas at the 1-year colonoscopy. For APACC (Table 6), we present the results from the 4-year colonoscopy, which was the primary endpoint. The 1-year and last colonoscopy (which was the 1-year or the 4-year colonoscopy) results are in Appendix D Table 6.

Table 6 Effect of Aspirin on 3- to 4-Year Incidence of Colorectal Adenoma in Randomized, Controlled Trials of Persons With a Prior Adenoma

Study | Treatment Group | Adenoma Incidence | | Advanced Lesion Incidence^*^ | | Adenoma Number
Study | Treatment Group | Events/N (%) | Relative Risk Estimate (95% CI) | Events/N (%) | Relative Risk Estimate (95% CI) | Mean Number (SD) | Relative Risk Estimate (95% CI)
APACC142,† | 160 mg/day | 15/55 (27%) | NR, p-value reported as not significant | 6/55 (11%) | NR, p-value reported as not significant | 0.4 (0.7) | NR Difference in proportions (aspirin 160 mg vs. placebo: p=0.025)
APACC142,† | 300 mg/day | 27/47 (57%) | NR, p-value reported as not significant | 4/47 (8.5%) | NR, p-value reported as not significant | 1 (1.1) | NR Difference in proportions (aspirin 160 mg vs. placebo: p=0.025)
APACC142,† | Placebo | 33/83 (40%) | NR, p-value reported as not significant | 7/83 (8%) | NR, p-value reported as not significant | 0.8 (1.3) | NR Difference in proportions (aspirin 160 mg vs. placebo: p=0.025)
ukCAP144,‡ | 300 mg/day | 99/434 (22.8%) | 0.79 (0.63 to 0.99) | 41/434 (9.4%) | 0.63 (0.43 to 0.91) | 0.31 (0.70) | NR, p=0.015
ukCAP144,‡ | Placebo | 121/419 (28.9%) | 0.79 (0.63 to 0.99) | 63/419 (15.0%) | 0.63 (0.43 to 0.91) | 0.47 (0.92) | NR, p=0.015
AFPP136,§ | 81 mg/day | 140/366 (38.3%) | 0.83 (0.70 to 0.98) | 28/366 (7.7%) | 0.58 (0.37 to 0.90) | NR | NR
AFPP136,§ | 325 mg/day | 160/355 (45.1%) | 0.95 (0.80 to 1.12) | 38/355 (10.7%) | 0.83 (0.55 to 1.23) | NR | NR
AFPP136,§ | Placebo | 171/363 (47.1%) | 0.95 (0.80 to 1.12) | 47/363 (12.9%) | 0.83 (0.55 to 1.23) | NR | NR

* Definition of advanced lesion: APACC, diameter ≥10 mm, ≥25% villous, or high grade dysplasia; ukCAP, adenomas ≥1 cm, villous or tubulovillous adenomas, adenomas with severe dysplasia, or colorectal cancer; AFPP, villous or tubulovillous adenoma, adenoma ≥1 cm, severe dysplasia, or invasive cancer

† Among persons who had undergone a colonoscopy with adequate bowel preparation and visualized cecum, had ≥3 adenomas or ≥1 adenoma 6 millimeters or larger, and removal of all polyps in the three months before study entry

‡ Among persons with an adenoma ≥0.5 cm that was removed in the 6 months before recruitment (or earlier if they also had ≥1 adenoma removed in the 6 months before randomization)

§ Among persons with a prior adenoma (either ≥1 adenomas in the 3 months before recruitment, ≥1 adenomas removed in the 16 months before recruitment and a lifetime history of ≥2 adenomas, or an adenoma ≥1 cm removed in the 16 months before recruitment) and with confirmation of no remaining polyps in the three months before recruitment

Abbreviations: AFPP = Aspirin/Folate Polyp Prevention Study; APACC = Association pour la Prevention par l'Aspirine du Cancer Colorectal; CI = confidence interval; mg = milligram; NR = not reported; SD = standard deviation; ukCAP = United Kingdom Colorectal Adenoma Prevention trial

In APACC (fair quality), the incidence of adenoma was lower in the 160 mg/day aspirin arm (27%) compared to placebo (40%) and the incidence in the 300 mg/day arm (57%) was higher than the placebo group (Table 6, Figure 9), but the differences were not statistically significant. In AFPP, the 81 mg/day aspirin group but not the 325 mg/day aspirin group had a statistically significantly reduced adenoma risk compared to placebo (38.3%, 45.1%, and 47.1%, respectively) although the p-value comparing doses was not significant. In ukCAP, 300 mg/day aspirin appeared protective (RR, 0.79 [95% CI, 0.63 to 0.99]). Results for risk of advanced lesion and mean adenoma number generally paralleled those for any adenoma.

Figure 9 Effect of Aspirin on 3- to 4-Year Risk of Colorectal Adenoma Incidence in Persons With a Prior Adenoma

Note: Differences from point estimates or 95% confidence intervals reported in studies are due to use of different statistical programs, and are minor and of no clinical or statistical significance

Abbreviations: AFPP = Aspirin/Folate Polyp Prevention study; APACC = Association pour la Prevention par l'Aspirine du Cancer Colorectal study; CG = control group; CI = confidence interval; IG = intervention group; mg = milligram; RR = relative risk; ukCAP = United Kingdom Colorectal Adenoma Prevention trial; yrs = years

This figure is a forest plot of the relative risk colorectal adenoma incidence among persons with a prior adenoma

Because of the small number of studies and inconsistent results, we did not pool estimates; however, Cole and colleagues reported a summary estimate based on individual patient data for 81 mg/day or 160 mg/day doses of aspirin (AFPP and APACC, N=1393) of RR, 0.83 (95% CI, 0.71 to 0.96) for any adenoma and RR, 0.83 (95% CI, 0.44 to 1.58) for advanced lesions.123 Of note, Cole and colleagues used the results from the last APACC colonoscopy (1 or 4 years) rather than the 4-year results. Because the estimates included results from the study of persons with a history of CRC (excluded from our review), we do not report their pooled results for any dose of aspirin or aspirin at 300 or 325 mg/day. For similar reasons, we do not include their results from subgroup analyses.

#### Timing of Effect

In 2003, the APACC study reported a benefit for aspirin on adenoma prevention after one year (Appendix D Table 6). In the aspirin groups combined, 30.2 percent had an adenoma recurrence, compared to 41.1 percent in the placebo group. In 2009, Cole and colleagues further explored the timing of benefit across all three studies, APACC, ukCAP, and AFPP.123 We could not use the pooled results from Cole and colleagues as they included results from a trial among people treated for CRC. However, they reported RRs by study by interval after randomization (Appendix D Table 7). Based on ukCAP and APACC data, risk of colorectal adenoma recurrence appeared to be approximately 34 to 38 percent reduced in the first year of treatment (doses analyzed at one year were 160 mg/day or 300 mg/day). No clear indication of reduced risk was observed during the other followup intervals. Limitation of these interval analyses were that not all colonoscopies occurred at the time prescribed by the study protocols and numbers were small.

## KQ 7 What Are the Harms of Regular Aspirin Use for the Prevention of Colorectal Cancer (i.e., at the Dosage and Duration Required to Achieve a Preventive Health Effect) in Adults Without a History of Colorectal Cancer, Familial Adenomatous Polyposis, or Lynch Syndrome?

### Summary of Results

A comprehensive review of the harms of aspirin use is included in a concurrent systematic evidence review prepared for the USPSTF. The results in this section are limited to studies of aspirin that reported on colorectal adenoma incidence, CRC incidence, or mortality (CRC-specific or all-cause). All 14 of the RCTs that reported on KQs 1/3, 4, or 5 reported on at least one harm of aspirin use; however, only one included cohort study reported harms (NHS). For KQ 7, we did not stratify results by adenoma history. Most studies reported on harms during scheduled treatment duration, the median of which was between 2.6 and 10.1 years; however, WHS included events during post-trial followup (median 17.5 years from randomization). Twelve RCTs (all except ETDRS and APACC) reported on gastrointestinal bleeding. Compared to controls, patients assigned to aspirin had higher risks of gastrointestinal bleeding (Table 7, Figure 10) and serious gastrointestinal bleeding (summary OR, 1.94 [95% CI, 1.44 to 2.62]) (Table 7, Figure 11). Results were not consistent for fatal gastrointestinal bleeding (Table 7, Figure 12). Intracranial bleeding data were available from 12 RCTs. Patients randomized to aspirin had a higher risk of intracranial bleeding than control patients (summary OR, 1.53 [95% CI, 1.21 to 1.93]) (Table 8, Figure 13). Aspirin users had a higher risk of hemorrhagic stroke than controls (summary OR, 1.47 [95% CI, 1.16 to 1.88]) (Table 9, Figure 14). We did not identify publications reporting on age-related macular degeneration as part of our systematic search strategy. However, two studies (WHS172 and PHS173) reported on age-related macular degeneration in other publications; those results are described in the concurrent evidence review for the USPSTF on total cancer, ACM, and harms. For all harms outcomes, very limited data were available on effect modification by age, sex, race, comorbidities, or concomitant medication use and are analyzed in more detail with additional studies in the companion evidence review.

Table 7 Effect of Aspirin on Risk of Gastrointestinal Bleeding in Randomized, Controlled Trials and Cohort Studies

Study Outcome Definition | Treatment Group | Gastrointestinal Bleeding | | Fatal Gastrointestinal Bleed
Study Outcome Definition | Treatment Group | Events/N (%) | Relative Risk Estimate (95% CI) | Events/N (%) | Relative Risk Estimate (95% CI)
RCTs
WHS113,† Nonspecific GI bleeding | 100 mg qod | 1,645/19,934 (8.3%) | HR, 1.14 (1.06 to 1.22) | 3/19,934 (0.02%)^*^ | NR
WHS113,† Nonspecific GI bleeding | Placebo | 1,452/19,942 (7.3%) | HR, 1.14 (1.06 to 1.22) | 3/19,942 (0.02%)^*^ | NR
PHS118 Nonspecific GI bleeding (major= death or required transfusion) | 325 mg qod | 440/11,037 (4.0%) Major=49/11,037 (0.4%)^*^ | NR, p=0.55 for nonspecific GI bleeding RR, 1.71 (1.09 to 2.69) for major GI bleeding, excluding one death | 1/11,037(<0.01%)^*^ | NR
PHS118 Nonspecific GI bleeding (major= death or required transfusion) | Placebo | 422/11,034 (3.8%) Major=28/11,034 (0.3%)^*^ | NR, p=0.55 for nonspecific GI bleeding RR, 1.71 (1.09 to 2.69) for major GI bleeding, excluding one death | 0/11,034 (0.0%)^*^ | NR
BMD124 GI hemorrhage, peptic ulcer hemorrhage or perforation | 500 mg/day | NR | NR | 3^¶^/3,429 (0.09%)^*^ | NR
BMD124 GI hemorrhage, peptic ulcer hemorrhage or perforation | Control (no placebo) | NR | NR | 3^¶^ /1,710 (0.18%)^*^ | NR
UK-TIA126 GI hemorrhage (serious=required hospitalization or fatal) | 1,200 mg/day | 39/815 (5%) Serious=19/815 (2.3%)^*^ | 1,200 mg vs. 300 mg: OR, 1.62 (0.94 to 2.79) 300 mg vs. placebo: OR, 2.57 (1.20 to 5.53) | 2/815 (1%) | NR
UK-TIA126 GI hemorrhage (serious=required hospitalization or fatal) | 300 mg/day | 25/806 (3%) Serious=10/806 (1.2%)^*^ | 1,200 mg vs. 300 mg: OR, 1.62 (0.94 to 2.79) 300 mg vs. placebo: OR, 2.57 (1.20 to 5.53) | 0/806 (0%) | NR
UK-TIA126 GI hemorrhage (serious=required hospitalization or fatal) | Placebo | 9/814 (1%) Serious=2/814 (0.2%)^*^ | 1,200 mg vs. 300 mg: OR, 1.62 (0.94 to 2.79) 300 mg vs. placebo: OR, 2.57 (1.20 to 5.53) | 0/814 (0%) | NR
SALT127 GI bleeding (severe=required hospitalization or discontinued medication) | 75 mg/day | 11/676 (1.6%) Severe=9/676 (1.3%) | NR | NR | NR
SALT127 GI bleeding (severe=required hospitalization or discontinued medication) | Placebo | 4/684 (0.6%) Severe=4/684 (0.6%) | NR | NR | NR
TPT108,§,‡ Major GI bleeding | 75 mg/day | Upper GI: IG: 5/1,268 (0.4%)^*^ CG: 1/1,272 (<0.1%)^*^ Lower GI: IG: 0/1,268 (0%)^*^ CG: 1/1,272 (<0.1%)^*^ Unknown GI: IG: 1/1,268 (<0.1%)^*^ CG: 0/1,272 (0%)^*^ | NR | 0/1,268 (0%) | NR
TPT108,§,‡ Major GI bleeding | Placebo | Upper GI: IG: 5/1,268 (0.4%)^*^ CG: 1/1,272 (<0.1%)^*^ Lower GI: IG: 0/1,268 (0%)^*^ CG: 1/1,272 (<0.1%)^*^ Unknown GI: IG: 1/1,268 (<0.1%)^*^ CG: 0/1,272 (0%)^*^ | NR | 1/1,272 (<0.1%) | NR
SAPAT130,‡ Major GI bleeding | 75 mg/day | 11/1,009 (1.1%)^*^ | NR | 2/1,009 (0.2%)^*^ | NR
SAPAT130,‡ Major GI bleeding | Placebo | 6/1,026 (0.6%)^*^ | NR | 1/1,026 (0.1%)^*^ | NR
JPAD131 GI bleeding (severe=required transfusion) | 81 or 100 mg/day\|\| | 12/1,262 (1.0%)^*^ Severe=4/1,262 (0.32%)^*^ | NR | NR | NR
JPAD131 GI bleeding (severe=required transfusion) | Placebo | 4/1,277 (0.3%)^*^ Severe=0/1,277 (0%)^*^ | NR | NR | NR
POPADAD132 GI bleeding | 100 mg/day | 28/638 (4.4%) | OR, 0.90 (0.53 to 1.52) | NR | NR
POPADAD132 GI bleeding | Placebo | 31/638 (4.9%) | OR, 0.90 (0.53 to 1.52) | NR | NR
AAA133,‡ Major GI hemorrhage | 100 mg/day | 9/1,675 (0.5%)^*^ | NR | NR | NR
AAA133,‡ Major GI hemorrhage | Placebo | 8/1,675 (0.5%)^*^ | NR | NR | NR
ukCAP144 GI bleeding | 300 mg/day | Upper GI: IG: 2/472 (0.4%) CG: 0/467 (0%) Lower GI: IG: 3/472 (0.6%) CG: 5/467 (1.1%) | NR | NR | NR
ukCAP144 GI bleeding | Placebo | Upper GI: IG: 2/472 (0.4%) CG: 0/467 (0%) Lower GI: IG: 3/472 (0.6%) CG: 5/467 (1.1%) | NR | NR | NR
AFPP136,‡ Serious GI bleeding (requiring hospitalization or surgical intervention) | 81 mg/day | 2/377 (0.5%)^*^ | NR, p=0.65 (three groups) | NR | NR
AFPP136,‡ Serious GI bleeding (requiring hospitalization or surgical intervention) | 325 mg/day | 4/372 (1.1%)^*^ | NR, p=0.65 (three groups) | NR | NR
AFPP136,‡ Serious GI bleeding (requiring hospitalization or surgical intervention) | Placebo | 3/372 (0.8%)^*^ | NR, p=0.65 (three groups) | NR | NR
Cohort studies
NHS146 GI bleeding requiring hospitalization or transfusion | 0.5 to 1.5 tablets/week (325 mg) | 1.07 per 1,000 person-years | NR | NR | NR
NHS146 GI bleeding requiring hospitalization or transfusion | 2 to 5 tablets/week (325 mg) | 1.07 per 1,000 person-years | NR | NR | NR
NHS146 GI bleeding requiring hospitalization or transfusion | 6 to 14 tablets/week (325 mg) | 1.40 per 1,000 person-years | NR | NR | NR
NHS146 GI bleeding requiring hospitalization or transfusion | more than 14 tablets/week (325 mg) | 1.57 per 1,000 person-years | NR | NR | NR
NHS146 GI bleeding requiring hospitalization or transfusion | No use | 0.77 per 1,000 person-years | NR | NR | NR

* Calculated

† In-trial and post-trial

‡ Restricted to serious or major events

§ Limited to arms in factorial design that did not receive warfarin, i.e., aspirin only and double placebo

|| Dose not randomized

¶ Number of estimated events = (rate of fatal gastric hemorrhage per 10,000 person-years * number of person-years /10,000) + (rate of fatal peptic ulcer hemorrhage per 10,000 person-years * number of person-years /10,000) + (rate of fatal peptic ulcer perforation per 10,000 person-years * number of person-years /10,000)

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; AFPP = Aspirin/Folate Polyp Prevention study; BMD = British Medical Doctors trial; CG = control group; CI = confidence interval; GI = gastrointestinal; HR = hazard ratio; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis With Aspirin for Diabetes; mg = milligram; NHS = Nurses' Health Study; NR = not reported; OR = odds ratio; PHS = Physicians' Health Study; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; qod = every other day; RR = relative risk; SALT = Swedish Aspirin Low-dose Trial; SAPAT = Swedish Angina Pectoris Aspirin Trial; TPT = Thrombosis Prevention Trial; ukCAP = United Kingdom Colorectal Adenoma Prevention trial; UK-TIA = UK Transient Ischaemic Attack trial; WHS = Women's Health Study

Figure 10 Effect of Aspirin on Gastrointestinal Bleeding Risk

* Serious gastrointestinal bleeding

Note: Differences from point estimates or 95% confidence intervals reported in studies are due to use of different statistical programs, and are minor and of no clinical or statistical significance

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ABI = ankle brachial index; AFPP = Aspirin/Folate Polyp Prevention study; CG = control group; CI = confidence interval; IG = intervention group; IHD = ischemic heart disease; JPAD = Japanese Primary Prevention of Atherosclerosis With Aspirin for Diabetes; MI = myocardial infarction; mg = milligrams; PHS = Physicians' Health Study; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; RAO = retinal artery occlusion; RR = relative risk; SALT = Swedish Aspirin Low-dose Trial; SAPAT = Swedish Angina Pectoris Aspirin Trial; TIA = transient ischemic attack; TPT = Thrombosis Prevention Trial; ukCAP = United Kingdom Colorectal Adenoma Prevention trial; UK-TIA = United Kingdom Transient Ischaemic Attack trial; ukCAP = United Kingdom Colorectal Adenoma Prevention trial; WHS = Women's Health Study; yrs = years

This figure is a forest plot of the relative risk of gastrointestinal bleeding

Figure 11 Effect of Aspirin on Serious Gastrointestinal Bleeding Risk

Note: Differences from point estimates or 95% confidence intervals reported in studies are due to use of different statistical programs, and are minor and of no clinical or statistical significance

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ABI = ankle brachial index; AFPP = Aspirin/Folate Polyp Prevention study; CG = control group; CI = confidence interval; IG = intervention group; IHD = ischemic heart disease; JPAD = Japanese Primary Prevention of Atherosclerosis With Aspirin for Diabetes; mg = milligram; MI = myocardial infarction; OR= odds ratio; PHS = Physicians' Health Study; RAO = retinal artery occlusion; SALT = Swedish Aspirin Low-dose Trial; SAPAT = Swedish Angina Pectoris Aspirin Trial; TIA = transient ischemic attack; TPT = Thrombosis Prevention Trial; UK-TIA = United Kingdom Transient Ischaemic Attack trial; yrs = years

This figure is a forest plot of the relative risk of serious gastrointestinal bleeding

Figure 12 Effect of Aspirin on Fatal Gastrointestinal Bleeding Risk

Abbreviations: BMD = British Medical Doctors trial; CG = control group; CI = confidence interval; IG = intervention group; IHD = ischemic heart disease; mg = milligram; MI = myocardial infarction; OR = odds ratio; PHS = Physicians' Health Study; SAPAT = Swedish Angina Pectoris Aspirin Trial; TIA = transient ischemic attack; TPT = Thrombosis Prevention Trial; UK-TIA = United Kingdom Transient Ischaemic Attack trial; WHS = Women's Health Study; yrs = years

This figure is a forest plot of the relative risk of fatal gastrointestinal bleeding

Table 8 Effect of Aspirin on Risk of Intracranial Bleeding in Randomized, Controlled Trials

Study | Treatment Group | Outcome Definition | Intracranial Hemorrhage/Bleeding
Study | Treatment Group | Outcome Definition | Events/N (%) | Relative Risk Estimate (95% CI)
WHS113,† | 100 mg qod | Hemorrhagic stroke | 85/19,934 (0.4%) | HR, 1.36 (0.98 to 1.88)
WHS113,† | Placebo | Hemorrhagic stroke | 62/19,942 (0.3%) | HR, 1.36 (0.98 to 1.88)
PHS118 | 325 mg qod | Hemorrhagic stroke | 23/11,037 (0.2%)^*^ | RR, 2.14 (0.96 to 4.77)
PHS118 | Placebo | Hemorrhagic stroke | 12/11,034 (0.1%)^*^ | RR, 2.14 (0.96 to 4.77)
BMD124 | 500 mg/day | Fatal hemorrhagic stroke and nonfatal stroke, probably hemorrhagic | 13^‡^/3,429 (0.4%)^*^ | NR
BMD124 | Control (no placebo) | Fatal hemorrhagic stroke and nonfatal stroke, probably hemorrhagic | 6^‡^/1,710 (0.4%)^*^ | NR
UK-TIA126 | 1,200 mg/day | Intracranial hemorrhage | 7/815 (0.9%) | NR
UK-TIA126 | 300 mg/day | Intracranial hemorrhage | 7/806 (0.9%) | NR
UK-TIA126 | Placebo | Intracranial hemorrhage | 2/814 (0.2%) | NR
SALT127 | 75 mg/day | Intracerebral and subarachnoid hemorrhage | 11/676 (1.6%)^*^ | NR
SALT127 | Placebo | Intracerebral and subarachnoid hemorrhage | 4/684 (0.6%)^*^ | NR
TPT108,§ | 75 mg/day | Hemorrhagic and sub-arachnoid stroke | 3/1,268 (0.2%)^*^ | NR
TPT108,§ | Placebo | Hemorrhagic and sub-arachnoid stroke | 2/1,272 (0.2%)^*^ | NR
SAPAT130 | 75 mg/day | Subdural hematoma and hemorrhagic stroke | 6/1,009 (0.6%)^*^ | NR
SAPAT130 | Placebo | Subdural hematoma and hemorrhagic stroke | 2/1,026 (0.2%)^*^ | NR
JPAD131 | 81 or 100 mg/day\|\| | Subdural hematoma and hemorrhagic stroke | 8/1,262 (0.6%)^*^ | NR
JPAD131 | Placebo | Subdural hematoma and hemorrhagic stroke | 7/1,277 (0.5%)^*^ | NR
POPADAD132 | 100 mg/day | Fatal hemorrhagic stroke | 2/638 (0.3%)^*^ | NR
POPADAD132 | Placebo | Fatal hemorrhagic stroke | 3/638 (0.5%)^*^ | NR
AAA133 | 100 mg/day | Intracranial hemorrhage | 11/1,675 (0.7%)^*^ | NR
AAA133 | Placebo | Intracranial hemorrhage | 7/1,675 (0.4%)^*^ | NR
AFPP136 | 81 mg/day | Hemorrhagic stroke | 1/377 (0.3%)^*^ | NR
AFPP136 | 325 mg/day | Hemorrhagic stroke | 0/372 (0%)^*^ | NR
AFPP136 | Placebo | Hemorrhagic stroke | 0/372 (0%)^*^ | NR
ukCAP144 | 300 mg/day | Subarachnoid hemorrhage | 2/472 (0.4%)^*^ | NR
ukCAP144 | Placebo | Subarachnoid hemorrhage | 0/467 (0%)^*^ | NR

* Calculated

† In-trial and post-trial

‡ Number of estimated events = (rate of fatal hemorrhagic stroke per 10,000 person-years * number of person-years /10,000) + (rate of nonfatal, probable hemorrhagic stroke per 10,000 person-years * number of person-years /10,000)

§ Limited to arms in factorial design that did not receive warfarin, i.e., aspirin only and double placebo

|| Dose not randomized

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; AFPP = Aspirin/Folate Polyp Prevention study; BMD = British Medical Doctors trial; CI = confidence interval; HR = hazard ratio; JPAD = Japanese Primary Prevention of Atherosclerosis With Aspirin for Diabetes; mg = milligram; NR = not reported; PHS = Physicians' Health Study; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; qod = every other day; RR = relative risk; SALT = Swedish Aspirin Low-dose Trial; SAPAT = Swedish Angina Pectoris Aspirin Trial; ukCAP = United Kingdom Colorectal Adenoma Prevention trial; UK-TIA = UK Transient Ischaemic Attack trial; TPT = Thrombosis Prevention Trial; WHS = Women's Health Study

Figure 13 Effect of Aspirin on Intracranial Bleeding Risk

Note: Differences from point estimates or 95% confidence intervals reported in studies are due to use of different statistical programs, and are minor and of no clinical or statistical significance

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ABI = ankle brachial index; AFPP = Aspirin/Folate Polyp Prevention study; BMD = British Medical Doctors trial; CG = control group; CI = confidence interval; IG = intervention group; IHD = ischemic heart disease; JPAD = Japanese Primary Prevention of Atherosclerosis With Aspirin for Diabetes; mg = milligram; MI = myocardial infarction: OR = odds ratio; PHS = Physicians' Health Study; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; RAO = retinal artery occlusion; SALT = Swedish Aspirin Low-dose Trial; SAPAT = Swedish Angina Pectoris Aspirin Trial; TIA = transient ischemic attack; TPT = Thrombosis Prevention Trial; ukCAP = United Kingdom Colorectal Adenoma Prevention trial; UK-TIA = United Kingdom Transient Ischaemic Attack trial; WHS = Women's Health Study; yrs = years

This figure is a forest plot of the relative risk of intracranial bleeding

Table 9 Effect of Aspirin on Risk of Hemorrhagic Stroke in Randomized, Controlled Trials

Study | Treatment Group | Events/N (%) | Relative Risk Estimate (95% CI)
WHS113,† | 100 mg qod | 85/19,934 (0.4%) | HR, 1.36 (0.98 to 1.88)
WHS113,† | Placebo | 62/19,942 (0.3%) | HR, 1.36 (0.98 to 1.88)
PHS118 | 325 mg qod | 23/11,037 (0.2%)^*^ | RR, 2.14 (0.96 to 4.77)
PHS118 | Placebo | 12/11,034 (0.1%)^*^ | RR, 2.14 (0.96 to 4.77)
BMD124 | 500 mg/day | 13^**^/3,429 (0.4%)^*^ | NR
BMD124 | Control (no placebo) | 6^**^/1,710 (0.4%)^*^ | NR
UK-TIA126,‡ | 1,200 mg/day | 7/815 (0.9%) | NR
UK-TIA126,‡ | 300 mg/day | 7/806 (0.9%) | NR
UK-TIA126,‡ | Placebo | 2/814 (0.2%) | NR
TPT108,§ | 75 mg/day | 2/1,268 (0.2%) | NR
TPT108,§ | Placebo | 0/1,272 (0%) | NR
SALT127 | 75 mg/day | 8^††^/676 (1.2%)^*^ | NR
SALT127 | Placebo | 3^††^/684 (0.4%)^*^ | NR
SAPAT130 | 75 mg/day | 5/1,009 (0.5%)^*^ | NR
SAPAT130 | Placebo | 2/1,026 (0.2%)^*^ | NR
JPAD131 | 81 or 100 mg/day^‖^ | 6/1,262 (0.5%)^*^ | NR
JPAD131 | Placebo | 7/1,277 (0.5%)^*^ | NR
POPADAD132,¶ | 100 mg/day | 2/638 (0.3%)^*^ | NR
POPADAD132,¶ | Placebo | 3/638 (0.5%)^*^ | NR
AAA133 | 100 mg/day | 5/1,675 (0.3%)^*^ | NR
AAA133 | Placebo | 4/1,675 (0.2%)^*^ | NR
AFPP136 | 81 mg/day | 1/377 (0.3%)^*^ | NR
AFPP136 | 325 mg/day | 0/372 (0%)^*^ | NR
AFPP136 | Placebo | 0/372 (0%)^*^ | NR

* Calculated

† Includes post-trial followup; fatal stroke, is limited to in-trial followup

‡ Limited to major or disabling hemorrhagic stroke

§ Limited to arms in factorial design that did not receive warfarin, i.e., aspirin only and double placebo

‖ Dose not randomized

¶ Limited to fatal hemorrhagic stroke

** Number of events estimated = (rate of fatal hemorrhagic stroke per 10,000 person-years * number of person-years /10,000) + (rate of nonfatal probable hemorrhagic stroke per 10,000 person-years * number of person-years /10,000

†† Intracerebral hemorrhage

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; AFPP = Aspirin/Folate Polyp Prevention study; BMD = British Medical Doctors trial; HR = hazard ratio; JPAD = Japanese Primary Prevention of Atherosclerosis With Aspirin for Diabetes; mg = milligram; NR = not reported; PHS = Physicians' Health Study; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; qod = every other day; RR = relative risk; SALT = Swedish Aspirin Low-dose Trial; SAPAT = Swedish Angina Pectoris Aspirin Trial; TPT = Thrombosis Prevention Trial; UK-TIA = UK Transient Ischaemic Attack trial; WHS = Women's Health Study

Figure 14 Effect of Aspirin on Hemorrhagic Stroke Risk

Note: Differences from point estimates or 95% confidence intervals reported in studies are due to use of different statistical programs, and are minor and of no clinical or statistical significance

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ABI = ankle brachial index; AFPP = Aspirin/Folate Polyp Prevention study; BMD = British Medical Doctors trial; CG = control group; CI = confidence interval; IG = intervention group; IHD = ischemic heart disease; JPAD = Japanese Primary Prevention of Atherosclerosis With Aspirin for Diabetes; MI = myocardial infarction; mg = milligram; OR = odds ratio; PHS = Physicians' Health Study; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; SALT = Swedish Aspirin Low-dose Trial; SAPAT = Swedish Angina Pectoris Aspirin Trial; RAO = retinal artery occlusion; TIA = transient ischemic attack; TPT = Thrombosis Prevention Trial; UK-TIA = United Kingdom Transient Ischaemic Attack trial; WHS = Women's Health Study; yrs = years

This figure is a forest plot of the relative risk of hemorrhagic stroke

### Detailed Results: Gastrointestinal Bleeding

We identified 12 RCTs (seven good quality, five fair quality) comparing gastrointestinal bleeding risk among patients randomized to aspirin vs. placebo (Table 7). The median intended treatment duration was 2.6 to 10.1 years. Ten trials were of daily or alternate day aspirin in the general population: WHS, PHS, BMD, UK-TIA, SALT, TPT, SAPAT, JPAD, POPADAD, and AAA. In addition, two RCTs conducted among patients with a prior adenoma (ukCAP and AFPP) also reported on gastrointestinal bleeding. All studies excluded patients with a history of bleeding, ulcers, contraindication on aspirin, or history of adverse effects from aspirin. All but two studies examined doses ≤325 mg/day, most of which were ≤100 mg/day.

In our analysis of any gastrointestinal bleeding, we examined results from 11 trials (N=79,542). We excluded BMD because it reported on fatal gastrointestinal bleeding only. In most trials, the incidence of gastrointestinal bleeding was higher in the aspirin group than the control group (Table 7, Figure 10); however, most studies had too few events to report RR estimates. We did not pool results because definitions of gastrointestinal bleeding differed across studies (i.e., some restricted to serious bleeds).

Serious gastrointestinal bleeds were those requiring transfusion or hospitalization, resulting in death, requiring surgical intervention, or defined as severe or major by the authors if not otherwise specified. Studies that reported only fatal events only were excluded from analyses of serious gastrointestinal bleeding because of incomplete capture of serious events. In the eight studies that reported on serious gastrointestinal bleeds (PHS, TPT, UK-TIA, SAPAT, AAA, AFPP, JPAD, and SALT) (N=37,451), the incidence was nearly twice as high in persons randomized to aspirin (0.64%) as in persons randomized to placebo (0.29%); in all but one study, the incidence was higher in the aspirin group than the control group (Table 7, Figure 11) (summary OR, 1.94 [95% CI, 1.44 to 2.62]).

Six studies reported on fatal gastrointestinal bleeding (N=74,096). Combining PHS, WHS, BMD, UK-TIA, TPT, and SAPAT data (Table 7, Figure 12), we estimated the incidence of fatal bleeding to be 0.03 percent in patients assigned to aspirin compared to 0.02 percent in patients assigned to placebo. RR estimates were not consistent across studies: three had computed ORs greater than one, two had ORs less than one, and one had and OR equal to one. The summary OR was 1.00 (95% CI, 0.43 to 2.36). In the single study that compared two different doses of aspirin to placebo (UK-TIA, N=2,435), there was a suggestion of increased risk of gastrointestinal hemorrhage in the higher-dose aspirin group (1,200 mg/day) than the lower-dose group (300 mg/day) (5% vs. 3%) during a median follow-up of 4.4 years (OR=1.62, [95% CI: 0.94 to 2.79]).

We identified one cohort study that assessed the risk of gastrointestinal bleeding in aspirin nonusers and users at doses and frequencies relevant for this review. NHS reported a higher risk of serious gastrointestinal bleeding in users of 6 to 14 tablets/week of 325 mg aspirin (1.40 per 1,000 person-years) and users of more than 14 tablets/week of 325 mg aspirin (1.57 per 1,000 person-years) compared to nonusers (0.77 per 1000 person-years).146

In summary, evidence primarily from RCTs suggested a two-fold increase in risk of serious gastrointestinal bleeding associated with daily or alternate-day aspirin use, but the effects on any gastrointestinal bleeding and fatal gastrointestinal bleeding were less clear.

### Detailed Results: Intracranial Bleeding, Including Hemorrhagic Stroke

Definitions of intracranial bleeding differed across studies. Where possible, we summed the number of events of hemorrhagic stroke, subarachnoid hemorrhage or stroke, and epidural and subdural hematoma. Not all event types were reported in all studies. Thus, the estimates in Table 8 have slightly different interpretations by study; however, within each study the definition was identical for aspirin users and controls. A total of 12 RCTs were included (N=84,681) (Table 8, Figure 13). The median intended treatment duration was 2.6 to 10.1 years. Nine studies tested doses of aspirin were ≤100/day. In 11 of 12 studies, the incidence of intracranial bleeding in the aspirin group was equal to or higher than the control group. Overall, the incidence across aspirin groups was 0.40 percent compared to 0.26 percent in the control group. The summary OR was 1.53 (95% CI, 1.21 to 1.93).

### Detailed Results: Hemorrhagic Stroke

Eleven RCTs reported on hemorrhagic stroke: WHS, PHS, BMD, UK-TIA, TPT, SALT, SAPAT, JPAD, POPADAD, AAA, and AFPP (N=83,742) (Table 9, Figure 14). In nearly all studies, the risk of hemorrhagic stroke was higher in the aspirin group than in the control group. Combining results across studies, the incidence of hemorrhagic stroke was 0.38 percent in the aspirin groups and 0.25 percent in the control groups (summary OR, 1.47 [95% CI, 1.16 to 1.88]). In UK-TIA, the risk of major and/or fatal definite hemorrhagic stroke was slightly higher among women than men in both the 1,200 mg/day aspirin group (men: 0.7%, women: 1.4%) and the 300 mg/day aspirin group (men: 0.8%; women: 1.0%), but not the placebo group (men: 0.3%; women: 0%); however the total number events was small (N=16). In the only study that compared doses of aspirin (UK-TIA, N=2,435), the incidence was identical (0.9%) in the two aspirin groups (1,200 mg/day vs. 300 mg/day); however each group had only seven events. None of the included cohort studies reported intracranial bleeding.

None of the included cohort studies reported on hemorrhagic stroke.

## Contextual Question What Is the Level of Persistence of Aspirin Use Among Adults Who Initiate a Regimen for the Prevention of Colorectal Cancer?

Our contextual question focused on persistence (continued use after initiation) of aspirin for CRC prevention; however, the body of evidence we examined was broader in two respects. First, some of the studies reported on adherence (use as directed), sometimes called compliance, rather than persistence. Second, we included literature that focused on aspirin for CVD prevention, as much of the data on benefits came from such studies. Adherence and persistence had varying definitions and ascertainment across studies. In general, we could not obtain information on persistence from cohort studies.

We summarized persistence and adherence information by indication for use, as evidence supports varying rates of adherence by indication with higher rates in individuals who use aspirin for secondary prevention or have a greater risk profile for the disease of interest.174 Appendix D Table 8 provides adherence information from RCTs and one observational study. Our primary interest was aspirin persistence rather than overall persistence in RCTs, which was generally lower than placebo in most trials reporting separate estimates.

Data for primary CRC prevention were the most relevant for this contextual question. These data were available from three trials focused on CRC prevention in persons with a prior adenoma; all three suggested high compliance within one year (87 to 95% from APACC and AFPP) and two years (91%) (AFPP). APACC reported 88 percent compliance at four years and ukCAP reported 75 percent at year three. Two RCTs targeted CVD prevention and cancer prevention in general (not CRC specifically). Both were conducted among U.S. healthcare professionals. The WHS (women) reported 88 percent 1-year compliance, 76 percent 5-year compliance, 67 percent 10-year compliance. PHS (men) reported 83 percent 4.75-year persistence. Of note, both WHS and PHS reported measures for aspirin and placebo groups combined.

The main primary prevention persistence/adherence literature came from CVD trials. We identified data from 12 RCTs focused on aspirin use for primary CVD prevention. Nearly all studies reporting multiple persistence/adherence measures over time demonstrated declines over the course of the trial. Ten trials reported persistence/adherence within the first year or at year one of 80 to 92 percent. Reported persistence/adherence dropped in all studies except the Primary Prevention Project (PPP),175 which maintained 81 percent persistence from the first trial year to 3.6 years. By 5 years, 58 to 83 percent of individuals in the CVD primary prevention studies were still persistent/adherent to treatment.

Aspirin persistence/adherence for secondary prevention of CVD was reported in 13 trials86,108,111,112,121,126-128,130-133,136,142,144,175-189 and one observational study.190 People with CVD taking aspirin for secondary prevention are theoretically the least relevant group for estimating persistence/adherence among individuals taking aspirin for CRC chemoprevention; however, we found no notable differences in reported adherence relative to the primary prevention trials. The persistence/adherence measures might not have been sensitive enough to detect differences or no differences may exist between primary and secondary CVD prevention users. A recent systematic review suggested adherence generally ranged from 72 to 92 percent over varying followup periods (generally <2 years).174

Real-world persistence may be best reflected in observational studies. However, we included only a single cohort study190 since others we reviewed had limitations in ascertainment of exposure (prior use). The cohort study we included ascertained dispensing data including strength, number of pills dispensed and instructions for use, enabling calculation of daily dose and adherence. In a population from Tayside, Scotland receiving aspirin for secondary CVD prevention,190 short-term adherence was substantially lower than reported in RCTs (58% at year one vs. 80 to 92 percent in primary CVD prevention RCTs, and 56% at five years vs. 50 to 83 percent in RCTs).

Duffy and colleagues recently reviewed the current literature on aspirin therapy adherence for primary and secondary CVD prevention.174 The literature on adherence rates, reasons for medication adherence, strategies for improving adherence, predictors of poor patient compliance and interventions for improving adherence are outlined in detail in their review.174 Of the 12 articles identified in the review, only two focused exclusively on populations taking aspirin for primary prevention and one focused on primary and secondary prevention combined. The review discusses how factors related to patients, providers, and medications can influence adherence. An additional factor affecting adherence to aspirin for prevention is that its use is largely for asymptomatic disease; this factor is associated with lower adherence.174 Another factor influencing adherence that might be less well known is the mode of use recommendation or prescription. Receiving a prescription for low-dose aspirin can lead to increased adherence relative to over-the-counter recommendations from providers.191

In summary, we found that in RCTs, persistence/adherence to aspirin was generally high (≥85%) in the first year, declining to 50 to 83 percent after three to five years, with substantial variability across studies.