# Methods

The USPSTF will use this systematic review to update its 2007 recommendation on aspirin use for the prevention of CRC.

## Analytic Framework and Key Questions

Following the methods of the USPSTF,106 we developed an analytic framework and key questions (KQs) to guide the literature search, data abstraction, and evidence synthesis for a systematic review of aspirin and CRC. We also included a contextual question (CQ) that was not systematically reviewed, and therefore not included in the analytic framework.

To establish the review scope and develop the analytic framework and KQs, we scanned for evidence published since the previous review to identify new information related to aspirin or NSAID use and CRC. We searched for existing systematic reviews and meta-analyses, using MEDLINE, British Medical Journal Clinical Evidence, Cochrane Database of Systematic Reviews, the Database of Abstracts of Reviews of Effects, and publications from the Institute of Medicine and the National Institute for Health and Clinical Excellence (Appendix A Figure 1A). We reviewed the titles and abstracts of 103 resultant articles and identified seven relevant reviews.

As part of the scan for new evidence, we examined relevant new and pending trials since the last review. We searched for ongoing trials using selected gray literature sources including ClinicalTrials.gov, the World Health Organization International Clinical Trials Registry Platform, Current Controlled Trials (ISRCTN Register), and the Food and Drug Administration website. We searched for results from pending trials using PubMed. Only one of the pending trials was relevant to this updated review because it includes an intervention other than a selective COX-2 inhibitor. Our search identified 38 new trials with seven determined to be potentially relevant because of a focus on aspirin and average-risk or adenoma populations.

The analytic framework addressing aspirin for the prevention of cancer is in Figure 1. Our report addresses KQs 1/3 (initially formulated as a combined question focusing on ACM and CRC mortality), KQ 4, KQ 5, and KQ 7. We addressed the following KQs in adults without a history of CRC, FAP, or Lynch syndrome.

Figure 1 Analytic Framework

Note: Numbers indicate Key Questions

Abbreviations: ASA = aspirin; CRC = colorectal cancer; FAP = Familial adenomatous polyposis

The figure is an analytic framework that depicts the Key Questions addressed in this report and a companion report on aspirin use to prevent all cancers. The figure illustrates how aspirin use for primary prevention among adults aged 40 years or older may reduce all-cause and cancer-related mortality (Key Question 1) including colorectal cancer (Key Question 2); the incidence of cancers (Key Question 2) including colorectal cancer (Key Question 4); and the incidence of colorectal adenomas (Key Question 5). The analytic framework also depicts the possible harms associated with aspirin use in the primary prevention of cancer (Key Question 6) or colorectal cancers specifically (Key Question 7). This report specifically addressed Key Questions 1, 2 and 6.

### Benefits Key Questions

1, 3 Does regular aspirin use reduce CRC mortality or ACM?
4 Does regular aspirin use reduce the incidence of CRC?
5 Does regular aspirin use reduce the incidence of colorectal adenoma?

For each of these benefits KQs we also addressed the following subquestions:

- Does the effect of aspirin vary by age, sex, race, comorbidities, or baseline cancer risk?
- Does the effect of aspirin vary by frequency, dosage, duration, or recency of use?

Comorbidities of interest were diabetes, liver disease, ulcer disease, and previous gastrointestinal bleeding as they are prevalent and/or may be affected by aspirin use. Adenoma history, family history and other established risk factors, as specified in the included studies, were considerations for baseline cancer risk.

### Harms Key Question

7 What are the harms of regular aspirin use for the prevention of CRC (at the dosage and duration required to achieve a preventive health effect)?

Aspirin harms of interest in this review were gastrointestinal bleeding (any, serious, and fatal); intracranial bleeding (including hemorrhagic stroke); hemorrhagic stroke; and age-related macular degeneration.

In this harms KQ we also addressed the following subquestion:

- Do harms vary by patient characteristics (e.g., age, sex, race, comorbidities, or concomitant medication use)?

In addition to the comorbidities considered for the benefits KQ subquestions, medications considered for this harms subquestion were nonaspirin NSAIDs and selective serotonin reuptake inhibitors (SSRIs).

### Contextual Question

What is the level of persistence of aspirin use among adults who initiate a regimen for the prevention of CRC?

## Data Sources and Searches

In addition to considering all studies from the previous USPSTF review1 for inclusion in the updated review, we developed a search strategy designed to capture relevant literature published since the previous review. The previous systematic evidence review searched literature published through 2004 (month and day varied by database). Our experienced medical librarian designed and conducted a comprehensive search for original new research from January 1, 2004 to September 2013 using MEDLINE, PubMed, and Central Register of Controlled Trials (Appendix A Figure 1B). We used search terms similar to those used in our scan for new synthesized evidence, but limited our search to studies of aspirin only. We also expanded our search criteria to include observational studies. Additionally, we examined reference lists of published reviews, meta-analyses, and primary studies to identify other potential articles for inclusion. In June 2014, the medical librarian conducted a bridge search through May 2014. In total, we identified 865 potentially relevant abstracts through these efforts.

We obtained data on ACM and harms of aspirin only from studies that reported on CRC outcomes. In other words, we did not conduct a separate search of the entire literature on the effects of aspirin on harms or ACM. The rationale for this decision was that the concurrent systematic reviews (Aspirin for the Primary Prevention of Cardiovascular Events and Aspirin Use in Adults: Total Cancer, All-Cause Mortality and Harms) were also obtaining data on these outcomes and the USPSTF would consider evidence from all the reviews together.

## Study Selection

Two reviewers reviewed the titles and abstracts of 865 unique articles (Appendix A Figure 2) against inclusion and exclusion criteria (Appendix A Table 1). We retrieved 149 potentially relevant articles (Appendix A Figure 2) that two investigators reviewed against the same inclusion and exclusion criteria. Reviewer disagreements at the abstract or full-text review stages were resolved by consensus and consultation with a third investigator if needed. We excluded articles that did not meet inclusion criteria or were rated as poor quality. Excluded articles and reasons for their exclusion by key question are in Appendix C.

We developed an a priori set of criteria for inclusion and exclusion of studies based on our understanding of the literature and the refined analytic framework and KQs (Figure 1). This review focused on average-risk adults, excluding people with inflammatory bowel disease, familial hereditary colorectal syndromes (Lynch, FAP, etc.), or a personal history of cancer. We focused on aspirin for chemoprevention; all nonaspirin NSAIDs were excluded from consideration. For analysis of benefits, we excluded intended or reported durations of use less than 12 months.

For all KQs (benefits and harms), we included RCTs, controlled clinical trials, fair-quality and good-quality systematic reviews and meta-analyses of RCTs, and fair-quality and good-quality prospective cohort studies (Appendix A Table 1). We included only studies in which the majority of patients were ≥40 years old (determined by the USPSTF to be the earliest appropriate target age) and at average risk for CRC based on patient characteristics (e.g., excluding for FAP, history of CRC, no colon, and symptoms). The exception to the patient characteristic exclusion was history of adenoma, which is associated with an intermediate CRC risk (depending on adenoma characteristics) due to risk of adenoma recurrence; however, people in this category are still are considered part of the average-risk primary care population. For the benefits KQs (1/3, 4, and 5), we included only articles in which the oral aspirin intervention or exposure was a minimum dose of 75 mg taken daily or on alternate days for a minimum of one year, since lower frequency of use, doses, and durations were less likely to have an effect and to be studied.81 For studies of alternate day dosing we divided by two to obtain the average daily dose.

No maximum dose or duration was specified. For the harms KQ (7), we required no minimum duration of use since harms could occur soon after initiation. For all KQs (benefits and harms), we were interested in studies in which the comparison group was a placebo, “no treatment,” or an unexposed group. To ensure that any effects observed resulted from aspirin and not another factor, we excluded studies with interventions or exposure group categories that combined aspirin with another medication for chemoprevention. However, factorial design studies were eligible for inclusion. For benefits KQs, examining the benefits of aspirin, we included studies that examined mortality (all-cause and CRC-specific), CRC incidence, and adenoma incidence. Studies reporting only on CRC metastasis or progression were excluded. After these inclusion and exclusion criteria were applied, we further limited inclusion to studies rated fair or good quality according to USPSTF risk-of-bias criteria106 and Newcastle Ottawa Scales for cohort studies.107 We excluded studies not published in English.

## Quality Assessment

Two investigators independently and critically appraised the methodological quality of each study that met the inclusion criteria. Quality was assessed using design-specific criteria developed by the USPSTF for RCTs106 and supplemented with Newcastle Ottawa Scales for cohort studies (Appendix A Table 2).107 We rated articles as good, fair, or poor quality with respect to internal validity. In general, a good-quality study clearly met all quality criteria. A fair-quality study did not meet, or did not clearly meet, all criteria for a good-quality study, but also had no important limitations that would suggest invalid results. A poor-quality study had at least one fatal flaw or multiple important limitations that collectively made its findings questionable in our judgment. Discordant quality ratings were resolved by interrater discussion and consultation with a third investigator as needed. We excluded poor-quality studies from this review (Appendix C).

Good-quality RCTs demonstrated adequate randomization procedures and allocation concealment; similar groups at baseline (i.e., little-to-no difference between groups in baseline demographics and characteristics); blinded outcome assessment; adherence to the intervention protocol; low attrition (≥90% of participants had followup data with <10 percentage-point difference in loss to followup between groups); and performed an intent-to-treat analysis. Trials were downgraded to fair if they did not meet one or more of the good-quality criteria but had no known threats to validity. Trials were rated as poor quality if attrition was greater than 40 percent or differed between groups by more than 10 percentage points or the analysis did not follow the intent-to-treat principle.

Good-quality cohort studies had unbiased definition and selection of the unexposed group, ascertainment of exposure that preceded the outcome, and an outcome of interest that was not present in the source population at study onset. Good-quality studies also had reliable outcome measures, blinded outcome assessment, low attrition, and adequate adjustment for potential confounders. Cohort studies were downgraded to fair if they did not meet all good-quality criteria. We rated cohort studies as poor quality if the exposed and unexposed groups were derived from different source populations or adjustment for key characteristics associated with CRC risk (e.g., age and gender) was inadequate.

## Data Abstraction

A primary reviewer abstracted data from all fair-quality or good-quality studies into structured evidence tables and a secondary reviewer verified all data. For each article, elements abstracted included study design details (e.g., study period, recruitment and enrollment setting and approach, targeted population, inclusion and exclusion criteria, run-in phase for trials, and followup); population characteristics (e.g., age, sex, race/ethnicity, BMI, smoking status, family history, screening history, adenoma history, and medication use); intervention or exposure characteristics (e.g., intervention design and adherence or persistence to study medication for trials, and dose, intensity, frequency, and duration of aspirin use); and sample sizes (N) recruited, enrolled, eligible, and analyzed.

We abstracted information including method of ascertainment on all study outcomes pertaining to the KQs. Information included ACM and CRC-specific mortality (KQ 1/3); CRC incidence (KQ 4); colorectal adenoma incidence, adenoma number, advanced adenoma incidence, advanced neoplasia, and adenoma size (KQ 5); and gastrointestinal bleeding, colorectal bleeding, esophageal bleeding, fatal bleeds, subarachnoid or subdural hemorrhage, intracranial bleed, stroke, and age-related macular degeneration (KQ 7). For each outcome, we abstracted the number of events, incidence rate, and measures of association or difference (e.g., relative risk [RR], hazard ratio [HR]) when provided. We abstracted outcome data for the overall study population and by intervention and exposure group when reported. We also abstracted outcome information by dose, duration, and time since first or last use separately, if provided.

As necessary, we summed across event subtypes to obtain the total number of events for our primary outcomes (e.g. hemorrhagic intracerebral stroke, subarachnoid stroke, and epidural or subdural hematoma were summed to obtain total number of intracranial bleeding cases). When studies reported gender distributions and means by exposure or treatment groups, we computed weighted averages to obtain study-level information. We used a similar approach for describing study populations in individual patient data (IPD) meta-analyses when pooled study population characteristics were not reported but were available from contributing studies. For factorial studies, we combined data across aspirin groups. The only exception was a factorial study of aspirin and warfarin,108 for which we examined the effect of aspirin on harms in the groups not receiving warfarin, an anticoagulant because of concerns about effect modification. Calculations not reported by study authors are marked with a symbol in the Tables.

## Data Synthesis and Analysis

For each body of literature defined by the KQs, we created summary evidence tables to capture key study characteristics and sources of heterogeneity (e.g., study quality, sample size, geographic location, age, sex, dose, frequency and duration of aspirin use, and duration of followup). These tables were the basis for our qualitative evidence synthesis for each KQ. We identified the range of results for ACM, CRC mortality, CRC incidence, colorectal adenoma incidence, and adverse events in the context of important population characteristics and study design features. In addition to the overall results for each included study, we also presented results by dose, duration, and followup period where possible. Categories of doses used for stratification are shown below.

Category | Aspirin Dose | Included Aspirin Ranges
High | >325 mg | 500 mg qd to 1200 mg qd
Low | ≤325 mg | 100 mg qod to 325 mg qd
Very Low | ≤100 mg | 100 mg qod to 100 mg qd

Abbreviations: qd = daily; qod = every other day.

In our quantitative synthesis of each body of literature, we used forest plots stratified by potentially important exposure and study characteristics to visually identify patterns in the study results and determine if pooling across studies was appropriate. We present results stratified by followup period because of apparent differences in effect by time since initiation of aspirin. We did not combine results from bodies of evidence limited to two studies, but instead presented results from each individual study. Decisions to pool were based on clinical and methodological similarity rather than statistical tests of heterogeneity.109 We did not combine across studies when estimates across studies had unexplained heterogeneity (e.g., not attributable to differences in study populations), with estimates of different magnitude or direction, based on statistical advice.110 We also did not combine studies if information was insufficient (e.g., rates but no samples sizes and event counts).

We chose a fixed effects model approach for all analyses, due to the relatively small number of studies. Fixed effects models assume a single treatment effect across studies, and assume that any heterogeneity between studies is due to random variation. We used the Peto fixed effects model to estimate the combined effect and confidence interval when the cumulative incidence of the outcome in the control group was less than one percent, or when one of the comparison groups had no events. The Peto method is the recommended meta-analysis method under the circumstance of rare binary outcomes, because it provides the least biased and most powerful estimate of the combined effect, and the best confidence interval coverage.109 For these analyses, we used a continuity correction factor, adding 0.5 to each cell for studies with no observed events in one or both study arms. When the outcome was less rare, and the cumulative incidence in the control group exceeded one percent, we used the Mantel-Haenszel fixed effects model to estimate the combined effect. We used Stata 12.0 (StataCorp LP, College Station, TX) for all statistical analyses.

## Expert Review and Public Comment

We posted the draft Research Plan for this review for public comment from June 13, 2013 to July 10, 2013. We received comments from seven organizations and individuals. All comments were addressed as appropriate. The main changes to the Research Plan based on public comments were: 1) inclusion of prospective observational studies, and 2) inclusion of patients with a history of adenoma. The final Research Plan was posted on the USPSTF website in October 2013. The draft version of this report was reviewed by experts and federal partners from June 2, 2014 to June 20, 2014. In July 2014, all three related aspirin evidence reviews were presented and discussed together at the USPSTF meeting.

## USPSTF Involvement

The authors worked with three USPSTF liaisons at key points throughout the review process to refine the analytic framework and KQs, resolve issues around review scope, and finalize the evidence synthesis. This research was funded by AHRQ under a contract to support the work of the USPSTF. AHRQ staff provided oversight for the project and facilitated communication with USPSTF liaisons. The USPSTF and AHRQ had no role in the study selection, quality assessment, or the drafting of this systematic review.