# Introduction

## Scope and Purpose

The Agency for Healthcare Research and Quality (AHRQ) commissioned an updated systematic evidence review on the use of aspirin and nonaspirin nonsteroidal anti-inflammatory drugs (NSAIDs) for the prevention of colorectal cancer (CRC) incidence and mortality.1,2 The United States Preventive Services Task Force (USPSTF) will use this report to update its 2007 recommendation on the use of aspirin and NSAIDs for CRC primary prevention, which recommended against the routine prophylactic use of these medicines for individuals at average risk for CRC (Grade D recommendation).3

The previous review for the USPSTF on CRC prevention found fair-to-good evidence on the benefits and harms of aspirin and/or NSAID use but lacked details about the doses, duration, and timing of use, particularly for subgroups with varying risk levels. Since the last evidence review in 2007, two selective cyclooxygenase-2 (COX-2) inhibitors, rofecoxib and valdecoxib, are no longer available in the United States (U.S.) because of their increased cardiovascular risk profile. Both the remaining COX-2 inhibitor (celecoxib) and nonselective NSAIDs now include black box warnings on their labels about increased general safety concerns. Because of concerns about NSAIDs, this evidence review update focuses only on use of aspirin for CRC prevention. In 2013, we developed a work plan for this review to address evidence gaps about aspirin chemoprevention and to support the USPSTF in updating its previous recommendation.

A separate systematic review to update the 2009 USPSTF recommendations on the targeted use of aspirin for the primary prevention of cardiovascular events has also been commissioned. A third systematic review assessing the effects of aspirin on total cancer, all-cause mortality (ACM), and harms has also been prepared. These three concurrent systematic reviews will allow the USPSTF to simultaneously consider all three bodies of evidence to evaluate the preventive health benefits of aspirin.

## Condition Definition

CRC begins in the large intestine with most cancers originating in the mucosa of this organ. CRC generally develops slowly from benign precursor lesions known as polyps. Adenomatous polyps or adenomas, which are characterized by the loss of normal cell differentiation, can become malignant and give rise to most CRCs.4 The identification and removal of adenomas via endoscopy prevents their progression into malignant lesions.5 Symptoms of CRC may include blood in the stool, anemia, a change in bowel habits (including diarrhea and constipation), abdominal pain or tenderness, or unexplained weight loss.6

## Prevalence and Burden of Disease

CRC is an important public health problem in the United States. It is the third most commonly diagnosed cancer in both men and women with an estimated 136,830 new cases expected to occur in 2014.^7^ It is also the third leading cause of cancer death. Approximately 50,310 CRC deaths are expected in 2014, accounting for 8.6 percent of all expected cancer deaths.6 According to the most recent Surveillance, Epidemiology, and End Results Program (SEER) data (2004-2010), 5-year survival for CRC is 64.7 percent, ranging from 89.8 percent for local stage disease to 12.9 percent for distant metastatic disease.8 CRC incidence and mortality have declined over the past 20 years, attributable to both population changes in CRC-related risks and the introduction of screening, with more recent declines largely attributed to increased colonoscopy utilization.6,9 The estimated costs associated with CRC care in the United States were $14 billion in 2010, and are projected to be $17 billion by 2020 if incidence, survival, and costs remain stable.10

Nonmodifiable risk factors that characterize subpopulations at increased CRC risk include:

- Age. CRC risk increases with age, with 90 percent of diagnoses in 2010 occurring among individuals aged 50 years or older,6 although incidence appears to be increasing in those younger than 50 years.11,12
- Gender. Men are at one-and-a-half to two-fold increased age-specific risk for both advanced adenomas and CRC relative to women,13-15 although lifetime CRC risk is believed to be comparable between men and women.13,16 A woman's risk appears to lag behind that of her male counterpart by about five years.17,18
- Race. CRC incidence and mortality are greatest among African Americans, with the highest incidence rates observed in black men. Per 100,000, rates are 62.3 for black men vs. 49.6 for white men; 47.5 for black women vs. 37.2 for white women.19 African Americans also develop CRC at younger ages than whites.20 The median diagnosis age among whites is 70 years, compared to 64 years among African Americans.21
- Type II Diabetes Mellitus. A meta-analysis of 15 studies including 2.6 million participants found that diabetes was associated with a 30 percent increased CRC risk.22 A more recent review reported similar results by anatomical subsite: 38 percent elevated risk for colon cancer and 20 percent for rectal cancer, although the association between diabetes and rectal cancer was limited to men.23
- Family History. CRC risk increases by 200-300 percent above expected population risk for first-degree relatives of affected family members.24,25 The increased risk associated with having any affected relative is 75 percent.24 Even more distant familial relations (second or third degree) may also be associated with modest increased risks.26,27 Diagnosis before age 50 in any affected relative and multiplicity of affected family members confers even greater CRC risk.24 The importance of family history may not be limited to a CRC history, as family history of adenomas is reported to increase CRC risk by 200 percent.25
- Hereditary CRC Syndromes. Individuals in families affected by familial polyp and cancer syndromes (hereditary nonpolyposis colorectal cancer or Lynch syndrome, familial adenomatous polyposis [FAP], MYH-associated polyposis [MAP], etc.) are at even higher risk for CRC than individuals with a family history of adenoma or CRC. For example, people with FAP-associated mutations have a 90 percent absolute risk of developing CRC by age 45 and people with mutations associated with Lynch syndrome have a 40 to 80 percent absolute risk of CRC by age 75.^28^

## Etiology and Natural History

Colorectal tumors consist of a variety of lesions that can be broadly classified into three groups: 1) non-neoplastic polyps, 2) neoplastic polyps, and 3) cancers.28 Non-neoplastic lesions such as hyperplastic polyps are generally viewed as not having malignant potential; however increasing evidence suggests that a subset of hyperplastic polyps—sessile serrated polyps—may be neoplastic and confer increased risk.29 30 The neoplastic group comprises adenomatous polyps (adenomas), which are considered cancer precursors. Larger size, villous features, and a higher degree of dysplasia characterize adenomas with greater malignant potential.28,31

CRC is characterized by genomic instability and CRC development is a multistep process involving genetic mutations or epigenetic changes that activate oncogenes or inactivate tumor suppressor genes or mutator genes. The genetic changes that occur and the order in which they occur define various carcinogenesis pathways.32,33 Below we describe the pathways for sporadic and hereditary cancers.

### Sporadic Cancers

#### Adenoma-Carcinoma Pathway

Most sporadic CRCs are believed to follow the adenoma-carcinoma histological carcinogenesis sequence, which is a common succession of changes in tumor suppressor genes and oncogenes. Progression is estimated to take 10 to 40 years, but most adenomas do not progress to cancer.34 Most adenomas are polypoid (protruding). Flat and depressed lesions were first characterized in 1985^35^ and whether these adenomas represent a separate carcinogenesis pathway or have greater malignant potential remains unclear.36 Nonetheless, they are being researched since they may be more easily missed by screening. Specific, ordered steps in the adenoma-carcinoma pathway are:

1. Dysplasia develops in a single crypt;
2. Single crypts develop into clusters that form adenomas;
3. Adenoma architecture changes from tubular to tubulovillous to villous with an increase in size;
4. Adenoma cells demonstrate progressively more severe atypia;
5. Adenocarcinoma appears;
6. Local invasion and metastasis.

#### Serrated Pathway

This is a more recently identified and less well-understood histological sequence associated with different genetic and epigenetic changes.37,38 This pathway describes the progression of serrated polyps with malignant potential, including both traditional serrated adenomas and sessile serrated adenomas, to CRC. Serrated lesions are characterized by a sawtooth-like infolding of the crypt epithelium and a predisposition to high levels of DNA methylation as the lesions progress.37

### Hereditary Cancers

Sporadic cancers arise from the stepwise accumulation of multiple somatic mutations. The common inherited CRC syndromes result from specific, single germline mutations. The syndromes include Lynch syndrome, caused by inherited mutations in mismatch repair genes (predominantly MLH1 and MSH2); FAP, caused by inherited mutations in the APC gene; and MAP, caused by biallelic mutations in the MUTYH gene.39,40 Mutations in STK11 cause Peutz-Jeghers syndrome, whereas mutations in SMAD4 or BMPR1A cause juvenile polyposis syndrome.40 MAP is currently the only known autosomal recessive hereditary CRC syndrome; all others are characterized by autosomal dominant inheritance.41

In contrast to the known mechanisms underlying sporadic cancers (75 percent of all CRCs) and the hereditary syndromes (5 to 6 percent of CRCs), little is known about familial CRCs without an identifiable inherited syndrome. Undiscovered genes acting singly or in concert with nongenetic factors likely contribute to the increased risk of cancer in individuals in these families.41

## Risk Factors

The epidemiology and risk factors for CRC have been well characterized. Nonmodifiable risk factors have been described for subpopulations of individuals who have increased CRC risk. Modifiable risk factors that may present opportunities for primary prevention of CRC include:42

- Smoking. Many observational studies report an increased risk associated with long-term cigarette smoking,43-46 and smoking may be responsible for 20 percent of CRCs in the United States.47
- Obesity. Increased body mass, regardless of the measure of adiposity (body mass index [BMI], waist circumference, waist-to-hip ratio), is associated with an increased CRC risk.48-51
- Alcohol Consumption. After adjustment for smoking and other known risk factors, several large prospective studies found that regular alcohol consumption is associated with increased CRC risk.52-54
- Physical Activity. Many studies suggest an inverse dose-response relationship between physical activity and CRC risk.55-57

## Interventions to Prevent Colorectal Cancer

Opportunities for primary prevention of CRC include the screening, lifestyle changes, and chemoprevention strategies described below.

- Screening. Since most CRCs are thought to arise over a long period from an identifiable precursor adenomatous polyp or adenoma,34 procedures such as endoscopy or computed tomography colonography can identify these CRC precursors and aid in their removal, preventing these lesions from developing into invasive carcinoma.58 A number of national organizations have developed clinical guidelines for these screening tests,59-62 with the USPSTF recommending colonoscopy every 10 years beginning at age 50 for average-risk individuals, sigmoidoscopy every 5 years.60 Annual fecal occult blood testing is also a recommended strategy for detecting CRC and may also lead to reduced incidence.
- Lifestyle Changes. Reducing or eliminating risk factors such as smoking, regular alcohol intake, obesity, and physical inactivity may prevent a substantial proportion of CRCs.
- Chemoprevention.
  a. Aspirin. Some evidence suggests an association between regular aspirin use and reduced risk of adenomatous polyps and CRC.3 In a Health Technology Assessment report,63 a pooled analysis of four studies of low-dose aspirin (100 to 325 mg every other day) showed no effect on CRC over the first 10 years of followup. In contrast, in the same report, an analysis of two, smaller studies of 300 to 1,200 mg/day of aspirin showed a 26 percent reduction in CRC incidence over a 23-year followup period. Aspirin has not been recommended for CRC prophylaxis in average-risk individuals because of the harms associated with long-term aspirin use (such as gastrointestinal bleeding) combined with limited evidence of benefit.
  b. Nonaspirin NSAIDs. Data suggest nonaspirin NSAIDs may reduce the risk of adenomas, but their link to ulcers, gastrointestinal bleeding, and adverse cardiovascular outcomes poses concerns. COX-2 inhibitors appear to reduce the risk of adenomas,3 but the risk of serious cardiovascular events64,65 including myocardial infarction does not support their prophylactic use. Ibuprofen and naproxen are the only nonaspirin NSAIDs currently available over the counter in the United States. NSAIDs available by prescription in the U.S. are celecoxib, diclofenac, diflunisal, etodolac, fenoprofen, flurbiprofen, indomethacin, ketorolac, meclofenamate, mefenamic acid, meloxicam, nabumetone, oxaprozin, piroxicam, salsalate, sulindac, and tolmetin. All these NSAIDs, including those available over the counter, have black box warnings about long-term use and cardiovascular disease (CVD) risk.
  c. Calcium and Vitamin D. Data suggest an inverse association between calcium intake and risk of CRC.66,67 The protective effect of calcium dietary supplementation to reduce CRC risk appears to extend well beyond the supplementation period.68 Two randomized controlled trials (RCTs), the Calcium Polyp Prevention Study69 and the European Cancer Prevention Organisation Intervention Study,70 showed that daily supplementation with 1,200 to 2,000 mg calcium was associated with a reduced risk of adenoma recurrence. The American College of Gastroenterology recommends calcium supplementation to decrease the risk of adenoma recurrence.71 Data from several observational studies indicate that vitamin D status is inversely associated with CRC risk.72 In contrast, the Women's Health Initiative (WHI) did not find that vitamin D supplementation reduced CRC incidence;73 however, the relatively low supplementation dose in this trial and the short duration of followup may account for the negative findings.74 In a recent recommendation statement,75 the USPSTF found inadequate evidence to determine the effect of vitamin D supplementation on cancer risk.

## Molecular Mechanism of Action for Aspirin in Colorectal Cancer Prevention

Evidence from animal models,76-78 observational studies79-82 and RCTs63,81,83-86 suggests that aspirin may inhibit CRC development and related mortality. Some potential mechanisms for these effects have been proposed and broadly classified as COX-dependent and COX-independent, but none is well understood. COX-2 pathways have been the predominant focus for the antineoplastic effects of aspirin, but increasing evidence also supports the role of COX-1 and non-COX pathways.87,88 COX-dependent mechanisms are currently better understood. The cyclooxygenases COX-1 and COX-2 catalyze the production of a class of tissue-specific signaling lipids89 including prostaglandins. Prostaglandins promote inflammation, which can create a cellular environment favorable to tumorigenesis.89-91 Aspirin, in contrast to the reversible action of nonaspirin NSAIDs, is believed to irreversibly inactivate COX enzymes to suppress production of prostaglandins.89,92 COX-2 increases apoptosis, decreases cellular proliferation, and increases angiogenesis; thus, its suppression should have the opposite effects. Direct COX-2 inhibition is postulated to be the predominant pathway for aspirin's effects on CRC neoplasia.87,93,94 CRCs have been observed to overexpress COX-2^95,96^ and a prospective study of two large cohorts found that the benefit of aspirin use for CRC reduction was limited almost entirely to COX-2-positive CRCs,97 supporting a COX-2 pathway. At low doses, aspirin is believed to selectively inhibit platelet activation through COX-1 suppression, with little effect on the COX-2 pathways.87,88 However, it has been hypothesized that suppression of COX-1 may also have a sequential effect on COX-2 suppression.87

COX-independent mechanisms have been hypothesized,87,88 but have been the focus of far fewer studies than the COX pathways. Different mechanisms and pathways may play a role at different points in the disease process, from blocking adenoma development to inhibiting progression87 at later stages in carcinogenesis. Primary targets of investigation include inhibition of IκB kinase (IKK) β, prevention of NF-κB activation, extracellular-signal-regulated kinase (ERK) inhibition, mitochondrial functions, and inhibition of the Wnt/ β-catenin pathway.88

## Current Clinical Practice and Recommendations of Other Groups

Currently, no health or professional organizations recommend aspirin for the primary prevention of CRC in average-risk adults. The American Cancer Society,98 the American Medical Association (AMA),99 and the American College of Physicians (ACP)100 explicitly recommend against the use of aspirin for chemoprevention, with the AMA and ACP citing the 2007 USPSTF guidelines3 as the basis for their recommendation. The American College of Gastroenterology,101 the National Institute for Health and Care Excellence,102 and the National Institutes of Health28 have no chemoprevention recommendations for CRC. However, some organizations acknowledge possible roles for aspirin in both primary and secondary prevention in high-risk adults. The American Gastroenterological Association recommends that aspirin be considered for patients with a personal history of CRC,103,104 advanced colorectal adenoma, or a strong family history, but not for people with a history of peptic ulcer disease or hemorrhagic stroke. The National Comprehensive Cancer Network105 limits their recommendation for aspirin use to primary prevention in adults with a personal history of classical FAP or attenuated FAP to reduce polyp burden as an adjunct to endoscopic surveillance.

## Previous USPSTF Recommendation

In 2007, the USPSTF concluded that the harms outweigh the benefits of aspirin use for the prevention of CRC (D recommendation)3 based on the following evidence.81

### Benefits of Aspirin Use

- Fair-to-good evidence that aspirin taken in higher doses for longer periods reduces the incidence of adenomatous polyps.
- Good evidence that low-dose aspirin does not lead to a reduction in the incidence of CRC.
- Fair evidence that aspirin used in doses higher than those recommended for prevention of CVD may be associated with a reduction in the incidence of CRC.
- Fair evidence that aspirin used over longer periods may be associated with a reduction in the incidence of CRC.
- Poor-quality evidence that aspirin use leads to a reduction in CRC-associated mortality.

### Harms of Aspirin Use

- Good evidence that aspirin increases the incidence of gastrointestinal bleeding in a dose-related manner and fair evidence that aspirin increases the incidence of hemorrhagic stroke.
- Overall, good evidence of at least moderate harms associated with aspirin.