# Characteristics of Included Studies

Appendix D Table 1 Included Randomized, Controlled Trials and Meta-Analyses of Aspirin in the General Population

Study Author Quality | Number of Participants | Year Begun | Population, Mean Age at Study Entry (SD), % Women | Aspirin Dose and Frequency vs. Comparison Group | Treatment Length Median (Range) | Benefits Reported (Followup Length)
WHS Cook, 2005^112^ Cook, 2013^113^ Good quality | N=39,876 IG:19,934 CG:19,942 | 1992 | U.S. women health care professionals, Age: 54.6 (7) years % women: 100% | 100 mg qod vs. Placebo (2 × 2 factorial with vitamin E) | 10.1 (NR) years | All-cause mortality (Median 17.5 years) CRC mortality (Median: 10.1 years) CRC incidence (Median: 17.5 years)
PHS Stürmer, 1998^135^ Good quality | N=22,071 IG: 11,037 CG: 11,034 | 1982 | US male physicians Age: 53.2 (9.5) years % women: 0% | 325 mg qod vs. Placebo (2 × 2 factorial with beta carotene) | 5.0^††^ (3.8 to 6.4) years | All-cause mortality CRC incidence (Mean: 12 years)
BMD Peto, 1988^124^ Fair quality | N=5,139 IG: 3,429 CG: 1,710 | 1978 | British male doctors Age: 61.6 (7.0) years^¶^ % women: 0% | 500 mg/day vs. no aspirin (Could receive 300 mg enteric coated if requested) | 6.0 (5.0 to 6.0) years^¶^ | All-cause mortality^‡^ CRC mortality^*,‡^ CRC incidence^*,†^ (See Rothwell/Flossman for follow-up)
UK-TIA UK-TIA Study Group, 1991^126^ Good quality | N=2,449^§§^ IG: 300 mg: 811 IG: 1200mg: 821 CG: 817 | 1979 | British men and women with recent TIA or minor ischemic stroke Age: 60.3 (9.0) years^¶^ % women: 27.0%^‡‡^ | 300 mg/day vs. 1,200 mg/day vs. Placebo | 4.4 (1.0 to 7.1) years^¶^ | All-cause mortality^‡^ CRC mortality^*,‡^ CRC incidence^*,†^ (See Rothwell/Flossman for follow-up)
TPT Medical Research Council's General Practice Research Framework, 1998^108^ Good quality | N=5,085 IG: 2,545 CG: 2,540 | 1989 | British men at high risk of IHD Age: 57.5 (6.7) years^¶^ % women: 0% | 75 mg/day vs. Placebo (2 × 2 factorial with warfarin) | 6.9 (4.3 to 8.6) years^¶^ | All-cause mortality^‡^ CRC mortality^*,‡^ CRC incidence^*^ (See Rothwell for follow-up)
SALT The SALT Collaborative Group, 1991^127^ Good quality | N=1,363^‖^ IG: 678 CG: 685 | 1984 | Sweden men and women with recent history of TIA, minor stroke, or retinal artery occlusion Age: 66.9 (7.1) years^**^ % women: 34.2%^‡‡^ | 75 mg/day vs. Placebo | 2.7 (1.0 to 5.3) years^**^ | All-cause mortality CRC mortality^*^ CRC incidence^*^ (See Rothwell for follow-up)
ETDRS ETDRS Investigators, 1992^128^ Good quality | N=3,711 IG: 1,856 CG: 1,855 | 1980 | U.S. men and women with diabetes with certain categories of diabetic retinopathy Age: 51 (NR) years^¶^ % women: 43.5%^‡‡^ | 650 mg/day vs. Placebo | 5.0 (4.0 to 9.0) years^¶^ | All-cause mortality^‡^ (See Rothwell for follow-up)
SAPAT Juul-Moller, 1992^130^ Fair quality | N=2,035 IG:1,009 CG: 1,026 | 1985 | Swedish men and women with chronic stable angina pectoris without prior MI Age: 67 (8) years^¶^ % women: 48%^‡‡^ | 75 mg/day vs. Placebo | 4.2 (1.9 to 6.3) years^¶^ | All-cause mortality^‡^ (See Rothwell for follow-up)
JPAD Ogawa, 2008^131^ Fair quality | N=2,539 IG: 1,262 CG: 1,277 | 2002 | Japanese men and women with type 2 diabetes without history of atherosclerotic disease Age: 64.5 (10.0) years^¶^ % women: 45.4%^‡‡^ | 81 mg/day or 100 mg/day^§^ vs. no recommendation to take aspirin | 4.4 (3.0 to 5.4) years^¶^ | All-cause mortality^‡^ CRC mortality^*^ (See Rothwell for follow-up)
POPADAD Belch, 2008^132^ Fair quality | N=1,276 IG: 638 CG: 638 | 1997 | Scottish men and women with diabetes and asymptomatic peripheral arterial disease Age: 60.3 (10.0) years^¶^ % women: 55.9%^‡‡^ | 100 mg/day vs. Placebo (2 × 2 factorial with antioxidant) | 6.7 (4.5 to 8.6) years^¶^ | All-cause mortality^‡^ CRC mortality^‡^ (See Rothwell for follow-up)
AAA Fowkes, 2010^133^ Fair quality | N=3,350 IG: 1,675 CG: 1,675 | 1998 | Scottish men and women with no history of vascular disease with low ankle brachial index Age: 62.0 (6.6) years^¶^ % women: 71.5%^‡‡^ | 100 mg/day vs. Placebo | 8.2 (6.7 to 10.5) years^¶^ | All-cause mortality^‡^ CRC mortality^*,‡^ (See Rothwell for follow-up)
Flossman, 2007^111^ Good quality | N=7,588^‡‡^ IG: 5,061 CG: 2,527 | 1978 | Participants in BMD and UK-TIA Age: 61.2 (NR) years^‡‡^ % women: 8.7%^‡‡^ | 300 mg/day- 1,200 mg/day vs. Placebo/control | 5.1 (1.0 to 7.1^‡‡^) years | CRC incidence (Median: 23 years)
Rothwell, 2010^85^ Fair quality (incidence) Good quality (mortality) | N=14,033 IG: 8,282 CG: 5,751 | 1978 | Participants in BMD, UK-TIA, TPT, SALT Age: 60.4 (NR) years^‡‡^ % women: 8.0%^‡‡^ | 75 mg/day- 1,200 mg/day vs. Placebo/control | 5.8 (1.0 to 8.5) years | CRC mortality CRC incidence (median: 18.3 years)
Rothwell, 2011^83^ Good quality | N=25,570 IG: 14,035 CG: 11,535 | 1978 | Participants in BMD, UK-TIA, TPT, ETDRS, SAPAT, JPAD, POPADAD, AAA (mean scheduled duration ≥ 4 years) Age: 59.8 (NR) years^‡‡^ % women: 29.4%^‡‡^ | 75 mg/day- 1,200 mg/day vs. Placebo/control | NR, see individual trials | All-cause mortality: all studies (in-trial followup) CRC mortality: BMD, UK-TIA, TPT, JPAD, POPADAD, AAA; (N=19,824^‡‡^) (In-trial followup) TPT, BMD, UK-TIA: (N=12,659 total, N=10,502 with scheduled treatment duration ≥5 years) (Up to 20 years followup)

* Included in Rothwell 2010^85^

† Included in Flossman 2007^111^

‡ Included in Rothwell 2011^83^

§ Dose not randomized

‖ After randomization, three patients were deemed ineligible. Number analyzed was IG: 676 and CG: 684

¶ As reported in Rothwell 2011^83^

** As reported in Rothwell 2010^85^

†† Mean

‡‡ Calculated

§§ Rothwell 2011^83^ analyzed N=2,435, excluding three people randomized in error and 14 with an intracranial tumor diagnosed shortly after randomization. N=806 in 300 mg/day group, N=815 in 1,200 mg/day group; N=814 in placebo group

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; BMD = British Medical Doctors trial; CG = control group; CRC = colorectal cancer; ETDRS = Early Treatment Diabetic Retinopathy Study; GI = gastrointestinal; IG = intervention group; IHD = ischemic heart disease; JPAD = Japanese Primary Prevention of Atherosclerosis With Aspirin for Diabetes; mg = milligram; MI = myocardial infarction; NR = not reported; PHS = Physicians' Health Study; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; qod = every other day; SALT = Swedish Aspirin Low-dose Trial; SAPAT = Swedish Angina Pectoris Aspirin Trial; SD = standard deviation; TIA = transient ischemic attack; TPT = Thrombosis Prevention Trial; UK-TIA = UK Transient Ischaemic Attack trial; WHS = Women's Health Study

Appendix D Table 2 Included Randomized, Controlled Trials of Aspirin in Persons With a Prior Adenoma

Study Author Quality | Number of Participants | Year Begun | Population Mean Age at Study Entry (SD) % Women | Aspirin Dose and Frequency | Treatment Length Median (Range) | Benefits Reported (Followup Length)
APACC Benamouzig, 2012^123,141-143^ Fair quality | N=272^†^ IG 160 mg: 73 IG 300 mg: 67 CG: 132 | 1996 | French men and women who had a colonoscopy with adequate bowel prep and visualized cecum, ≥3 adenomas irrespective of size or ≥1 adenoma ≥6 mm, and removal of all polyps Age: 58 (10) years % women: 30% | 160 mg/day vs. 300 mg/day vs. Placebo | 44.4 (11.9 to 47.6) months^§^ | All-cause mortality, Adenoma incidence, Advanced adenoma incidence, Adenoma number, Adenoma size (Median: 47.2, IQR 14.8 to 48.4 months, N=272)^§^
ukCAP Logan, 2008^129,137,138^ Good quality | N=945^‡^ IG: 472 CG: 467 | 1997 | British men and women with either a colorectal adenoma ≥0.5 cm removed in the 6 months before recruitment (or earlier if they also had ≥1 adenoma removed in the 6 months before randomization). All must have had a clean colon. Age: 57.8 (NR) years % women: 43.1%^*^ | 300 mg/day vs. Placebo (2 × 2 factorial with folate) | 34.9 (13.5 to 38.9) months^§^ | All-cause mortality, CRC incidence, Adenoma incidence, Advanced neoplasia incidence, Adenoma number (Median: 37.5, IQR 33.3 to 42.3 months, N=939)^§^
AFPP Baron, 2003^136^ Good quality | N=1,121 IG 81 mg: 377 IG 325 mg: 372 CG: 372 | 1994 | U.S. and Canadian men and women with a history of adenoma, with confirmation of no remaining polyps in 3 months before study Age: 57.5 (NR) years^*^ % women: 36.5%^*^ | 81 mg/day vs. 325 mg/day vs. Placebo (3 × 2 factorial with folic acid) | 31.7 (30.2 to 33.1) months^§^ | All-cause mortality, CRC incidence, Adenoma incidence, Advanced lesion incidence, Tubular adenoma incidence (Median: 32.2, IQR 31.1 to 33.6 months, N=1,121)^§^

* Calculated

† Number analyzed restricted to persons receiving follow-up colonoscopy: IG 160 mg=55; IG 300 mg= 47, CG=82

‡ Total commencing medication was N=939 since six people were enrolled in error. Number analyzed for CRC and adenoma incidence restricted to persons receiving follow-up colonoscopy: IG=434; CG=419

§ Reported by Cole 2009^123^

Abbreviations: AFPP = Aspirin/Folate Polyp Prevention study; APACC = Association pour la Prevention par l'Aspirine du Cancer Colorectal; CG = control group; cm = centimeter; CRC = colorectal cancer; IG = intervention group; IQR = interquartile range; NR = not reported; mg = milligram; mm = millimeter; SD = standard deviation; ukCAP = United Kingdom Colorectal Adenoma Prevention trial

Appendix D Table 3 Characteristics of Included Cohort Studies

Study Author Quality | Number of Participants | Year Begun | Population Mean Age at Study Entry (SD) % Women | Relevant Exposure Categories by Key Question
NHS Chan 2005^146^ Fair quality | Overall: 121,701 Analysis: 82,911 | 1980 | U.S. women registered nurses Age: By baseline number of 325 mg aspirin tablets per week^†^: 0 tables/week: 46 (40 to 53) 0.5 to 1.5 tablets/week: 47 (41 to 53) 2 to 5 tablets/week: 45 (40 to 52) 6 to 14 tablets/week: 47 (41 to 53) more than 14 tablets/week: 49 (43 to 54) % women: 100% | KQ3, KQ4, KQ5: Frequency: Number of 325 mg aspirin tablets per week; KQ4: Recency: Number of 325 mg aspirin tablets/week in previous 10 years; Number of 325 mg aspirin tablets/week in past ≥10 years
HPFS Chan 2008^152^ Fair quality | Overall: 51,529 Analysis: 47,363 | 1986 | U.S. men health professionals Age: 54 (NR) years^*^ % women: 0% | KQ4: Frequency: Number of 325 mg aspirin tablets per week
Swedish Mammography Cohort and the Cohort of Swedish Men Larsson and colleagues 2006^153^ Fair quality | Overall: 104,880^*^ Analysis: 74,250 | 1997 | Members of two Swedish cohorts Age: 60.6 (NR) years^*^ % women: 43.2%^*^ | KQ4: Frequency: Number of aspirin tablets per week (assumed 500 mg tablet)
Danish Diet, Cancer, and Health Study Friis 2009^160^ Fair quality | Overall: 57,053 Analysis: 51,053 | 1995 | Danish men and women aged 50 to 64 years Age: 56.2 (51.2 to 63.2) years^‡^ % women: 52.3% | KQ4: ≥1 pill per day (self-report); prescription use Dose: prescription 75 mg or 150 mg
VITAL Brasky 2012^161,162^ and White 2004^162^ Fair quality | Overall: 77,719 Analysis: 64,847 | 2000 | Washington State men and women aged 50 to 76 years Age: 61 (NR) years^†,§^ % women: 51%^*^ | KQ4: Frequency/duration Low use (<4 days/week or <4 years); High use (≥4 days/week and ≥4 years); Dose: Low-dose; Regular-strength
WHI Observational Cohort Allison 2006^164^ and The Women's Health Initiative Study Group 1988^163^ Good quality | Overall: 93,676 Analysis: 91,574 | 1993 | Postmenopausal women aged 50 to 79 years who were screened and not eligible or unwilling to participate in the WHI RCT Age: 63.5 (NR) years^*^ % women: 100% | KQ4: Dose: Daily: 0 mg, less than 165 mg, 165 to less than 330 mg, 330 to 494 mg, ≥495 mg; Daily: 0 mg, less than 325 mg, ≥325 mg Duration: Annual increments: 0 years, 0 to 0.9 years, 1 to 1.9 years, 2 to 2.9 years, 3 to 3.9 years, 4 to 4.9 years, ≥5 years Longer increments: 0 years, 1 to 5 years, 5.1 to 10 years, 10.1 to ≤20 years, more than 20 years
CPSII Nutrition Cohort Jacobs 2007,^156^ Calle 2002,^154^ and Jacobs 2012^158^ Fair quality CPSII Thun 1991^170^ Quality not assessed independently from CPSII Nutrition Cohort | Overall: 184,194∥ KQ3 Analysis: 100,139 KQ4 Analysis: 146,113 Overall: 1,185,239 Analysis: 662,424 | 1992 1982 | Subset of the CPSII study who responded to a followup questionnaire in 1992 Age: 63 (NR) years^†^ Adults (≥30 years) from households with at least one member 45+ years in all 50 states, Washington D.C., and Puerto Rico Age: 57 (NR) years % women: 57%^154^ | KQ3: Recency/duration Current daily use less than 5 years Current daily use ≥5 years Past or occasional use KQ4: Duration 325 mg/day current daily use less than 5 years 325 mg/day current daily use ≥5 years KQ3: Use ≥16 times per month for at least 1 year

* Calculated

† Median (interquartile range)

‡ Median (10^th^-90^th^ percentile)

§ Reported on cohort in White 2004 (N=76,072)

∥ Total calculated from Jacobs and colleagues 2007^156^ is 184,190. Total reported in Calle and colleagues 2002^154^ is 184,194

Abbreviations: CPSII = Cancer Prevention Study II; KQ = key question; HPFS = Health Professionals Follow-up Study; mg = milligram; NHS = Nurses' Health Study; NR = not reported; RCT = randomized controlled trial; SD = standard deviation; VITAL = VITamins And Lifestyle study; WHI = Women's Health Initiative

Appendix D Table 4 Effect of Aspirin on Colorectal Cancer Incidence in Randomized, Controlled Trials, Overall and by Proximal vs. Distal Anatomic Region of Colon

Study | All Colon | | Proximal Colon | | Distal Colon
Study | Events/N (%) | Relative Risk Estimate (95% CI) | Events/N (%) | Relative Risk Estimate (95% CI) | Events/N (%) | Relative Risk Estimate (95% CI)
WHS113 | IG: 155/19,934 (0.8%) | HR, 0.79 (0.64 to 0.97) | IG: 88/19,934 (0.4%) | HR, 0.73 (0.55 to 0.95) | IG: 59/19,934 (0.3%) | HR, 0.87 (0.62 to 1.24)
WHS113 | CG: 195/19,942 (1.0%) | HR, 0.79 (0.64 to 0.97) | CG: 120/19,942 (0.6%)^*^ | HR, 0.73 (0.55 to 0.95) | CG: 67/19,942 (0.3%) | HR, 0.87 (0.62 to 1.24)
BMD, UK-TIA, TPT, SALT85,† | IG: 278/14,033 (2.0%)^*^ | HR, 0.76 (0.60 to 0.96) | IG: 69/14,033 (0.5%)^*^ | HR, 0.45 (0.28 to 0.74) | IG: 100/14,033 (0.7%)^*^ | HR, 1.10 (0.73 to 1.64)
BMD, UK-TIA, TPT, SALT85,† | CG: 229/10,533 (2.2%)^*,‡^ | HR, 0.75 (0.58 to 0.97)^‡^ | CG: 61/10,533 (0.6%)^*,‡^ | HR, 0.35 (0.20 to 0.63)^‡^ | CG: 75/10,533 (0.7%)^*,‡^ | HR, 1.14 (0.69 to 1.86)^‡^

* Calculated

† All doses (75-1200 mg) vs. control on long-term risk

‡ Limited to patients with a scheduled treatment duration ≥5 years

Abbreviations: BMD = British Medical Doctors trial; IG = intervention group; CG = control group; CI = confidence interval; HR = hazard ratio; SALT = Swedish Aspirin Low-dose Trial; TPT = Thrombosis Prevention Trial; UK-TIA = UK Transient Ischaemic Attack trial; WHS = Women's Health Study

Appendix D Table 5 Multivariable Adjusted Relative Risk Estimates for Association Between Aspirin Use and Colorectal Cancer Incidence in Cohort Studies, by Dose and Frequency

Aspirin Use | NHS146 | HPFS152 | Swedish Mammography Cohort and the Cohort of Swedish Men153
Aspirin Use | Relative Risk (95% CI) | Relative Risk (95% CI) | Aspirin Use | Relative Risk (95% CI)
Nonuse | Referent | Referent | Nonuse | Referent
0.5 to 1.5 tablets/week (325 mg) | 1.10 (0.92 to 1.31) | 0.94 (0.75 to 1.18) | 1 tablet/week (500 mg) | 0.83 (0.61 to 1.14)
2 to 5 tablets/week (325 mg) | 0.89 (0.73 to 1.10) | 0.80 (0.63 to 1.01) | 2 to 6 tablets/week (500 mg) | 0.88 (0.68 to 1.16)
6 to 14 tablets/week (325 mg) | 0.78 (0.62 to 0.97) | 0.72 (0.56 to 0.92) | more than 6 tablets/week (500 mg) | 0.77 (0.59 to 0.99)
More than 14 tablets/week (325 mg) | 0.68 (0.49to 0.95) | 0.30 (0.11to 0.81) | more than 6 tablets/week (500 mg) | 0.77 (0.59 to 0.99)
| p-trend<0.001 | p-trend=0.004 | | p-trend=0.04

Abbreviations: CI = confidence interval; HPFS = Health Professionals Follow-up Study; mg = milligrams; NHS = Nurses' Health Study.

Appendix D Table 6 Adenoma Incidence at Different Followup Timepoints in the APACC Study

Treatment Group | 1 Year141 | 4 Year142 | Last Colonoscopy (1 or 4 Years)142
Treatment Group | Events/N (%) | Events/N (%) | Events/N (%)
160 mg/day | NR/66 | 15/55 (27%) | 32/68 (47%)
300 mg/day | NR/60 | 27/47 (57%) | 33/60 (55%)
Both aspirin doses | 38/126 (30.2%) | 42/102 (41%) | 65/128 (51%)
Placebo | 46/112 (41.1%) | 33/83 (40%) | 62/116 (53%)

Abbreviations: mg = milligrams; NR = not reported.

Appendix D Table 7 Adenoma Incidence by Interval After Randomization in Randomized, Controlled Trials of Persons With a Prior Adenoma123

Study | Treatment Group | 0 to 12 Months | 12 to 24 Months | 24 to 38 Months | ≥38 Months
Study | Treatment Group | Events/N (%) | Events/N (%) | Events/N (%) | Events/N (%)
APACC | 160 or 300 mg/day | 19/67 (28.4%) | 20/58 (34.5%) | NR | 37/94 (39.4%)
APACC | Placebo | 30/66 (45.5%) | 18/49 (36.7%) | NR | 31/81 (38.3%)
APACC | Relative risk (95% CI) | 0.62 (0.39 to 0.99) | 0.94 (0.56 to 1.56) | NR | 1.03 (0.71 to 1.49)
ukCAP | 300 mg/day | 17/36 (47.2%) | 9/35 (25.7%) | 38/191 (19.9%) | 38/191 (19.9%)
ukCAP | Placebo | 30/42 (71.4%) | 16/33 (48.5%) | 39/152 (25.7%) | 43/209 (20.6%)
ukCAP | Relative risk (95% CI) | 0.66 (0.45 to 0.98) | 0.53 (0.27 to 1.03) | 0.78 (0.52 to 1.15) | 0.97 (0.65 to 1.43)
AFPP | 81 or 325 mg/day | NR | 15/36 (41.7%) | 271/669 (40.5%) | 20/42 (47.6%)
AFPP | Placebo | NR | 3/15 (20.0%) | 158/338 (46.7%) | 11/23 (47.8%)
AFPP | Relative risk (95% CI) | NR | 2.08 (0.71 to 6.16) | 0.87 (0.75 to 1.00) | 1.00 (0.59 to 1.69)

Abbreviations: AFPP = Aspirin/Folate Polyp Prevention Study; APACC = Association pour la Prevention par l'Aspirine du Cancer Colorectal; CI = confidence interval; mg = milligrams; NR = not reported; ukCAP = United Kingdom Colorectal Adenoma Prevention trial

Appendix D Table 8 Persistence and Adherence to Aspirin for Prevention of Colorectal Cancer and Cardiovascular Disease, by Prevention Focus

Population | Definition | Followup Timepoint
Population | Definition | <1 Year | 1 Year | 2 Years | 3 to 4 Years | 5 Years | >5 Years
Primary prevention of colorectal cancer
APACC129,134-136 | Compliance: count of returned sachets | 87%^†^ (4 mo) | | | 88% (4 yrs)^§^
ukCAP129,137,138 | Compliance: percent taking ≥95% of medication among those who had a followup colonoscopy | | | | 75%^†^ (3 yrs)
AFPP123,136-140 | Compliance: percent taking medication 6 to 7 days/week | | 81 mg: 95%^†^ 325 mg: 95%^†^ | 81 mg: 91%^†^ 325mg: 91%^†^
AFPP123,136-140 | Compliance: percent taking “virtually all” medication | | 94%
Primary prevention of cardiovascular disease
PACE177 | Tablet count | | 87%
BMD124 | Persistence: percent who did not stop using | | 81%^*,†^ | | | | 61%^*,†^ (6 yrs)
ETDRS128,129 | Persistence: still taking study medication | | 92%^*,†^ | | | 70%^†^
AAA133 | Persistence: did not stop taking | 85%^†^ (6 mo)
POPADAD132 | Persistence: did not stop tablets | | 86%^*^ | | | 50%^*^
JPAD131 | Persistence: did not stop taking | | | | 90%^†^ (4 yrs)
WHS^‡,112,176^ | Compliance: taking at least two-thirds of the study aspirin or aspirin placebo | | 88% | | | 76% | 67% (10 yrs)
ASPREE180 | Persistence: still taking study medication | | 80%
DAMAD179 | Adherence: mean rate of aspirin consumption based on pill count in subgroup at 1 center | | | | 82%^†^ (3 yrs)
PPP175 | Persistence: did not stop taking study medication | | 81%^†^ | | 81%^†^ (yr 3.6)
PHS^‡,120^ | Persistence: taking both of the study medications | 91%^†^ (6 mo) | | | | 83% (4.75 yrs)
TPT108 | Persistence: did not withdraw from trial treatment | | 86%^*^ | | 71%^*^ (3 yrs) | 58%^*^
Secondary prevention of cardiovascular disease
UK-TIA125,126 | 4 mo persistence: percent who did not stop using. By 6 yr: Positive urine test, called “compliance” but likely to be persistence | 88%^*^ (4 mo) | | | | 75%^†^ (by 6 yrs)
SAPAT130 | Persistence: did not stop taking | | | | 64%^*,†^ (4 yrs)
SALT127 | Persistence: did not permanently discontinue | | | | 83%^*^ (31 mo)
HOT178 | “Compliance” measured by electronic cap timing | | 78%^†^
AMIS187 | Adherence: took an average of 1.6 capsules per day | | | | 89% (yr 3)
ASPIRE181 | Persistence: percent that did not discontinue | | 81%^*,†^ | 73%^*,†^ | 63%^*,†^ (yr 3) 57%^*,†^ (yr 4)
CDPA182 | Adherence: ≥80% study medication taken over entire study period | | | 81%^†^ (1.8 yrs)
ACBS183 | Adherence: fully complied | | | 85%
ESPS-2^189^ | Persistence: did not stop taking treatment | 84%^†^ (6 mo) | 84%^†^ | 82^†^%
EAFT186 | Persistence: did not withdraw from treatment among those still at risk | 86%^†^ (6 mo) | 80%^†^ | 71%^†^ | 66%^†^
PARIS188 | Adherence: total number of tablets possible | | | | 72%^†^ (3.4 yrs)
JAST185 | Adherence: took aspirin regularly | | | 78%^*,†^
SPAF184 | Adherence: more than 80% compliance by pill count during study (including interruptions) | | 88% (1.3 yrs)
Tayside Scotland (Registry dispensing study)190 | Adherence: percent with good adherence defined as ≥80% where adherence is number of days with supply/total days since prescription | | 58%^†^ | 56%^†^ | 54%^†^ (yr 3) 55%^†^ (yr 4) | 56%^†^ | 55%^†^ (6 yrs); 53%^†^ (7 yrs); 58%^†^ (8 yrs)

* Calculated

† Measures are for aspirin specifically; others are reported for the overall study population

‡ PHS and WHS targeted primary prevention of both cancer and cardiovascular disease

§ Among persons who completed the 4 year colonoscopy

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ACBS = Asymptomatic Cervical Bruit Study; AFPP = Aspirin/Folate Polyp Prevention study; AMIS = Aspirin Myocardial Infarction Study; APACC = Association pour la Prevention par l'Aspirine du Cancer Colorectal study; ASPIRE = Aspirin to Prevent Recurrent Venous Thromboembolism; ASPREE = ASPirin in Reducing Events in the Elderly; BMD = British Medical Doctors trial; CDPA = Coronary Drug Project Aspirin study; DAMAD = Males and females w/ diabetics and diabetic retinopathy; EAFT = European Atrial Fibrillation Trial; ESPS-2 = European Stroke Prevention Study 2; ETDRS = Early Treatment Diabetic Retinopathy Study; HOT = Hypertension Optimal Treatment study; JAST = Japan Atrial Fibrillation Stroke Trial; JPAD = Japanese Primary Prevention of Atherosclerosis With Aspirin for Diabetes; mg = milligrams; mo = month; PACE = Prevention with Low-dose Aspirin of Cardiovascular disease in the Elderly; PARIS = Persantine-Aspirin Reinfarction Study; PHS = Physicians' Health Study; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; PPP = Primary Prevention Project; SALT = Swedish Aspirin Low-dose Trial; SAPAT = Swedish Angina Pectoris Aspirin Trial; SPAF = Stroke Prevention in Atrial Fibrillation study; TPT = Thrombosis Prevention Trial; ukCAP = United Kingdom Colorectal Adenoma Prevention trial; UK-TIA = UK Transient Ischaemic Attack trial; WHS = Women's Health Study; yr(s) = year(s)