# Excluded Studies

Code | Reason for Exclusion
E1 | Trial results not yet reported
E2 | Wrong population
E3 | Wrong intervention or exposure
E3a | Exposure to ASA less than 12 months
E3b | No information on ASA dosage
E3c | No minimum ASA dose specified
E3d | Comparison group limited to ASA users or includes regular ASA users
E3f | ASA cannot be separated from other medications
E4 | No relevant outcomes
E5 | Wrong study design
E6 | Systematic review or meta-analysis with no primary data
E7 | Wrong setting
E8 | Non-English
E9 | Poor quality
E10 | Unable to locate

Abbreviations: AE = adverse events; ASA = acetylsalicylic acid; CRC = colorectal cancer; EPA = eicosapentaenoic acid; g = gram; mg = milligram; mm = millimeter; N

1 A comparison of two doses of aspirin (30 mg vs. 283 mg a day) in patients after a transient ischemic attack or minor ischemic stroke. The Dutch TIA Trial Study Group. N Engl J Med. 1991;325(18):1261-1266. KQ4E3d. [pmid: 1922220].
2 Use of aspirin and its effect on adenoma risk. Managed Care Interface. 2004;17(6):70-71. KQ5E5.
3 Algra AM, Rothwell PM. Effects of regular aspirin on long-term cancer incidence and metastasis: a systematic comparison of evidence from observational studies versus randomised trials. Lancet Oncology. 2012;13(5):518-527. KQ4E6. [pmid: 22440112].
4 Arber N. Do NSAIDs prevent colorectal cancer?. Canadian journal of gastroenterology. 2000;14(4):299-307. KQ4E5. [pmid: 10799083].
5 Arber N, Eagle CJ, et al. Celecoxib for the prevention of colorectal adenomatous polyps. New England Journal of Medicine. 2006;355(9):885-895. KQ5E3c, KQ4E3c. [pmid: 16943401].
6 Arber N, Spicak J, et al. Five-year analysis of the prevention of colorectal sporadic adenomatous polyps trial. American Journal of Gastroenterology. 2011;106(6):1135-1146. KQ5E3c, KQ7E3c. [pmid: 21503000].
7 Asano TK, McLeod RS. Nonsteroidal anti-inflammatory drugs and aspirin for the prevention of colorectal adenomas and cancer: a systematic review. Diseases of the Colon & Rectum. 2004;47(5):665-673. KQ4E6, KQ5E6, KQ7E6. [pmid: 15054679].
8 Baron JA, Sandler RS, et al. A randomized trial of rofecoxib for the chemoprevention of colorectal adenomas. Gastroenterology. 2006;131(6):1674-1682. KQ5E3c, KQ7E3f. [pmid: 17087947].
9 Barry ELR, Baron JA, et al. Ornithine decarboxylase polymorphism modification of response to aspirin treatment for colorectal adenoma prevention. Journal of the National Cancer Institute. 2006;20:1494-1500TN. NCT00272324/ClinicalTrials.gov. KQ5E3.
10 Barry EL, Mott LA, et al. Variants downstream of the ornithine decarboxylase gene influence risk of colorectal adenoma and aspirin chemoprevention. Cancer Prevention Research. 2011;4(12):2072-2082. KQ5E3. [pmid: 21930798].
11 Barry EL, Poole EM, et al. CYP2C9 variants increase risk of colorectal adenoma recurrence and modify associations with smoking but not aspirin treatment. Cancer Causes & Control. 2013;24(1):47-54. KQ5E3. [pmid: 23081681].
12 Barry EL, Sansbury LB, et al. Cyclooxygenase-2 polymorphisms, aspirin treatment, and risk for colorectal adenoma recurrence--data from a randomized clinical trial. Cancer Epidemiology, Biomarkers & Prevention. 2009;18(10):2726-2733. KQ5E3.
13 Bartolucci AA, Howard G. Meta-analysis of data from the six primary prevention trials of cardiovascular events using aspirin. Am J Cardiol. 2006;98(6):746-750. KQ1/3E4, KQ4E4, KQ5E4, KQ7E4. [pmid: 16950176].
14 Benamouzig R, Yoon H, et al. APACC, a French prospective study on aspirin efficacy in reducing colorectal adenoma recurrence: design and baseline findings. Eur J Cancer Prev. 2001;10(4):327-335. KQ4E4. [pmid: 11535875].
15 Benamouzig R, Deyra J, et al. Daily soluble aspirin and prevention of colorectal adenoma recurrence: one-year results of the APACC trial. Gastroenterology. 2003;125(2):328-336. KQ1/3E4, KQ4E4, KQ7E4. [pmid: 12891533].
16 Benamouzig R, Uzzan B, et al. Cyclooxygenase-2 expression and recurrence of colorectal adenomas: effect of aspirin chemoprevention. Gut. 2010;59(5):622-629. KQ5E3. [pmid: 20427397].
17 Beresford SAA, Johnson KC, et al. Low-fat dietary pattern and risk of colorectal cancer: the Women's Health Initiative Randomized Controlled Dietary Modification Trial. JAMA. 2006;295(6):643-654. KQ4E3a. [pmid: 16467233].
18 Bertagnolli MM, Eagle CJ, et al. Celecoxib for the prevention of sporadic colorectal adenomas. New England Journal of Medicine. 2006;355(9):873-884. KQ5E3c, KQ7E3c. [pmid: 16943400].
19 Bosetti C, Gallus S, et al. Aspirin and cancer risk: an updated quantitative review to 2005. Cancer Causes & Control. 2006;17(7):871-888. KQ4E6. [pmid: 16841255].
20 Bosetti C, Rosato V, et al. Aspirin and cancer risk: a quantitative review to 2011. Annals of Oncology. 2012;23(6):1403-1415. KQ4E6. [pmid: 22517822].
21 Brasky TM, Liu J, et al. Non-steroidal Anti-inflammatory Drugs and Cancer Risk in Women: Results from the Women's Health Initiative. Int J Cancer. 2014;135(8):1869-83. KQ4E3. [pmid: 24599876].
22 Brown CJ, Gallinger S, et al. Long-term effects of aspirin on colorectal cancer. Journal of the American College of Surgeons. 2012;214(6):1023-1026. KQ1/3E5, KQ4E5, KQ5E5. [pmid: 22626547].
23 Bujanda L, Lanas A, et al. Effect of aspirin and antiplatelet drugs on the outcome of the fecal immunochemical test. Mayo Clinic Proceedings. 2013;88(7):683-689. KQ4E5, KQ5E5. [pmid: 23751980].
24 Calton BA, Lacey JV Jr., et al. Physical activity and the risk of colon cancer among women: a prospective cohort study (United States). International Journal of Cancer. 2006;119(2):385-391. KQ4E3b.
25 Chan AT, Giovannucci EL, et al. Long-term use of aspirin and nonsteroidal anti-inflammatory drugs and risk of colorectal cancer. JAMA. 2005;294(8):914-923. KQ5E4. [pmid: 16118381].
26 Chan AT, Tranah GJ, et al. A prospective study of genetic polymorphisms in the cytochrome P-450 2C9 enzyme and the risk for distal colorectal adenoma. Clinical Gastroenterology & Hepatology. 2004;2(8):704-712. KQ5E5. [pmid: 15290664].
27 Chan AT, Hsu M, et al. The influence of UGT1A6 variants and aspirin use in a randomized trial of celecoxib for prevention of colorectal adenoma. Cancer Prevention Research. 2012;5(1):61-72. KQ5E3c. [pmid: 22030088].
28 Chan AT, Ogino S, et al. Aspirin and the risk of colorectal cancer in relation to the expression of COX-2. New England Journal of Medicine. 2007;356(21):2131-2142. KQ4E2. [pmid: 17522398].
29 Cibere J, Sibley J, Haga M. Rheumatoid arthritis and the risk of malignancy. Arthritis and rheumatism. 1997;40(9):1580-6. KQ4E3. [pmid: 9324011].
30 Cole BF, Baron JA, et al. Folic acid for the prevention of colorectal adenomas: a randomized clinical trial. JAMA. 2007;297(21):2351-2359. KQ5E3. [pmid: 17551129].
31 Cooper K, Squires H, et al. Chemoprevention of colorectal cancer: systematic review and economic evaluation. Health Technology Assessment (Winchester, England). 2010;14(32):1-206. KQ1/3E4, KQ4E6, KQ5E6, KQ7E6.
32 Dube C, Rostom A, et al. The use of aspirin for primary prevention of colorectal cancer: a systematic review prepared for the U.S. Preventive Services Task Force. Annals of Internal Medicine. 2007;146(5):365-375. KQ1/3E6, KQ4E6, KQ5E6, KQ7E6. [pmid: 17339622].
33 Findings from the aspirin component of the ongoing Physicians' Health Study. N Engl J Med. 1988;318(4):262-264. KQ5E4. [pmid: 3275899].
34 Friis S, Sorensen HT, et al. A population-based cohort study of the risk of colorectal and other cancers among users of low-dose aspirin. Br J Cancer. 2003;88(5):684-688. KQ1/3E4, KQ4E3d, KQ5E4, KQ7E4. [pmid: 12618874].
35 Gandhi S, Narula N, et al. Does acetylsalicylic acid or warfarin affect the accuracy of fecal occult blood tests?. Journal of Gastroenterology & Hepatology. 2013;28(6):931-936. KQ4E6, KQ5E6. [pmid: 23517228].
36 Gann PH, Manson JE, et al. Low-dose aspirin and incidence of colorectal tumors in a randomized trial. J Natl Cancer Inst. 1993;85(15):1220-1224. KQ1/3E4, KQ5E4, KQ7E4. [pmid: 8331682].
37 Giovannucci E, Rimm EB, et al. Aspirin use and the risk for colorectal cancer and adenoma in male health professionals. Ann Intern Med. 1994;121(4):241-246. KQ1/3E3b, KQ4E3b, KQ5E3b, KQ7E4. [pmid: 8037405].
38 Glynn RJ, Buring JE, et al. Adherence to aspirin in the prevention of myocardial infarction. The Physicians' Health Study. Arch Intern Med. 1994;154(23):2649-2657. KQ5E4. [pmid: 7993148].
39 Grau MV, Baron JA, et al. Interaction of calcium supplementation and nonsteroidal anti-inflammatory drugs and the risk of colorectal adenomas. Cancer Epidemiology, Biomarkers & Prevention. 2005;14(10):2353-2358. KQ5E3.
40 Greenberg ER, Baron JA, et al. Reduced risk of large-bowel adenomas among aspirin users. The Polyp Prevention Study Group. J Natl Cancer Inst. 1993;85(11):912-916. KQ1/3E3b, KQ4E3b, KQ5E3b, KQ7E3b. [pmid: 8492320].
41 Greenspan EJ, Madigan JP, et al. Ibuprofen inhibits activation of nuclear {beta}-catenin in human colon adenomas and induces the phosphorylation of GSK-3{beta}. Cancer Prevention Research. 2011;4(1):161-171. KQ5E3f. [pmid: 21205744].
42 Half E, Arber N. Colon cancer: preventive agents and the present status of chemoprevention. Expert Opinion on Pharmacotherapy. 2009;10(2):211-219. KQ4E5, KQ5E5. [pmid: 19236194].
43 Harris RE, Beebe-Donk J, et al. Aspirin, ibuprofen, and other non-steroidal anti-inflammatory drugs in cancer prevention: a critical review of non-selective COX-2 blockade (review). Oncology Reports. 2005;13(4):559-583. KQ4E6. [pmid: 15756426].
44 Hart RG, Halperin JL, et al. Aspirin for the primary prevention of stroke and other major vascular events: meta-analysis and hypotheses. Arch Neurol. 2000;57(3):326-332. KQ1/3E4, KQ4E4, KQ5E4, KQ7E4. [pmid: 10714657].
45 He J, Whelton PK, et al. Aspirin and risk of hemorrhagic stroke: a meta-analysis of randomized controlled trials. JAMA. 1998;280(22):1930-1935. KQ1/3E4, KQ4E4, KQ5E4, KQ7E4. [pmid: 9851479].
46 Hennekens CH, Buring JE, et al. Lack of effect of long-term supplementation with beta carotene on the incidence of malignant neoplasms and cardiovascular disease. N Engl J Med. 1996;334(18):1145-1149. KQ1/3E3, KQ4E3, KQ5E3, KQ7E3. [pmid: 8602179].
47 Hoffmeister M, Chang-Claude J, et al. Do older adults using NSAIDs have a reduced risk of colorectal cancer?. Drugs & Aging. 2006;23(6):513-523. KQ4E6. [pmid: 16872234].
48 Hollestein LM, van Herk-Sukel MPP, et al. Incident cancer risk after the start of aspirin use: results from a Dutch population-based cohort study of low dose aspirin users. International Journal of Cancer. 2014;135(1):157-65. KQ4E3d.
49 Hu FB, Stampfer MJ, et al. Dietary fat and coronary heart disease: a comparison of approaches for adjusting for total energy intake and modeling repeated dietary measurements. Am J Epidemiol. 1999;149(6):531-540. KQ1/3E3, KQ4E3, KQ5E3, KQ7E3. [pmid: 10084242].
50 Huang L, Wang X, et al. The comparison of the clinical manifestations and risk factors of colorectal cancer and adenomas: results from a colonoscopy-based study in southern Chinese. International Journal of Colorectal Disease. 2010;25(11):1343-1351. KQ4E5, KQ5E5. [pmid: 20680303].
51 Huang WK, Chiou MJ, et al. The association between low-dose aspirin use and the incidence of colorectal cancer: a nationwide cohort study. Aliment Pharmacol Ther. 2013;38(4):432-9. KQ1/3E5, KQ4E5. [pmid: 23799975].
52 Hubner RA, Muir KR, et al. Genetic variants of UGT1A6 influence risk of colorectal adenoma recurrence. Clinical Cancer Research. 2006;12(21):6585-6589. KQ5E3. [pmid: 17085674].
53 Hubner RA, Muir KR, et al. Polymorphisms in PTGS1, PTGS2 and IL-10 do not influence colorectal adenoma recurrence in the context of a randomized aspirin intervention trial. International Journal of Cancer. 2007;121(9):2001-2004. KQ5E3.
54 Hull MA, Sandell AC, et al. A randomized controlled trial of eicosapentaenoic acid and/or aspirin for colorectal adenoma prevention during colonoscopic surveillance in the NHS Bowel Cancer Screening Programme (The seAFOod Polyp Prevention Trial): study protocol for a randomized controlled trial. Trials. 2013;14(1):237-237. KQ5E1. [pmid: 23895505].
55 Johnson CC, Hayes RB, et al. Non-steroidal anti-inflammatory drug use and colorectal polyps in the Prostate, Lung, Colorectal, And Ovarian Cancer Screening Trial. American Journal of Gastroenterology. 2010;105(12):2646-2655. KQ5E5. [pmid: 20808298].
56 Koretz R. ACP Journal Club. Meta-analysis: aspirin reduces risk for colon cancer and related mortality at 20 years, particularly when taken for >= 5 years. Annals of Internal Medicine. 2011;154(6):JC3-3. KQ1/3E5, KQ4E5. [pmid: 21403066].
57 Levine AJ, Grau MV, et al. Baseline plasma total homocysteine and adenoma recurrence: results from a double blind randomized clinical trial of aspirin and folate supplementation. Cancer Epidemiology, Biomarkers & Prevention. 2010;19(10):2541-2548. KQ5E3.
58 Liao X, Lochhead P, et al. Aspirin use, tumor PIK3CA mutation, and colorectal-cancer survival. New England Journal of Medicine. 2012;367(17):1596-1606. KQ1/3E4, KQ4E4, KQ7E4. [pmid: 23094721].
59 Lip GY, Felmeden DC. Antiplatelet agents and anticoagulants for hypertension. Cochrane Database Syst Rev. 2004;(3). CD003186. KQ1/3E4, KQ4E4, KQ5E4, KQ7E4.
60 Lynch PM. Does regular use of aspirin reduce the risk of colorectal cancer?. Nature Clinical Practice Oncology. 2006;3(4):186-187. KQ4E5.
61 Mahipal A, Anderson KE, et al. Nonsteroidal anti-inflammatory drugs and subsite-specific colorectal cancer incidence in the Iowa women's health study. Cancer Epidemiology, Biomarkers & Prevention. 2006;15(10):1785-1790. KQ4E3b.
62 Manson JE, Buring JE, et al. Baseline characteristics of participants in the Physicians' Health Study: a randomized trial of aspirin and beta-carotene in U.S. physicians. Am J Prev Med. 1991;7(3):150-154. KQ5E4. [pmid: 1931143].
63 Mansouri D, McMillan DC, et al. The impact of aspirin, statins and ACE-inhibitors on the presentation of colorectal neoplasia in a colorectal cancer screening programme. British Journal of Cancer. 2013;109(1):249-256. KQ4E3b, KQ5E3b. [pmid: 23778525].
64 Massat NJ, Moss SM, et al. Screening and primary prevention of colorectal cancer: a review of sex-specific and site-specific differences. Journal of Medical Screening. 2013;20(3):125-48. KQ4E6. [pmid: 24197771].
65 Meyskens FL Jr., McLaren CE, et al. Difluoromethylornithine plus sulindac for the prevention of sporadic colorectal adenomas: a randomized placebo-controlled, double-blind trial. Cancer Prevention Research. 2008;1(1):32-38. KQ5E3c, KQ7E3d. [pmid: 18841250].
66 Mills EJ, Wu P, et al. Low-dose aspirin and cancer mortality: a meta-analysis of randomized trials. Am J Med. 2012;125(6):560-7. KQ1/3E4. [pmid: 22513195].
67 Nishihara R, Lochhead P, et al. Aspirin use and risk of colorectal cancer according to BRAF mutation status. JAMA. 2013;309(24):2563-2571. KQ1/3E4, KQ4E2. [pmid: 23800934].
68 Paganini-Hill A. Aspirin and colorectal cancer: the Leisure World cohort revisited. Prev Med. 1995;24(2):113-115. KQ1/3E4, KQ4E3b, KQ5E4, KQ7E9. [pmid: 7597009].
69 Paganini-Hill A, Chao A, et al. Aspirin use and chronic diseases: a cohort study of the elderly. BMJ. 1989;299(6710):1247-1250. KQ4E3b, KQ7E9. [pmid: 2513898].
70 Paganini-Hill A, Hsu G, et al. Aspirin use and incidence of large-bowel cancer in a California retirement community. J Natl Cancer Inst. 1991;83(16):1182-1183. KQ4E3b. [pmid: 1886151].
71 Pasche B. Differential effects of aspirin before and after diagnosis of colorectal cancer. JAMA. 2013;309(24):2598-2599. KQ1/3E5, KQ4E5, KQ7E5. [pmid: 23800937].
72 Perez R, Lasa A, et al. Relationship between sporadic hyperplastic polyps and colorectal neoplasia in Hispanic veterans. Puerto Rico Health Sciences Journal. 2010;29(4):372-376. KQ4E5, KQ5E5. [pmid: 21261176].
73 Physician's Health Study. Final Report on the Aspirin Component of the Ongoing Physicians' Health Study. New England Journal of Medicine. 1989;321(3):129-135. KQ5E4. [pmid: 2664509].
74 Poynter JN, Inoue-Choi M, et al. Reproductive, lifestyle, and anthropometric risk factors for cancer in elderly women. Cancer Epidemiology, Biomarkers & Prevention. 2013;22(4):681-687. KQ4E3b.
75 Purdue MP, Mink PJ, et al. Hormone replacement therapy, reproductive history, and colorectal adenomas: data from the Prostate, Lung, Colorectal and Ovarian (PLCO) Cancer Screening Trial (United States). Cancer Causes & Control. 2005;16(8):965-973. KQ5E3f. [pmid: 16132805].
76 Quintero E, Castells A, et al. Colonoscopy versus fecal immunochemical testing in colorectal-cancer screening. N Engl J Med. 2012;366(8):697-706. KQ4E5, KQ5E5. [pmid: 22356323].
77 Ratnasinghe LD, Graubard BI, et al. Aspirin use and mortality from cancer in a prospective cohort study. Anticancer Res. 2004;24(5B):3177-3184. KQ1/3E3b. [pmid: 15510608].
78 Rimm EB, Giovannucci EL, et al. Prospective study of alcohol consumption and risk of coronary disease in men. Lancet. 1991;338(8765):464-468. KQ4E3. [pmid: 1678444].
79 Rimm EB, Giovannucci EL, et al. Reproducibility and validity of an expanded self-administered semiquantitative food frequency questionnaire among male health professionals. Am J Epidemiol. 1992;135(10):1114-1126. discussion 1127-1136. KQ1/3E3, KQ4E3, KQ5E3, KQ7E3. [pmid: 1632423].
80 Ritenbaugh C, Patterson RE, et al. The Women's Health Initiative Dietary Modification trial: overview and baseline characteristics of participants. Ann Epidemiol. 2003;13(9 Suppl):S87-97. KQ4E3. [pmid: 14575941].
81 Rosenberg L, Louik C, Shapiro S. Nonsteroidal antiinflammatory drug use and reduced risk of large bowel carcinoma. Cancer. 1998;82(12):2326-33. KQ4E5. [pmid: 9635524].
82 Rostom A, Dube C, et al. 2007. Use of Aspirin and NSAIDs to Prevent Colorectal Cancer. KQ1/3E3, KQ4E3, KQ5E3, KQ7E3.
83 Rothwell PM, Wilson M, et al. Effect of daily aspirin on risk of cancer metastasis: a study of incident cancers during randomised controlled trials. Lancet. 2012;379(9826):1591-1601. KQ1/3E4. [pmid: 22440947].
84 Rothwell PM, Price JF, et al. Short-term effects of daily aspirin on cancer incidence, mortality, and non-vascular death: analysis of the time course of risks and benefits in 51 randomised controlled trials. Lancet. 2012;379(9826):1602-12. KQ1/3E3a, KQ4E4. [pmid: 22440946].
85 Ruder EH, Laiyemo AO, et al. Non-steroidal anti-inflammatory drugs and colorectal cancer risk in a large, prospective cohort. American Journal of Gastroenterology. 2011;106(7):1340-1350. KQ4E3b. [pmid: 21407185].
86 Siemes C, Visser LE, et al. Protective effect of NSAIDs on cancer and influence of COX-2 C(-765G) genotype. Curr Cancer Drug Targets. 2008;8(8):753-764. KQ1/3E4, KQ4E3b. [pmid: 19075598].
87 Smalley W, Ray WA, et al. Use of nonsteroidal anti-inflammatory drugs and incidence of colorectal cancer: a population-based study. Arch Intern Med. 1999;159(2):161-166. KQ4E3. [pmid: 9927099].
88 Stampfer MJ, Willett WC, et al. Test of the National Death Index. Am J Epidemiol. 1984;119(5):837-839. KQ1/3E3, KQ4E3, KQ5E3, KQ7E3. [pmid: 6720679].
89 Sturmer T, Buring JE, et al. Colorectal cancer after start of nonsteroidal anti-inflammatory drug use. American Journal of Medicine. 2006;119(6):494-502. KQ4E3f. [pmid: 16750963].
90 Sturmer T, Glynn RJ, et al. Aspirin use and colorectal cancer: post-trial follow-up data from the Physicians' Health Study. Ann Intern Med. 1998;128(9):713-720. KQ1/3E4, KQ5E4, KQ7E4. [pmid: 9556464].
91 Sutcliffe P, Connock M, et al. Aspirin for prophylactic use in the primary prevention of cardiovascular disease and cancer: a systematic review and overview of reviews. Health Technology Assessment (Winchester, England). 2013;17(43):1-253. KQ1/3E6, KQ4E6, KQ7E6.
92 Tangrea JA, Albert PS, et al. Non-steroidal anti-inflammatory drug use is associated with reduction in recurrence of advanced and non-advanced colorectal adenomas (United States). Cancer Causes Control. 2003;14(5):403-411. KQ1/3E4, KQ4E4, KQ5E3a, KQ7E4. [pmid: 12946034].
93 Tenenbaum A, Grossman E, et al. Long-term diuretic therapy in patients with coronary disease: increased colon cancer-related mortality over a 5-year follow-up. J Hum Hypertens. 2001;15(6):373-379. KQ4E3b. [pmid: 11439311].
94 Thompson P, Roe DJ, et al. Design and baseline characteristics of participants in a phase III randomized trial of celecoxib and selenium for colorectal adenoma prevention. Cancer Prevention Research. 2012;5(12):1381-1393. KQ5E1. [pmid: 23060037].
95 Wang H, Taverna D, et al. 2013. Genetic Variation in the Inflammation and Innate Immunity Pathways and Colorectal Cancer Risk. Cancer Epidemiol Biomarkers Prev. KQ4E3b.
96 Weisman SM, Graham DY, et al. Evaluation of the benefits and risks of low-dose aspirin in the secondary prevention of cardiovascular and cerebrovascular events. Arch Intern Med. 2002;162(19):2197-2202. KQ1/3E4, KQ4E4, KQ5E4, KQ7E4. [pmid: 12390062].
97 Wells BJ, Kattan MW, et al. ColoRectal Cancer Predicted Risk Online (CRC-PRO) calculator using data from the Multi-Ethnic Cohort Study. Journal of the American Board of Family Medicine: JABFM. 2014;27(1):42-55. KQ4E3a. [pmid: 24390885].
98 Willett WC, Sampson L. Reproducibility and validity of a semiquantitative food frequency questionnaire. Am J Epidemiol. 1985;122(1):51-65. KQ1/3E3, KQ4E3, KQ5E3, KQ7E3. [pmid: 4014201].
99 Ye X, Fu J, et al. Dose-risk and duration-risk relationships between aspirin and colorectal cancer: a meta-analysis of published cohort studies. PLoS ONE. [Electronic Resource]. 2013;8(2):e57578. KQ4E6. [pmid: 23451245].