# Ongoing or Recently Completed Studies

RCT | Aim | Population | Intervention | Control | Relevant Outcomes | Status
Systematic Evaluation of Aspirin and Fish Oil (SeAFOod) polyp prevention trial194 (ISRCTN05926847) | Determine whether EPA or ASA prevent colorectal adenomas | English Bowel Cancer Screening Program: patients aged 55 to 73 years identified as “high risk” (detection of ≥5 small adenomas or ≥3 adenomas with at least one ≥10 mm in diameter) at first screening colonoscopy | 1 g EPA-free fatty acid twice daily or 300 mg ASA daily for 12 months | Placebo | Number of patients with colorectal adenomas, AEs, number of patients with “advanced” adenomas, number of adenomas, number of “advanced” adenomas, location of adenomas | Completed as of May 2014
Aspirin in Preventing Colorectal Cancer in Patients at Increased Risk of Colorectal Cancer (NCT00468910) | Determine how well aspirin prevents CRC in patients with increased CRC risk | Patients up to 75 years old with history of significant colonic neoplasia | Daily aspirin (dose not specified) | Placebo | Spectral markers in distant colonic mucosa | Ongoing as of December 2013

Abbreviations: AE = adverse events; ASA = acetylsalicylic acid; CRC = colorectal cancer; EPA = eicosapentaenoic acid; g = gram; mg = milligram; mm = millimeter; NSAIDs = nonsteroidal antiinflammatory drugs; RCT = randomized controlled trial