# Literature Search Strategies

## A Systematic Evidence Review Search Strategies

### Cochrane Database of Systematic Reviews search strategy

#1 (colorectal or colon or colonic or rectal or rectum or rectosigmoid or adenomat*):ti,ab,kw
#2 (cancer* or carcinoma* or adenocarcinoma* or malignan* or tumor* or tumour* or neoplasm* or polyp*):ti,ab,kw
#3 #1 and #2
#4 (NSAID* or “Nonsteroidal Antiinflammatory” or “Non steroidal Antiinflammatory” or “Nonsteroidal Anti inflammatory” or “Non steroidal Anti inflammatory”):ti,ab,kw
#5 (Cyclooxygenase next Inhibitor* or Cyclo next Oxygenase next Inhibitor* or Cyclooxygenase next 2 next Inhibitor* or Cyclo next oxygenase next 2 next Inhibitor* or COX2 next Inhibitor* or COX next 2 next Inhibitor*):ti,ab,kw
#6 (Aspirin or “acetylsalicylic acid” or Salicylate*):ti,ab,kw
#7 (Celecoxib or Diclofenac or Diflunisal or Etodolac or Fenoprofen or Flurbiprofen or Indomethacin or Ketroprofen or Ketorolac):ti,ab,kw
#8 (Meclofenamate or “Meclofenamic Acid” or “Mefenamic Acid” or Nabumetone or Naproxen or Oxaprozin or Piroxicam or Sulindac or Tolmetin):ti,ab,kw
#9 (Ibuprofen or Meloxicam):ti,ab,kw
#10 (chemoprevent* or chemoprophyl*):ti,ab,kw
#11 #4 or #5 or #6 or #7 or #8 or #9 or #10
#12 #3 and #11 from 2004 to 2013, in Cochrane Reviews (Reviews and Protocols)

### Database of Abstracts of Reviews of Effects search strategy

1. (colorectal ) OR (colon) OR (colonic) OR (rectal) OR (rectum) IN DARE FROM 2004 TO 2013
2. (rectosigmoid) OR (adenomat*) IN DARE FROM 2004 TO 2013
3. #1 OR #2
4. (cancer*) OR (carcinoma*) OR (adenocarcinoma*) OR (malignan*) OR (tumor*) IN DARE FROM 2004 TO 2013
5. (tumour*) OR (neoplasm*) OR (polyp*) IN DARE FROM 2004 TO 2013
6. #4 OR #5
7. #3 AND #6
8. (NSAID*) OR (Nonsteroidal ADJ Antiinflammatory) OR (Non ADJ steroidal ADJ Antiinflammatory) OR (Nonsteroidal ADJ Anti ADJ inflammatory) OR (Non ADJ steroidal ADJ Anti ADJ inflammatory) IN DARE FROM 2004 TO 2013
9. (Cyclooxygenase ADJ Inhibitor*) OR (Cyclo ADJ Oxygenase ADJ Inhibitor*) OR (Cyclooxygenase ADJ 2 ADJ Inhibitor*) OR (Cyclo ADJ oxygenase ADJ 2 ADJ Inhibitor*) OR (COX2 ADJ Inhibitor*) IN DARE FROM 2004 TO 2013
10. (COX ADJ 2 ADJ Inhibitor*) OR (Aspirin) OR (acetylsalicylic ADJ acid) OR (Salicylate*) OR (Celecoxib) IN DARE FROM 2004 TO 2013
11. (Diclofenac) OR (Diflunisal) OR (Etodolac) OR (Fenoprofen) OR (Flurbiprofen) IN DARE FROM 2004 TO 2013
12. (Indomethacin) OR (Ketroprofen) OR (Ketorolac) OR (Meclofenamate) OR (Meclofenamic ADJ Acid) IN DARE FROM 2004 TO 2013
13. (Mefenamic ADJ Acid) OR (Nabumetone) OR (Naproxen) OR (Oxaprozin) OR (Piroxicam) IN DARE FROM 2004 TO 2013
14. (Sulindac) OR (Tolmetin) IN DARE FROM 2004 TO 2013
15. (Ibuprofen) OR (Meloxicam) IN DARE FROM 2004 TO 2013
16. #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 OR #15
17. #7 AND #16

### PubMed search strategy

#21 #3 AND #18 AND systematic[sb] Filters: Publication date from 2004/01/01; English
#20 #3 AND #18 AND systematic[sb] Filters: English
#19 #3 AND #18 AND systematic[sb]
#18 #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #14 OR #15 OR #16 OR #17
#17 chemoprevent*[ti] OR chemoprophyl*[ti]
#16 Ibuprofen[tiab] OR Meloxicam[tiab]
#15 Meclofenamate[tiab] OR Meclofenamic Acid[tiab] OR Mefenamic Acid[tiab] OR Nabumetone[tiab] OR Naproxen[tiab] OR Oxaprozin[tiab] OR Piroxicam[tiab] OR Sulindac[tiab] OR Tolmetin[tiab]
#14 Celecoxib[tiab] OR Diclofenac[tiab] OR Diflunisal[tiab] OR Etodolac[tiab] OR Fenoprofen[tiab] OR Flurbiprofen[tiab] OR Indomethacin[tiab] OR Ketroprofen[tiab] OR Ketorolac[tiab]
#9 Aspirin[tiab] OR acetylsalicylic acid[tiab] OR Salicylate*[tiab]
#8 Cyclooxygenase Inhibitor*[tiab] OR Cyclo Oxygenase Inhibitor*[tiab] OR Cyclooxygenase 2 Inhibitor*[tiab] OR Cyclo oxygenase 2 Inhibitor*[tiab] OR COX2 Inhibitor*[tiab] OR COX 2 Inhibitor*[tiab]
#7 NSAID*[tiab] OR Nonsteroidal Antiinflammatory[tiab] OR Non steroidal Antiinflammatory[tiab] OR Nonsteroidal Anti inflammatory[tiab] OR Non steroidal Anti inflammatory[tiab]
#6 “nabumetone” [Supplementary Concept] OR Naproxen[mesh] OR “oxaprozin” [Supplementary Concept] OR Piroxicam[mesh] OR Sulindac[mesh] OR Tolmetin[mesh] OR “Chemoprevention”[Mesh:NoExp]
#5 Diclofenac[mesh] OR Diflunisal[mesh] OR Ibuprofen[mesh] OR Etodolac[mesh] OR Fenoprofen[mesh] OR Flurbiprofen[mesh] OR “Indomethacin”[Mesh:NoExp] OR Ketoprofen[mesh] OR Ketorolac[mesh] OR “Meclofenamic Acid”[Mesh] OR “Mefenamic Acid”[Mesh] OR “meloxicam” [Supplementary Concept]
#4 “Anti-Inflammatory Agents, Non-Steroidal”[Mesh:noexp] OR “Cyclooxygenase Inhibitors”[Mesh:noexp] OR “Cyclooxygenase 2 Inhibitors”[Mesh] OR “Anti-Inflammatory Agents, Non-Steroidal”[Pharmacological Action] OR “Aspirin”[Mesh] OR “Salicylates”[Mesh:NoExp] OR “celecoxib”[Supplementary Concept]
#3 #1 OR #2
#2 ((colorectal[tiab] OR colon[tiab] OR colonic[tiab] OR rectal[tiab] OR rectum[tiab] OR rectosigmoid*[tiab] OR adenomat*[tiab]) AND (cancer*[tiab] OR carcinoma*[tiab] OR adenocarcinoma*[tiab] OR malignan*[tiab] OR tumor[tiab] OR tumoro* OR tumors OR tumour*[tiab] OR neoplasm*[tiab] OR polyp OR polypo* OR polyps*[tiab]))
#1 “Colorectal Neoplasms”[Mesh:noexp] OR “Adenomatous Polyposis Coli”[Mesh:noexp] OR “Colonic Neoplasms”[Mesh:noexp] OR “Sigmoid Neoplasms”[Mesh:noexp] OR “Colorectal Neoplasms, Hereditary Nonpolyposis”[Mesh] OR “Rectal Neoplasms”[Mesh] OR “Anus Neoplasms”[Mesh:noexp] OR “Anal Gland Neoplasms”[Mesh] OR “Colonic Polyps”[Mesh] OR “Adenomatous Polyps”[Mesh:noexp]

## B Key Question Literature Search Strategies

### Database: Ovid MEDLINE(R) without Revisions <1996 to September Week 2 2013>, Ovid MEDLINE(R) Daily Update <September 20, 2013>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <September 20, 2013>

Search Strategy:

1. Colorectal Neoplasms/ (44682)
2. Adenomatous Polyposis Coli/ (3261)
3. Colonic Neoplasms/ (28061)
4. Sigmoid Neoplasms/ (1333)
5. Colorectal Neoplasms, Hereditary Nonpolyposis/ (2858)
6. Rectal Neoplasms/ (13410)
7. Anus Neoplasms/ (2312)
8. Anal Gland Neoplasms/ (56)
9. Colonic Polyps/ (4018)
10. Adenomatous Polyps/ (894)
11. (colorectal or colon or colonic or rectal or rectum or rectosigmoid$ or adenomat$).ti,ab. (179977)
12. (cancer$ or carcinoma$ or adenocarcinoma$ or malignan$ or tumor$ or tumour$ or neoplas$ or polyp$).ti,ab. (1471032)
13. 11 and 12 (123625)
14. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 13 (139804)
15. Aspirin/ (17756)
16. Salicylates/ (2799)
17. aspirin.ti,ab. (22644)
18. acetylsalicylic acid.ti,ab. (3377)
19. salicylate$.ti,ab. (3860)
20. 15 or 16 or 17 or 18 or 19 (35077)
21. 14 and 20 (1162)
22. limit 21 to (english language and yr=“2004 -Current”) (699)
23. remove duplicates from 22 (699)

### Database: PUBMED- [publisher supplied references only]

#6 | Search #3 AND publisher[sb] Filters: Publication date from 2004/01/01 to 2013/12/31; English
#5 | Search #3 AND publisher[sb] Filters: English
#4 | Search #3 AND publisher[sb]
#3 | Search #1 AND #2
#2 | Search Aspirin[tiab] OR acetylsalicylic acid[tiab] OR Salicylate*[tiab]
#1 | Search ((colorectal[tiab] OR colon[tiab] OR colonic[tiab] OR rectal[tiab] OR rectum[tiab] OR rectosigmoid*[tiab] OR adenomat*[tiab]) AND (cancer[tiab] OR cancers[tiab] OR cancerous[tiab] OR carcinoma*[tiab] OR adenocarcinoma*[tiab] OR malignan*[tiab] OR tumor[tiab] OR tumoro* OR tumors OR tumour*[tiab] OR neoplasm*[tiab] OR polyp OR polypo* OR polyps[tiab]))

### Database: Cochrane Central Register of Controlled Clinical Trials (CENTRAL)

Issue 8 of 12, August 2013

#1 (colorectal or colon or colonic or rectal or rectum or rectosigmoid or adenomat*):ti,ab,kw from 2004 to 2013, in Trials
#2 (cancer* or carcinoma* or adenocarcinoma* or malignan* or tumor* or tumour* or neoplas* or polyp*):ti,ab,kw from 2004 to 2013, in Trials
#3 #1 and #2 from 2004 to 2013, in Trials
#4 (Aspirin or “acetylsalicylic acid” or Salicylate*):ti,ab,kw from 2004 to 2013, in Trials
#5 #3 and #4 from 2004 to 2013, in Trials

Appendix A Figure 1 Literature Flow Diagram

This figure is a flow chart that summarizes the search and selection of articles. There were 977 citations identified through literature databases. An additional 91 citations were identified from outside sources such as reference lists. After duplicates were removed, 865 unique citations were screened at the title/abstract phase. The full-text of 149 citations were examined for inclusion for one or more of the Key Questions. There were 39 articles (16 studies) for Key Questions 1 and 3, 45 articles (16 studies) for Key Question 4, 15 articles (4 studies) for Key Question 5, and 32 articles (15 studies) for Key Question 7. Reasons for excluding the other articles are available in Appendix C.

Appendix A Table 1 Inclusion and Exclusion Criteria

| Included | Excluded
Populations | Men and women aged 40 years or older | - Nonhuman populations; - Studies where the majority of patients were younger than 40 years old; - Studies limited to or with a high proportion of patients with the following conditions who could not be examined separately:; ○ Familial adenomatous polyposis; ○ Lynch syndrome; ○ Personal history of CRC; ○ Inflammatory bowel disease (Crohn's disease and ulcerative colitis); ○ No colon; ○ History of another cancer or familial multiple cancer syndrome that includes CRC; ○ Symptomatic (i.e., undergoing diagnostic colonoscopy)
Interventions | KQs 1/3, 4, and 5:; - Oral aspirin; - Aspirin use for any indication (e.g., primary or secondary prevention of cardiovascular disease, arthritis treatment), as long as intended duration is at least 1 year; KQ7: No minimum intended duration of use | - Interventions/exposures limited to combined products containing levels of aspirin below 75 mg per day or every other day; - Interventions/exposures limited to nonaspirin NSAIDs; - Interventions/exposures using nonoral routes of delivery; - Studies with no information on dose; - Interventions/exposures limited to irregular or occasional use only
Comparators | - Placebo; - No treatment; (Note: includes studies in which both intervention and control (or exposed and unexposed) groups may be taking other medications or supplements.) | - Studies limited to comparison of aspirin with other medications; - Studies examining aspirin in combination with other medications (i.e., intentional cotreatment) for chemoprevention
Outcomes | KQs 1/3, 4, and 5 (benefits):; - Colorectal adenoma incidence; - Colorectal adenoma number; - Advanced adenoma incidence; - Advanced neoplasia; - CRC incidence; - CRC mortality; - All-cause mortality; KQ7 (harms):; - Major nonintracranial bleeding, particularly serious gastrointestinal bleeding; - Intracranial bleeding; - Stroke (any, hemorrhagic); - Age-related macular degeneration | - CRC metastasis or progression
Study Design | KQs 1/3, 4, 5, and 7 RCTs, CCTs, fair-quality and good-quality systematic reviews of RCTs, meta-analyses of RCTs, and high- quality prospective cohort studies | KQ 1/3, 4, 5, and 7 Retrospective cohort studies, case control studies, case series, case reports, narrative reviews, commentaries, or editorials KQ7 Studies that do not report on CRC outcomes
Timing | No minimum followup
Setting | Outpatient | Exclusively inpatient
Country | All countries
Language | English | Non-English

Abbreviations: CCT = controlled clinical trial; CRC = colorectal cancer; KQ = key question; mg = milligram; NSAIDs = nonsteroidal anti-inflammatory drugs; RCT = randomized controlled trials

Appendix A Table 2 Quality Assessment Criteria

Study Design | Adapted Quality Criteria
Randomized controlled trials, adapted from the USPSTF methods193 | - Was random assignment valid?; - Was allocation concealed at randomization?; - Were eligibility criteria specified?; - Were groups similar at baseline?; - Were outcome assessors blinded?; - Were measurements equal, valid and reliable?; - Was adherence to the intervention adequate?; - Was followup acceptable?; - Were the statistical methods acceptable?; - Was an intent-to-treat analysis performed?; - Was handling of missing data appropriate?; - Was there evidence of selective reporting of outcomes?; - What was the funding source?
Cohort studies, adapted from the Newcastle-Ottawa Scales107 | - Was the exposed cohort representative?; - Was the selection of the nonexposed cohort systematic?; - Were eligibility criteria specified?; - Was the outcome of interest not present at baseline?; - Were potential confounders considered in study design?; - Were groups similar at baseline?; - Was ascertainment of exposure reported?; - Were measurements equal, valid and reliable?; - Were outcome assessors blinded?; - Was followup acceptable?; - Were the statistical methods acceptable?; - Was there evidence of differential censoring?; - Was handling of missing data appropriate?; - Was there adjustment for confounders?; - What was the funding source?

Abbreviations: USPSTF = U.S. Preventive Services Task Force