# References

1 Barnett H, Burrill P, Iheanacho I. Don't use aspirin for primary prevention of cardiovascular disease. BMJ. 2010;340:c1805. [pmid: 20410163].
2 Matthys F, De BT, De BG, et al. Review of guidelines on primary prevention of cardiovascular disease with aspirin: how much evidence is needed to turn a tanker?. Eur J Prev Cardiol. Mar. 2014;21(3):354-65. [pmid: 23610452].
3 Rose PW, Watson EK, Jenkins LS. Aspirin for prevention of cancer and cardiovascular disease. Br J Gen Pract. Jun. 2011;61(587):412-5. [pmid: 21801534].
4 Taber's Cyclopedic Medical Dictionary. Charlottesville, VA. Unbound Medicine, Inc. 2013. PMID: None.
5 Howlader N, Noone AM, Krapcho M, et al. SEER Cancer Statistics Review, 1975-2011. Bethesda, MD. National Cancer Institute. 2014. PMID: None.
6 Siegel R, Naishadham D, Jemal A. Cancer statistics, 2013. CA Cancer J Clin. Jan. 2013;63(1):11-30. [pmid: 23335087].
7 Mariotto AB, Yabroff KR, Shao Y, et al. Projections of the cost of cancer care in the United States: 2010-2020. J Natl Cancer Inst. Jan. 19. 2011;103(2):117-28. [pmid: 21228314].
8 Rothwell PM, Fowkes FG, Belch JF, et al. Effect of daily aspirin on long-term risk of death due to cancer: analysis of individual patient data from randomised trials. Lancet. 2011;377(9759):31-41. [pmid: 21144578].
9 Rothwell PM, Wilson M, Elwin CE, et al. Long-term effect of aspirin on colorectal cancer incidence and mortality: 20-year follow-up of five randomised trials. Lancet. Nov. 20. 2010;376(9754):1741-50. PMID:. [pii: S0140-6736(10)61543-7]. [doi: 10.1016/S0140-6736(10)61543-7]. [pmid: 20970847].
10 Rothwell PM, Price JF, Fowkes FG, et al. Short-term effects of daily aspirin on cancer incidence, mortality, and non-vascular death: analysis of the time course of risks and benefits in 51 randomised controlled trials. Lancet. Apr. 28. 2012;379(9826):1602-12. [pmid: 22440946].
11 Thun MJ, Jacobs EJ, Patrono C. The role of aspirin in cancer prevention. Nat Rev Clin Oncol. May. 2012;9(5):259-67. [pmid: 22473097].
12 Sostres C, Gargallo CJ, Lanas A. Aspirin, cyclooxygenase inhibition and colorectal cancer. World J Gastrointest Pharmacol Ther. Feb. 6. 2014;5(1):40-9. [pmid: 24605250].
13 Chan AT, Ogino S, Fuchs CS. Aspirin and the risk of colorectal cancer in relation to the expression of COX-2. N Engl J Med. May. 24. 2007;356(21):2131-42. [pmid: 17522398].
14 Sutcliffe P, Connock M, Gurung T, et al. Aspirin for prophylactic use in the primary prevention of cardiovascular disease and cancer: a systematic review and overview of reviews. Health Technology Assessment (Winchester, England). Sep. 2013;17(43):1-253. [pmid: 24074752].
15 Laine L. Review article: gastrointestinal bleeding with low-dose aspirin - what's the risk?. [Review] [61 refs]. Alimentary Pharmacology & Therapeutics. Sep. 15. 2006;24(6):897-908. [pmid: 16948802].
16 Lanas A, Wu P, Medin J, et al. Low doses of acetylsalicylic acid increase risk of gastrointestinal bleeding in a meta-analysis. Clin Gastroenterol Hepatol. Sep. 2011;9(9):762-8. [pmid: 21699808].
17 Cryer B, Mahaffey KW. Gastrointestinal ulcers, role of aspirin, and clinical outcomes: pathobiology, diagnosis, and treatment. J Multidiscip Healthc. 2014;7:137-46. [pmid: 24741318].
18 Valkhoff VE, Sturkenboom M, Hill C, et al. Low-dose acetylsalicylic acid use and the risk of upper gastrointestinal bleeding: A meta-analysis of randomized clinical trials and observational studies. Can J Gastroenterol. Mar. 2013;27(3):159-67. [pmid: 23516680].
19 Baron JA, Senn S, Voelker M, et al. Gastrointestinal adverse effects of short-term aspirin use: a meta-analysis of published randomized controlled trials. Drugs R D. Mar. 27. 2013;13(1):9-16. [pmid: 23532576].
20 Liew G, Mitchell P, Wong TY, et al. The association of aspirin use with age-related macular degeneration. JAMA Intern Med. Jan. 21. 2013;173(4):258-64. [pmid: 23337937].
21 de Jong PT, Chakravarthy U, Rahu M, et al. Associations between aspirin use and aging macula disorder: the European Eye Study. Ophthalmology. Jan. 2012;119(1):112-8. [pmid: 21920607].
22 Miser WF. Appropriate aspirin use for primary prevention of cardiovascular disease. Am Fam Physician. Jun. 15. 2011;83(12):1380-6. [pmid: 21671538].
23 Lanza FL, Chan FK, Quigley EM. Guidelines for prevention of NSAID-related ulcer complications. Am J Gastroenterol. Mar. 2009;104(3):728-38. [pmid: 19240698].
24 Aspirin. Waltham, MA. UpToDate, Inc. 2015. http://www.uptodate.com/contents.aspirin-drug-information. PMID: None.
25 Soni A. Aspirin use among the adult U.S. noninstitutionalized population, with and without indicators of heart disease, 2005. Statistical Brief #179. Rockville, MD. Agency for Healthcare Research and Quality. 2007. PMID: None.
26 Kolber M, Sharif N, Marceau R, et al. Family practice patients' use of acetylsalicylic acid for cardiovascular disease prevention. Can Fam Physician. Jan. 2013;59(1):55-61. [pmid: 23341662].
27 Ajani UA, Ford ES, Greenland KJ, et al. Aspirin use among U.S. adults: Behavioral Risk Factor Surveillance System. Am J Prev Med. Jan. 2006;30(1):74-7. [pmid: 16414427].
28 Pignone M, Anderson GK, Binns K, et al. Aspirin use among adults aged 40 and older in the United States: results of a national survey. Am J Prev Med. May. 2007;32(5):403-7. [pmid: 17478266].
29 Mosca L, Benjamin EJ, Berra K, et al. Effectiveness-based guidelines for the prevention of cardiovascular disease in women--2011 update: a guideline from the American Heart Association. J Am Coll Cardiol. Mar. 22. 2011;57(12):1404-23. [pmid: 21388771].
30 Perk J, De BG, Gohlke H, et al. European Guidelines on cardiovascular disease prevention in clinical practice (version 2012). The Fifth Joint Task Force of the European Society of Cardiology and Other Societies on Cardiovascular Disease Prevention in Clinical Practice (constituted by representatives of nine societies and by invited experts). Eur Heart J. Jul. 2012;33(13):1635-701. [pmid: 22555213].
31 Aspirin for the prevention of cardiovascular disease: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. Mar. 17. 2009;150(6):396-404. [pmid: 19293072].
32 Vandvik PO, Lincoff AM, Gore JM, et al. Primary and secondary prevention of cardiovascular disease: Antithrombotic Therapy and Prevention of Thrombosis, 9th ed: American College of Chest Physicians Evidence-Based Clinical Practice Guidelines. Chest. Feb. 2012;141(2 Suppl):e637S-e668S. [pmid: 22315274].
33 American Academy of Family Physicians. Summary of recommendations for clinical preventive services. Leawood, KS. American Academy of Family Physicians. 2012. PMID: None.
34 Scottish Intercollegiate Guidelines Network (SIGN). Antithrombotics: indications and management. SIGN Publication No. 129. Edinburgh. SIGN. 2013. PMID: None.
35 National Institute for Health and Clinical Excellence. Clinical Knowledge Summaries. Antiplatelet treatment. When to prescribe antiplatelet treatment (primary prevention). 2013. http://cks.nice.org.uk/antiplatelet-treatment#!scenariorecommendation. April 15, 2014. PMID: None.
36 Joint British Societies' consensus recommendations for the prevention of cardiovascular disease (JBS3). Heart. Apr. 2014;100(Suppl 2):ii1-ii67. [pmid: 24667225].
37 Routine aspirin or nonsteroidal anti-inflammatory drugs for the primary prevention of colorectal cancer: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. Mar. 6. 2007;146(5):361-4. [pmid: 17339621].
38 Dube C, Rostom A, Lewin G, et al. The use of aspirin for primary prevention of colorectal cancer: a systematic review prepared for the U.S. Preventive Services Task Force. Ann Intern Med. Mar. 6. 2007;146(5):365-75. [pmid: 17339622].
39 Wolff T, Miller T, Ko S. Aspirin for the primary prevention of cardiovascular events: an update of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. Mar. 17. 2009;150(6):405-10. [pmid: 19293073].
40 Chubak J, Kamineni A, Buist D, et al. Aspirin use for the prevention of colorectal cancer: an evidence update for the U.S. Preventive Services Task Force. Rockville, MD. Agency for Healthcare Research and Quality. 2014. PMID: None.
41 Guirguis-Blake JM, Evans CV, Rowland MG, et al. Aspirin for the primary prevention of cardiovascular events: a systematic evidence review for the U.S. Preventive Services Task Force. Rockville, MD. Agency for Healthcare Research and Quality. 2014. PMID: None.
42 Whitlock EP, Williams S, Burda BU, et al. Aspirin use in adults: total cancer, all-cause mortality and harms. Rockville, MD. Agency for Healthcare Research and Quality. 2014. PMID: None.
43 Maciosek MV, Dehmer SP, Flottemesch TJ. Aspirin use to prevent CVD and cancer: decision analysis. Washington, D.C. Agency for Healthcare Research and Quality. 2015. PMID: None.
44 Seshasai SR, Wijesuriya S, Sivakumaran R, et al. Effect of aspirin on vascular and nonvascular outcomes: meta-analysis of randomized controlled trials. Arch Intern Med. Feb. 13. 2012;172(3):209-16. [pmid: 22231610].
45 Wolff T, Miller T, Ko S. Aspirin for the primary prevention of cardiovascular events: an update of the evidence for the U.S. Preventive Services Task Force. Rockville, MD. Agency for Healthcare Research and Quality. 2009. [pmid: 20722166].
46 Wallace BC, Small K, Brodley CE, et al. Deploying an interactive machine learning system in an evidence-based practice center: abstrackr. Proceedings of the ACM International Health Informatics Symposium. 2012:819-24. PMID: None.
47 Human development report 2013. The rise of the south: human progress in a diverse world. New York. United Nations Development Program. 2013. PMID: None.
48 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. Apr. 2001;20(3 Suppl):21-35. [pmid: 11306229].
49 Wells GA, Shea B, O'Connell D, et al. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analysis. Ottawa. Ottawa Hospital Research Institute. 2014. http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp. January 21, 2014. PMID: None.
50 Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
51 Effect of aspirin alone and aspirin plus dipyridamole in early diabetic retinopathy. A multicenter randomized controlled clinical trial. The DAMAD Study Group. Diabetes. Apr. 1989;38(4):491-8. [pmid: 2647556].
52 Silagy CA, McNeil JJ, Donnan GA, et al. Adverse effects of low-dose aspirin in a healthy elderly population. Clin Pharmacol Ther. Jul. 1993;54(1):84-9. [pmid: 8330469].
53 Nelson MR, Reid CM, Ames DA, et al. Feasibility of conducting a primary prevention trial of low-dose aspirin for major adverse cardiovascular events in older people in Australia: results from the ASPirin in Reducing Events in the Elderly (ASPREE) pilot study. Med J Aust. Jul. 21. 2008;189(2):105-9. [pmid: 18637782].
54 Juul-Moller S, Edvardsson N, Jahnmatz B, et al. Double-blind trial of aspirin in primary prevention of myocardial infarction in patients with stable chronic angina pectoris. The Swedish Angina Pectoris Aspirin Trial (SAPAT) Group. Lancet. Dec. 12. 1992;340(8833):1421-5. [pmid: 1360557].
55 Fortmann SP, Burda BU, Senger CA, et al. Vitamin and mineral supplements in the primary prevention of cardiovascular disease and cancer: An updated systematic evidence review for the U.S. Preventive Services Task Force. Ann Intern Med. Dec. 17. 2013;159(12):824-34. [pmid: 24217421].
56 Fu R, Gartlehner G, Grant M, et al. Conducting quantitative synthesis when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. Nov. 2011;64(11):1187-97. [pmid: 21477993].
57 Belch J, MacCuish A, Campbell I, et al. The prevention of progression of arterial disease and diabetes (POPADAD) trial: factorial randomised placebo controlled trial of aspirin and antioxidants in patients with diabetes and asymptomatic peripheral arterial disease. BMJ. 2008;337:a1840. [pmid: 18927173].
58 Brighton TA, Eikelboom JW, Mann K, et al. Low-dose aspirin for preventing recurrent venous thromboembolism. N Engl J Med. Nov. 22. 2012;367(21):1979-87. [pmid: 23121403].
59 Aspirin in coronary heart disease. The Coronary Drug Project Research Group. Circulation. Dec. 1980;62(6 Pt 2):V59-V62. [pmid: 7002353].
60 Cook NR, Lee IM, Gaziano JM, et al. Low-dose aspirin in the primary prevention of cancer: the Women's Health Study: a randomized controlled trial. JAMA. Jul. 6. 2005;294(1):47-55. [pmid: 15998890].
61 de Gaetano G. Low-dose aspirin and vitamin E in people at cardiovascular risk: a randomised trial in general practice. Collaborative Group of the Primary Prevention Project. Lancet. Jan. 13. 2001;357(9250):89-95. [pmid: 11197445].
62 Diener HC. European Stroke Prevention Study 2. Efficacy and safety data. J Neurol Sci. Sep. 1997;151(Suppl 1):S1-S77. [pmid: 9276859].
63 Secondary prevention in non-rheumatic atrial fibrillation after transient ischaemic attack or minor stroke. EAFT (European Atrial Fibrillation Trial) Study Group. Lancet. Nov. 20. 1993;342(8882):1255-62. [pmid: 7901582].
64 Aspirin effects on mortality and morbidity in patients with diabetes mellitus. Early treatment Diabetic Retinopathy Study report 12. ETDRS Investigators. JAMA. 1992;268(10):1292-300. [pmid: 1507375].
65 Farrell B, Godwin J, Richards S, et al. The United Kingdom transient ischaemic attack (UK-TIA) aspirin trial: final results. J Neurol Neurosurg Psychiatry. Dec. 1991;54(12):1044-54. [pmid: 1783914].
66 Fowkes FG, Price JF, Stewart MC, et al. Aspirin for prevention of cardiovascular events in a general population screened for a low ankle brachial index: a randomized controlled trial. JAMA. Mar. 3. 2010;303(9):841-8. [pmid: 20197530].
67 Hansson L, Zanchetti A, Carruthers SG, et al. Effects of intensive blood-pressure lowering and low-dose aspirin in patients with hypertension: principal results of the Hypertension Optimal Treatment (HOT) randomised trial. HOT Study Group. Lancet. Jun. 13. 1998;351(9118):1755-62. [pmid: 9635947].
68 Logan RF, Grainge MJ, Shepherd VC, et al. Aspirin and folic acid for the prevention of recurrent colorectal adenomas. Gastroenterology. Jan. 2008;134(1):29-38. [pmid: 18022173].
69 Thrombosis Prevention Trial: randomised trial of low-intensity oral anticoagulation with warfarin and low-dose aspirin in the primary prevention of ischaemic heart disease in men at increased risk. The Lancet. Jan. 24. 1998;351(9098):233-41. [pmid: 9457092].
70 Ogawa H, Nakayama M, Morimoto T, et al. Low-dose aspirin for primary prevention of atherosclerotic events in patients with type 2 diabetes: a randomized controlled trial. JAMA. Nov. 12. 2008;300(18):2134-41. [pmid: 18997198].
71 Persantine and aspirin in coronary heart disease. The Persantine-Aspirin Reinfarction Study Research Group. Circulation. Sep. 1980;62(3):449-61. [pmid: 7398002].
72 Peto R, Gray R, Collins R, et al. Randomised trial of prophylactic daily aspirin in British male doctors. Br Med J (Clin Res Ed). Jan. 30. 1988;296(6618):313-6. [pmid: 3125882].
73 Final report on the aspirin component of the ongoing Physicians' Health Study. N Engl J Med. Jul. 20. 1989;321(3):129-35. [pmid: 2664509].
74 The Salt Collaborative Group. Swedish Aspirin Low-dose Trial (SALT) of 75 mg aspirin as secondary prophylaxis after cerebrovascular ischaemic events. The Lancet. Nov. 30. 1991;338(8779):1345-9. [pmid: 1682734].
75 A randomized, controlled trial of aspirin in persons recovered from myocardial infarction. JAMA. Feb. 15. 1980;243(7):661-9. [pmid: 6985998].
76 Stroke Prevention in Atrial Fibrillation Study. Final results. Circulation. Aug. 1991;84(2):527-39. [pmid: 1860198].
77 Baron JA, Cole BF, Sandler RS, et al. A randomized trial of aspirin to prevent colorectal adenomas. N Engl J Med. Mar. 6. 2003;348(10):891-9. [pmid: 12621133].
78 Becattini C, Agnelli G, Schenone A, et al. Aspirin for preventing the recurrence of venous thromboembolism. N Engl J Med. May. 24. 2012;366(21):1959-67. [pmid: 22621626].
79 Cote R, Battista RN, Abrahamowicz M, et al. Lack of effect of aspirin in asymptomatic patients with carotid bruits and substantial carotid narrowing. The Asymptomatic Cervical Bruit Study Group. Ann Intern Med. Nov. 1. 1995;123(9):649-55. [pmid: 7574219].
80 Petersen P, Boysen G, Godtfredsen J, et al. Placebo-controlled, randomised trial of warfarin and aspirin for prevention of thromboembolic complications in chronic atrial fibrillation. The Copenhagen AFASAK study. Lancet. Jan. 28. 1989;1(8631):175-9. [pmid: 2563096].
81 Sato H, Ishikawa K, Kitabatake A, et al. Low-dose aspirin for prevention of stroke in low-risk patients with atrial fibrillation: Japan Atrial Fibrillation Stroke Trial. Stroke. Feb. 2006;37(2):447-51. [pmid: 16385088].
82 Benamouzig R, Deyra J, Martin A, et al. Daily soluble aspirin and prevention of colorectal adenoma recurrence: one-year results of the APACC trial. Gastroenterology. Aug. 2003;125(2):328-36. [pmid: 12891533].
83 Huang ES, Strate LL, Ho WW, et al. A prospective study of aspirin use and the risk of gastrointestinal bleeding in men. PLoS ONE. 2010;5(12):e15721. [pmid: 21209949].
84 Huang ES, Strate LL, Ho WW, et al. Long-term use of aspirin and the risk of gastrointestinal bleeding. Am J Med. May. 2011;124(5):426-33. [pmid: 21531232].
85 de Berardis G, Lucisano G, D'Ettorre A, et al. Association of aspirin use with major bleeding in patients with and without diabetes. JAMA. Jun. 6. 2012;307(21):2286-94. [pmid: 22706834].
86 Ekstrom N, Cederholm J, Zethelius B, et al. Aspirin treatment and risk of first incident cardiovascular diseases in patients with type 2 diabetes: an observational study from the Swedish National Diabetes Register. BMJ Open. 2013;3(4):2013. [pmid: 23604419].
87 Baigent C, Blackwell L, Collins R, et al. Aspirin in the primary and secondary prevention of vascular disease: collaborative meta-analysis of individual participant data from randomised trials. Lancet. May. 30. 2009;373(9678):1849-60. [pmid: 19482214].
88 Cook NR, Lee IM, Zhang SM, et al. Alternate-day, low-dose aspirin and cancer risk: long-term observational follow-up of a randomized trial. Ann Intern Med. Jul. 16. 2013;159(2):77-85. [pmid: 23856681].
89 Rothwell PM. Treating individuals 2. Subgroup analysis in randomised controlled trials: importance, indications, and interpretation. Lancet. Jan. 8. 2005;365(9454):176-86. [pmid: 15639301].
90 Sun X, Briel M, Busse JW, et al. Credibility of claims of subgroup effects in randomised controlled trials: systematic review. BMJ. 2012;344:e1553. [pmid: 22422832].
91 Christen WG, Glynn RJ, Chew EY, et al. Low-dose aspirin and medical record-confirmed age-related macular degeneration in a randomized trial of women. Ophthalmology. Dec. 2009;116(12):2386-92. [pmid: 19815293].
92 Christen WG, Glynn RJ, Ajani UA, et al. Age-related maculopathy in a randomized trial of low-dose aspirin among US physicians. Arch Ophthalmol. Aug. 2001;119(8):1143-9. [pmid: 11483080].
93 Hallas J, Lauritsen J, Villadsen HD, et al. Nonsteroidal anti-inflammatory drugs and upper gastrointestinal bleeding, identifying high-risk groups by excess risk estimates. Scand J Gastroenterol. May. 1995;30(5):438-44. [pmid: 7638569].
94 Iso H, Hennekens CH, Stampfer MJ, et al. Prospective study of aspirin use and risk of stroke in women. Stroke. Sep. 1999;30(9):1764-71. [pmid: 10471421].
95 Hernandez-Diaz S, Rodriguez LA. Incidence of serious upper gastrointestinal bleeding/perforation in the general population: review of epidemiologic studies. J Clin Epidemiol. Feb. 2002;55(2):157-63. [pmid: 11809354].
96 Derry S, Loke YK. Risk of gastrointestinal haemorrhage with long term use of aspirin: meta-analysis. BMJ. Nov. 11. 2000;321(7270):1183-7. [pmid: 11073508].
97 Garcia Rodriguez LA, Hernandez-Diaz S, de Abajo FJ. Association between aspirin and upper gastrointestinal complications: systematic review of epidemiologic studies. Br J Clin Pharmacol. Nov. 2001;52(5):563-71. PMID:. [pii: 1476]. [pmid: 11736865].
98 Hernandez-Diaz S, Garcia Rodriguez LA. Cardioprotective aspirin users and their excess risk of upper gastrointestinal complications. BMC Med. 2006;4:22. [pmid: 16987411].
99 Soriano LC, Rodriguez LA. Risk of Upper Gastrointestinal Bleeding in a Cohort of New Users of Low-Dose ASA for Secondary Prevention of Cardiovascular Outcomes. Frontiers in Pharmacology. 2010;1:126. PMID: None. [pmid: 21811460].
100 Sostres C, Lanas A. Gastrointestinal effects of aspirin. Nat Rev Gastroenterol Hepatol. Jul. 2011;8(7):385-94. [pmid: 21647198].
101 Dalton SO, Sorensen HT, Johansen C. SSRIs and upper gastrointestinal bleeding: what is known and how should it influence prescribing?. CNS Drugs. 2006;20(2):143-51. [pmid: 16478289].
102 Garcia Rodriguez LA, Lin KJ, Hernandez-Diaz S, et al. Risk of upper gastrointestinal bleeding with low-dose acetylsalicylic acid alone and in combination with clopidogrel and other medications. Circulation. Mar. 15. 2011;123(10):1108-15. [pmid: 21357821].
103 Lee YC, Shau WY, Chang CH, et al. Antidepressant use and the risk of upper gastrointestinal bleeding in psychiatric patients: a nationwide cohort study in Taiwan. J Clin Psychopharmacol. Aug. 2012;32(4):518-24. [pmid: 22722503].
104 Sorensen HT, Mellemkjaer L, Blot WJ, et al. Risk of upper gastrointestinal bleeding associated with use of low-dose aspirin. Am J Gastroenterol. Sep. 2000;95(9):2218-24. [pmid: 11007221].
105 Lanas A, Polo-Tomas M, Casado-Arroyo R. The aspirin cardiovascular/gastrointestinal risk calculator--a tool to aid clinicians in practice. Aliment Pharmacol Ther. Apr. 2013;37(7):738-48. [pmid: 23413984].
106 Thiagarjan P, Jankowski JA. Tipping the balance: benefits and risks of aspirin in chemoprevention of colorectal cancers. Curr Colorectal Cancer Reports. 2013;9(1):1-8. PMID: None.
107 Kolber MR, Korownyk C. An aspirin a day? Aspirin use across a spectrum of risk: cardiovascular disease, cancers and bleeds. Expert Opin Pharmacother. Feb. 2014;15(2):153-7. [pmid: 24206142].
108 Siller-Matula JM. Hemorrhagic complications associated with aspirin: an underestimated hazard in clinical practice?. JAMA. Jun. 6. 2012;307(21):2318-20. [pmid: 22706838].
109 Hedberg J, Sundstrom J, Thuresson M, et al. Low-dose acetylsalicylic acid and gastrointestinal ulcers or bleeding--a cohort study of the effects of proton pump inhibitor use patterns. J Intern Med. Oct. 2013;274(4):371-80. [pmid: 23800296].
110 Campbell CL, Smyth S, Montalescot G, et al. Aspirin dose for the prevention of cardiovascular disease: a systematic review. [Review] [61 refs]. JAMA. May. 9. 2007;297(18):2018-24. [pmid: 17488967].
111 Serebruany VL, Steinhubl SR, Berger PB, et al. Analysis of risk of bleeding complications after different doses of aspirin in 192,036 patients enrolled in 31 randomized controlled trials. Am J Cardiol. May. 15. 2005;95(10):1218-22. [pmid: 15877994].
112 de Abajo FJ, Garcia Rodriguez LA. Risk of upper gastrointestinal bleeding and perforation associated with low-dose aspirin as plain and enteric-coated formulations. BMC Clin Pharmacol. 2001;1:1. [pmid: 11228592].
113 McQuaid KR, Laine L. Systematic review and meta-analysis of adverse events of low-dose aspirin and clopidogrel in randomized controlled trials. Am J Med. Aug. 2006;119(8):624-38. [pmid: 16887404].
114 Jaspers Focks J, Tielemans MM, van Rossum LG, et al. Gastrointestinal symptoms in low-dose aspirin users: a comparison between plain and buffered aspirin. Neth Heart J. Mar. 2014;22(3):107-12. [pmid: 24522950].
115 Martin Merino E, Johansson S, Nagy P, et al. Effect of baseline gastrointestinal risk and use of proton pump inhibitors on frequency of discontinuation of aspirin for secondary cardiovascular prevention in United kingdom primary care. American Journal of Cardiology. Oct. 15. 2013;112(8):1075-82. [pmid: 23831164].
116 Sylvester KW, Cheng JW, Mehra MR. Esomeprazole and aspirin fixed combination for the prevention of cardiovascular events. Vasc Health Risk Manag. 2013;9:245-54. [pmid: 23696706].
117 Bowman L. ASCEND: A Study of Cardiovascular Events iN Diabetes. http://clinicaltrialsgov/ct2/show/NCT00135226?term=cardiovascular+events+prevention+trial+in+diabetes&rank=4. 2011. PMID: None.
118 de Berardis G, Sacco M, Evangelista V, et al. Aspirin and simvastatin Combination for Cardiovascular Events Prevention Trial in Diabetes (ACCEPT-D): design of a randomized study of the efficacy of low-dose aspirin in the prevention of cardiovascular events in subjects with diabetes mellitus treated with statins. Trials. 2007;8:21. [pmid: 17725825].
119 Gray J, Mao JT, Szabo E, et al. Lung cancer chemoprevention: ACCP evidence-based clinical practice guidelines. 2nd Edition. Chest. Sep. 2007;132(3 Suppl):56S-68S. [pmid: 17873160].
120 Spechler SJ, Sharma P, Souza RF, et al. American Gastroenterological Association medical position statement on the management of Barrett's esophagus. Gastroenterology. Mar. 2011;140(3):1084-91. [pmid: 21376940].
121 Allum WH, Blazeby JM, Griffin SM, et al. Guidelines for the management of oesophageal and gastric cancer. Gut. Nov. 2011;60(11):1449-72. [pmid: 21705456].
122 Cuzick J, Otto F, Baron JA, et al. Aspirin and non-steroidal anti-inflammatory drugs for cancer prevention: an international consensus statement. Lancet Oncol. May. 2009;10(5):501-7. [pmid: 19410194].
123 Ridker PM, Cook NR, Lee IM, et al. A randomized trial of low-dose aspirin in the primary prevention of cardiovascular disease in women. N Engl J Med. Mar. 31. 2005;352(13):1293-304. [pmid: 15753114].
124 Aspirin Myocardial Infarction Study: design, methods and baseline results. Washington, D.C. U.S. Department of Health and Human Services. 1980. PMID: None.
125 Kurata JH, Abbey DE. The effect of chronic aspirin use on duodenal and gastric ulcer hospitalizations. J Clin Gastroenterol. Jun. 1990;12(3):260-6. [pmid: 2193980].
126 Strate LL, Liu YL, Huang ES, et al. Use of aspirin or nonsteroidal anti-inflammatory drugs increases risk for diverticulitis and diverticular bleeding. Gastroenterology. May. 2011;140(5):1427-33. [pmid: 21320500].
127 Manson JE, Stampfer MJ, Colditz GA, et al. A prospective study of aspirin use and primary prevention of cardiovascular disease in women. JAMA. Jul. 24. 1991;266(4):521-7. [pmid: 2061978].
128 Mills EJ, Wu P, Alberton M, et al. Low-dose Aspirin and Cancer Mortality: A Meta-analysis of Randomized Trials. The American Journal of Medicine. Jun. 2012;125(6):560-7. [pmid: 22513195].
129 Bosetti C, Rosato V, Gallus S, et al. Aspirin and cancer risk: a quantitative review to 2011. Annals of Oncology. 2012;23(6):1403-15. [pmid: 22517822].
130 Algra AM, Rothwell PM. Effects of regular aspirin on long-term cancer incidence and metastasis: a systematic comparison of evidence from observational studies versus randomised trials. Lancet Oncol. May. 2012;13(5):518-27. [pmid: 22440112].
131 Oh SW, Myung SK, Park JY, et al. Aspirin use and risk for lung cancer: a meta-analysis. Annals of Oncology. 2011;22(11):2456-65. [pmid: 21385885].
132 McCormack VA, Hung RJ, Brenner DR, et al. Aspirin and NSAID use and lung cancer risk: a pooled analysis in the International Lung Cancer Consortium (ILCCO). Cancer Causes Control. Dec. 2011;22(12):1709-20. [pmid: 21987079].
133 Xu J, Yin Z, Gao W, et al. Meta-analysis on the association between nonsteroidal anti-inflammatory drug use and lung cancer risk. Clinical Lung Cancer. 2012;13(1):44-51. [pmid: 21813335].
134 Takkouche B, Regueira-Mendez C, Etminan M. Breast cancer and use of nonsteroidal anti-inflammatory drugs: a meta-analysis. J Natl Cancer Inst. Oct. 15. 2008;100(20):1439-47. [pmid: 18840819].
135 Zhao YS, Zhu S, Li XW, et al. Association between NSAIDs use and breast cancer risk: a systematic review and meta-analysis. Breast Cancer Research and Treatment. 2009;117(1):141-50. [pmid: 18979210].
136 Mangiapane S, Blettner M, Schlattmann P. Aspirin use and breast cancer risk: a meta-analysis and meta-regression of observational studies from 2001 to 2005. Pharmacoepidemiology and Drug Safety. 2008;17(2):115-24. [pmid: 17955496].
137 Luo T, Yan HM, He P, et al. Aspirin use and breast cancer risk: a meta-analysis. Breast Cancer Res Treat. Jan. 2012;131(2):581-7. [pmid: 21898115].
138 Mahmud SM, Franco EL, Aprikian AG. Use of nonsteroidal anti-inflammatory drugs and prostate cancer risk: a meta-analysis. Int J Cancer. Oct. 1. 2010;127(7):1680-91. [pmid: 20091856].
139 Abnet CC, Freedman ND, Kamangar F, et al. Non-steroidal anti-inflammatory drugs and risk of gastric and oesophageal adenocarcinomas: results from a cohort study and a meta-analysis. Br J Cancer. Feb. 10. 2009;100(3):551-7. [pmid: 19156150].
140 Yang P, Zhou Y, Chen B, et al. Aspirin use and the risk of gastric cancer: a meta-analysis. Digestive Diseases and Sciences. 2010;55(6):1533-9. [pmid: 19672710].
141 Tian W, Zhao Y, Liu S, et al. Meta-analysis on the relationship between nonsteroidal anti-inflammatory drug use and gastric cancer. European Journal of Cancer Prevention. 2010;19(4):288-98. [pmid: 20386312].
142 Wang F, Lv ZS, Fu YK. Nonsteroidal anti-inflammatory drugs and esophageal inflammation - Barrett's esophagus - adenocarcinoma sequence: a meta-analysis. Diseases of the Esophagus. 2011;24(5):318-24. [pmid: 21166737].
143 Sun L, Yu S. Meta-analysis: non-steroidal anti-inflammatory drug use and the risk of esophageal squamous cell carcinoma. Dis Esophagus. Nov. 2011;24(8):544-9. [pmid: 21539676].
144 Liao LM, Vaughan TL, Corley DA, et al. Nonsteroidal anti-inflammatory drug use reduces risk of adenocarcinomas of the esophagus and esophagogastric junction in a pooled analysis. Gastroenterology. Mar. 2012;142(3):442-52. [pmid: 22108196].
145 Armitage JM. ASCEND: A Study of Cardiovascular Events iN Diabetes. Washington, D.C. National Institute of Health. 2014. http://clinicaltrials.gov/ct2/show/NCT00135226?term=cardiovascular+events+prevention+trial+in+diabetes&rank=4. PMID: None.
146 Study design of ASPirin in Reducing Events in the Elderly (ASPREE): A randomized, controlled trial. Contemp Clin Trials. Oct. 7. 2013;36(2):555-64. [pmid: 24113028].
147 Grimm R, McNeil J. Aspirin in reducing events in the elderly (ASPREE). Minneapolis. Berman Center for Outcomes and Clinical Research. 2013. http://www.aspree.org/AUS/aspree-content/aspree-study-details/about-aspree.aspx. May 8, 2013. PMID: None.
148 A study to assess the efficacy and safety of enteric-coated acetylsalicylic acid in patients with moderate risk of cardiovascular disease (ARRIVE). Pittsburgh, PA. Bayer Healthcare LLC. 2013. http://clinicaltrials.gov/show/NCT00501059. May 8, 2013. PMID: None.
149 Selak V, Elley CR, Crengle S, et al. IMProving Adherence using Combination Therapy (IMPACT): design and protocol of a randomised controlled trial in primary care. Contemp Clin Trials. Nov. 2011;32(6):909-15. [pmid: 21777702].
150 Teramoto T, Shimada K, Uchiyama S, et al. Rationale, design, and baseline data of the Japanese Primary Prevention Project (JPPP)-a randomized, open-label, controlled trial of aspirin versus no aspirin in patients with multiple risk factors for vascular events. Am Heart J. Mar. 2010;159(3):361-9. [pmid: 20211296].