# Abbreviations

AAA: Aspirin for Asymptomatic Atherosclerosis
ACBS: Asymptomatic Cervical Bruit Study
ACCEPT-D: Aspirin and Simvastatin Combination for Cardiovascular Events Prevention Trial in Diabetes
AFASAK: Atrial Fibrillation, Aspirin and Anticoagulation
AFPPS: Aspirin/Folate Polyp Prevention Study
AHRQ: Agency for Healthcare Research and Quality
AMIS: Aspirin Myocardial Infarction Study
AMSTAR: Assessment of Multiple Systematic Reviews
APACC: Association por la Prevention par l'Aspirine due Cancer Colorectal
ARMD: age-related macular degeneration
ARR: absolute risk reduction
ASA: acetylsalicylic acid
ASCEND: A Study of Cardiovascular Events in Diabetes
ASPIRE: Aspirin to Prevent Recurrent Venous Thromboembolism
ASPREE: ASPirin in Reducing Events in Elderly
ATT: Antithrombotic Trialists
BMD: British Medical Doctors
BMI: body mass index
BMJ: British Medical Journal
CCT: controlled clinical trial
CDPA: Coronary Drug Project Aspirin
CHD: coronary heart disease
CI: confidence interval
COX: cyclooxygenase
CRC: colorectal cancer
CVD: cardiovascular disease
DNA: deoxyribonucleic acid
EAFT: European Atrial Fibrillation Trial
e.g.: for example
ESPS-2: European Stroke Prevention Study 2
ETDRS: Early Treatment Diabetic Retinopathy
FDA: Food and Drug Administration
GI: gastrointestinal
HOT: Hypertension Optimal Treatment
HPS: Health Professional Study
HR: hazard ratio
ICD: International classification of disease
JAST: Japanese Atrial Fibrillation Trial
JPAD: Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes
k: number of studies
kg: kilogram
KQ: key question
mg: milligram(s)
MI: myocardial infarction
mm Hg: millimeters of mercury
n: number of participants
NHS: Nurse's Health Study
NNH: number needed to harm
NNT: number needed to treat
NSAIDs: nonsteroidal anti-inflammatory drugs
OR: odds ratio
PARIS: Persantine-Aspirin Reinfarction Study
PHS: Physician's Health Study
POPADAD: Prevention of Progression of Arterial Disease and Diabetes
PPI: proton pump inhibitor
PPP: Primary Prevention Project
RCT: randomized controlled trial
RR: relative risk
SALT: Swedish Aspirin Low-dose Trial
SAPAT: Swedish Angina Pectoris Aspirin Trial
SNDR: Swedish National Diabetes Register
SPAF: Stroke Prevention in Atrial Fibrillation
SSRI: selective serotonin reuptake inhibitor
TIA: transient ischemic attack
TPT: Thrombosis Prevention Trial
U.K.: United Kingdom
ukCAP: United Kingdom Colorectal Adenoma Prevention
UK-TIA: United Kingdom Transient Ischemic Attack
U.S.: United States
USPSTF: United States Preventive Services Task Force
WARFASA: Aspirin for the Prevention of Recurrent Venous Thromboembolism
WHS: Women's Health Study