# [Preface]

This systematic review was conducted in coordination with two other systematic reviews1,2 and a decision model3 to support the U.S. Preventive Services Task Force (USPSTF) in making updated clinical preventive service recommendations for aspirin in primary prevention. The original literature searches were completed in June 2014. In order to prepare a set of manuscripts derived from these reviews, we conducted updated literature searches through January 6, 2015 to identify newly published information since the original searches.

A single open-label randomized, controlled clinical trial in a cardiovascular disease (CVD) primary prevention population—the Japanese Primary Prevention Project (JPPP)4—was the only additional clinical research report located through the updated searches that met inclusion/exclusion criteria for any of the reviews. Outcomes from this study (nonfatal myocardial infarction [MI], nonfatal stroke [nonfatal cerebral infarction, intracranial hemorrhage, and undefined cardiovascular events], CVD mortality [fatal MI, cerebral infarction, intracranial hemorrhage, subarachnoid hemorrhage, and other fatal cardiovascular events], hemorrhagic stroke [fatal and nonfatal intracranial hemorrhage], and all-cause mortality) were incorporated into the final evidence reviewed by the USPSTF and resulted in updated inputs into the decision analysis.

This systematic review has NOT been updated to reflect the incorporation of results from JPPP. Updated results are reflected in the manuscript derived from this review, which is available for public comment at http://www.uspreventiveservicestaskforce.org. Results for this systematic review for outcomes unrelated to those reported in JPPP are current through January 6, 2015. No further updated literature searches have been undertaken.

## References

1 Chubak J, Kamineni A, Buist DS, et al. Aspirin Use for the Prevention of Colorectal Cancer: An Updated Systematic Evidence Review for the U.S. Preventive Services Task Force. Evidence SynthesisNo. 133. AHRQ Publication No. 15-05228-EF-1. Rockville, MD. Agency for Healthcare Research and Quality. 2015.
2 Guirguis-Blake JM, Evans CV, Senger CA, et al. Aspirin for the Primary Prevention of Cardiovascular Events: A Systematic Evidence Review for the U.S. Preventive Services Task Force. Evidence Synthesis No. 131. Rockville, MD. Agency for Healthcare Research and Quality. 2015.
3 Dehmer SP, Maciosek MV, Flottemesch TJ. Aspirin Use to Prevent Cardiovascular Disease and Colorectal Cancer: A Decision Analysis. AHRQ Publication No. 15-05229-EF-1. Rockville, MD. Agency for Healthcare Research and Quality. 2015.
4 Ikeda Y, Shimada K, Teramoto T, et al. Low-dose aspirin for primary prevention of cardiovascular events in Japanese patients 60 years or older with atherosclerotic risk factors: a randomized clinical trial. JAMA. 2014;312(23):2510-20. [pmid: 25401325].