# Discussion

## Summary of Evidence

This review focused on the impact of ASA use on all cancers combined because data were too sparse to allow estimates of cancer incidence or mortality for individual cancers (with the exception of CRC, which is covered in a separate report). A summary of the evidence for specific cancers taken from previous systematic reviews and meta-analyses addressing trials, cohort studies, and case-control studies is provided in Appendix G. Ongoing research will be important in further delineating specific cancer effects.

Similarly, our interpretation of the evidence is primarily based in the context of determining any additional benefit on cancer incidence or mortality in those taking ASA for CVD primary prevention. We did not focus on additional cancer benefits in those taking ASA for CVD secondary prevention since that use is outside the usual scope of the USPSTF and is firmly recommended, even without considering potential additional beneficial outcomes.

We attempted to examine a coherent body of evidence to determine additional all cancer incidence and mortality effects in those taking ASA for CVD primary prevention, as well as considering the most applicable evidence for estimating all-cause mortality and ASA-related bleeding harms. The available bodies of evidence for each of the important outcomes in this review varied considerably in the populations, dosages, and durations of treatment they represent. There was further variation in definitions of important outcomes. Primarily due to the differing timeframe over which risks and benefits might be expected to occur (within the first year for bleeding risks to at least 5 and perhaps 10 to 20 years for many cancer effects), many previous analyses of cancer outcomes have relied on subsets of studies that offer longer-term followup. However, these also differ somewhat or substantially in terms of the populations and interventions they represent from the body of CVD primary prevention trials. Thus, due to the clinical application of interest for this review, our primary analyses were focused on the cancer impact as shown in the CVD primary prevention trials that form the basis for the current USPSTF systematic review,41 with a further emphasis on very low-dose ASA (≤100 mg daily or every other day), in line with the USPSTF approach in 2009.^31^ We conducted a series of sensitivity analyses within this set of studies as well as within the larger set of studies representing broader primary and secondary CVD prevention to compare and contrast our findings with those of other recent reports.

We first summarize our findings at the population level of the relative effects of ASA on cancer, all-cause mortality, and bleeding outcomes, which were the major harms demonstrated. We then consider the importance of baseline risk in moderating the absolute effect of ASA and explore appropriate baseline bleeding rate estimation and its modification by bleeding risk factors and ASA. Finally, we consider challenges and future directions in applying this evidence to individuals.

### Aspirin Effects on Cancer Mortality

When focused on the 10 CVD primary prevention trials, our main analysis, we found nonsignificantly reduced mortality due to cancer (RR, 0.96 [95% CI, 0.87 to 1.06]). We found no difference when we stratified results by time period of followup (<5 vs. ≥5 years), although trials with longer-term followup tended to show a larger cancer mortality reduction (RR, 0.94) than those lasting less than 5 years (RR, 1.01). Sensitivity analyses (Table 9) excluding higher dosages above 100 mg had little effect on the point estimate for cancer mortality benefit (RR, 0.95), while excluding studies of every other day dosages increased the suggested benefit (RR, 0.93). When we combined all trials in our review (primary and secondary CVD prevention), the overall estimate changed little (RR, 0.93). These added studies, however, primarily had very short-term followup (<4 years) in which mortality effects from cancer prevention would be unlikely. By restricting to treatment durations of 4 years or greater and considering only trials utilizing daily ASA dosing only, we found a statistically significant cancer mortality benefit (RR, 0.83 [95% CI, 0.70 to 0.98]) among primary and secondary CVD prevention trials, close to that reported by Rothwell and colleagues.

Our findings differ from those reported in a study-level meta-analysis of eight trials; Rothwell and colleagues (2011) found a 21 percent statistically significant reduction (95% CI, 8% to 32%) in cancer mortality using a somewhat different set of included studies than our CVD primary prevention trials analysis.8 These studies differed in that Rothwell and colleagues required daily ASA use for at least 4 years and included both secondary and primary CVD trial data. Working from our set of 10 CVD primary prevention trials, we could almost reproduce their results by eliminating large U.S. studies of alternate day ASA use (PHS, WHS),60,73 restricting to trials with at least 4 years duration, and adding results from one secondary prevention trial (UK-TIA) (our analysis of this restricted set of studies produced an 18% statistically significant cancer mortality benefit compared to their estimate of 21%).65 We believe our original analysis, which includes the alternate day studies, is preferable since alternate day low-dose ASA use is an important part of the evidence base estimating CVD primary prevention, and cancer impact by alternate day dosing is now known to be possible. WHS has recently demonstrated a reduction in CRC incidence with alternate day dosing and followup beyond 10 years.88

Data from seven of the eight trials summarized in a study-level meta-analysis by Rothwell and colleagues (2011) were further analyzed by the same group through an IPD meta-analysis.8 Time-to-event data suggested an impact on cancer mortality primarily in deaths after 5 years. In analyses that included only a smaller set of three primary and secondary prevention trials with posttrial followup to 20 years, Rothwell and colleagues found a significant reduction (21% to 23%) in cancer mortality at 0 to 10 years as well as at 10 to 20 years in patients with at least 5 years of scheduled ASA treatment duration (n=10,502; 1,378 cancer deaths). However, these results may not be broadly applicable to a CVD primary prevention population taking low-dose ASA. These three trials (TPT, UK-TIA, BMD) primarily utilized higher dosages of ASA (300 to 1,200 mg daily) and almost exclusively represented men, 31 to 53 percent of whom were current smokers.65,69,72 The applicability of these trials is important when considering ASA's effect on CRC mortality as well, since these trials represent three of the four studies demonstrating long-term CRC mortality benefits.40 Whether these studies might separately represent an identifiable primary care population eligible and willing to take daily ASA for at least 5 years for cancer prevention is not clear, but this was not the main purpose of our review.

None of the main findings from our review suggested a statistically significant benefit for all-cancer mortality in primary and secondary CVD populations taking ASA, and others have concluded no protective role for ASA on cancer mortality in the CVD primary prevention population based on very similar analyses.44 All of our pooled estimates were imprecise, with relatively wide CIs consistent with slight harm, no benefit, or substantial benefit, depending on the body of evidence summarized. Better precision could be gained through longer followup and time-to-event analyses among all available CVD primary prevention trials.

### Aspirin Effects on All-Cause Mortality

All-cause mortality was significantly reduced (RR, 0.94 [95% CI, 0.88 to 0.99]) in the 10 CVD primary prevention trials and when all studies were retained in the analysis. These results, however, were somewhat sensitive to changes in which data were utilized (Table 9). For instance, when we substituted longer-term mortality effects at 17.5 years from WHS for 10-year data, point estimates for all-cause mortality moved closer to 1.0 and none of the sensitivity analyses were statistically significant. Also, we found no statistically significant effect in any of our sensitivity analyses when combining only trials most applicable to a CVD-cancer primary prevention application (i.e., very low-dose ASA [≤100 mg/day], likely sufficient for cancer as well as cardiovascular effects), although these results could reflect reduced power. In this analysis of studies most applicable to a CVD-cancer primary prevention application, currently available results are consistent with some benefit (6%), but we cannot rule out substantial benefit, no effect, or slight harm. When longer-term WHS data are substituted, all-cause mortality results are consistent with a lesser benefit, but we cannot rule out some benefit, no effect, or some harm.

When we combined primary and secondary prevention trials, all-cause mortality results showed a significant and consistent benefit (RR, 0.93 [95% CI, 0.89 to 0.98]), with no change when restricting to dosages of 100 mg or less (Table 9). Since these added studies mostly contributed very short-term followup (<4 years) and resulted in no significant impact on cancer mortality, the mechanism for mortality effects must be through CVD or other causes. This interpretation would be consistent with the IPD meta-analysis by the ATT Collaboration that showed an all-cause mortality benefit in secondary, but not primary, prevention trials.87 This interpretation would also be consistent with a study-level meta-analysis by Rothwell and colleagues (2012) that found a reduction in nonvascular deaths (OR, 0.88 [95% CI, 0.78 to 0.98]), but not vascular deaths (OR, 0.99 [95% CI, 0.87 to 1.12]), when combining 12 trials of CVD primary prevention populations testing daily ASA of any dosage.10

Differences in observed or expected all-cause mortality effects between primary and secondary prevention populations likely reflect the relative impact of nonvascular deaths, since these have been reported to vary significantly in their relative contribution to all-cause mortality (representing only 10% to 20% of total deaths in high-dose ASA trials among those with existing CVD to up to 70% of deaths in those taking low-dose ASA for primary prevention). In the CVD primary prevention trials in our review, about two thirds of all deaths were attributed to nonvascular causes.44 Nonvascular deaths, however, are not clearly due to cancers. Just 61 percent of nonvascular deaths in these CVD primary prevention trials were attributed to cancer,44 which is quite consistent with the 58 percent of all nonvascular deaths attributed to cancer in 34 primary and secondary prevention trials.10 Thus, approximately 20 to 25 percent of all deaths in CVD primary prevention trials were due to nonvascular noncancer causes, and among all the mortality subtypes, nonvascular noncancer deaths tended to show the greatest mortality reduction from ASA use (OR, 0.90 [95% CI, 0.76 to 1.07]).44

We conclude that there would not be certain benefit on all-cause mortality in a CVD primary prevention population taking very low-dose ASA (≤100 mg daily) for both CVD and cancer prevention within 6 to 10 years of followup, although such a benefit was apparent in a secondary prevention population. Although a statistically significant beneficial effect on all-cause mortality was suggested in some of our meta-analyses of ASA use in CVD primary prevention trials, the 95% CI included a range of effects that may reflect imprecision or heterogeneity of effects among subpopulations. Lack of statistical heterogeneity in the pooled estimates does not completely eliminate this possibility, since these statistical tests are known to have low power. Given that a CVD primary prevention population may include persons with a range of risk factors or other diseases, it is unclear whether a uniform overall mortality effect across all subpopulations represented in a CVD primary prevention pool should be expected; nonvascular causes of death were prominent contributors to overall mortality in CVD primary prevention trials and aspirin appeared to most robustly reduce nonvascular noncancer deaths. Further research to clarify the types of deaths and their timing across various subpopulations within an overall population using ASA for CVD primary prevention would be extremely informative.

### Aspirin Effects on Cancer Incidence

Fewer CVD primary prevention trials reported a cancer incidence outcome. Where reported, effects within 10 years were generally small (2% reduction) and not statistically significant, even when restricted to studies with daily dosing schedules and at least 4 years of scheduled treatment (Table 9). Among all of our study-level meta-analyses, only the analysis that included either primary or secondary CVD prevention populations assigned to daily ASA (75 to 500 mg) for at least 4 years showed a statistically significant reduction in cancer incidence after 4.2 to 8.2 years. Recent longer-term followup from a CVD primary prevention trial of every other day 100 mg ASA for 10 years in women (WHS) further supports a complex interaction of ASA dosage, frequency, and duration in cancer incidence effects overall, as well as for specific cancers.88 In WHS, cumulative incidence of invasive CRC began to diverge between ASA allocated and unallocated arms at 10 years, with a substantial reduction in the hazards of invasive CRC over 17.5 median years of total followup (HR, 0.80 [95% CI, 0.67 to 0.97]). As in WHS, benefits for CRC and other cancers are likely delayed in some of the lower dosage ASA studies, for up to or even beyond 10 years. Thus, longer-term followup for many trials would be needed to confidently demonstrate (or exclude) cancer-specific and overall cancer effects. Given current limitations in available trial data, additional trial results may be necessary before definitive conclusions about the protective effects of ASA, the size and timing of the chemopreventive benefit, any dose-response relationships, and trends in subgroup analyses can be firmly established.

### Aspirin Effects on Population Bleeding Risks by Site

We found relatively consistent RR increases for most types of serious bleeding events with low-dose ASA use in our review, which is consistent with other meta-analyses.87 RR estimates were similar for major extracranial bleeding and for hospitalizations for first major bleeding events (intracranial and extracranial), as seen in a large cohort study. We found no substantially different RRs for serious bleeding with ASA use when varying the sets of trials we included to represent broader populations. Our sensitivity analyses restricting to the lowest dosages found the same result, although these comparisons are not robust (Table 11). Our pooled estimates from trials suggested at least a 19 percent increase in hemorrhagic strokes with 100 mg low-dose ASA use per day (or less), although estimated effects were quite imprecise due to relatively rare events; CIs were consistent with a larger harm or modest benefit. Sensitivity analyses revealed variability, with larger point estimates of increased risk when including CVD secondary prevention trials. This analysis also revealed some sensitivity to ASA dosage, but all analyses were curtailed by very few events.

One IPD meta-analysis by the ATT Collaboration of six CVD primary prevention trials found a relative increase in the yearly event rates for hemorrhagic strokes (RR, 1.32 [95% CI, 1.00 to 1.75]).87 One cohort study suggested intracranial bleeding were not as rare as seen in the clinical trials (one third of first hospitalizations for major bleeding events for intracranial bleeding and two thirds for extracranial bleeding). In this cohort study, the RRs for intracranial and extracranial serious bleeding events with low-dose ASA use were quite similar, suggesting an increased bleeding risk at either site of about 54 percent. Precise estimates for intracranial bleeding events are difficult to achieve given their relative rarity and reporting differences between studies (as to what type of bleeding among intracerebral, subdural, intracranial, or ischemic is counted). As reported elsewhere, in CVD primary and secondary prevention populations, ischemic strokes are more frequent than hemorrhagic strokes, although hemorrhagic strokes accounted for more of the fatal strokes.87 This suggests that the hemorrhagic strokes caused by ASA could be more serious than the ischemic strokes prevented by ASA. As such, a better understanding of their impact remains important.

In summary, RR estimates for serious bleeding events were relatively consistent for GI bleeding, but these estimates were imprecise and more variable for hemorrhagic strokes/intracranial bleeding.

Although we focused on major bleeding events resulting in transfusion, hospitalization, or death, we found synthesized data from the same CVD primary prevention trials by others suggesting different RRs associated with ASA use for other bleeding outcomes. For nontrivial bleeding events, RRs were somewhat lower (OR, 1.31 [95% CI, 1.14 to 1.50]). In a single 10-year study of 100 mg of alternate day ASA use, the risk was greatly reduced (HR, 1.15 [95% CI, 1.07 to 1.24]).88 However, these bleeding outcomes reflected (any) self-reported GI bleeding diagnosis by a doctor in primarily middle-aged healthy women taking very low-dose ASA (100 mg every other day).88 Thus, the reasonably consistent RR associated with serious bleeding events is likely not appropriate for estimating all other types of bleeding.

## Estimating Population and Subpopulation Effects of Aspirin on Bleeding, Cancer, and CVD Outcomes

In the absence of a large RCT examining all outcomes, the effect of ASA on different outcomes can be difficult to estimate without a model. This is particularly true in the absence of clear information on how baseline risk for events might vary in the target population. The most obvious source for estimates for baseline event rates are control group rates from the CVD primary prevention trials. However, almost none of the trials reported time-to-event data, and trials varied from an average of 3.6 to 10.1 years of followup. Therefore, we simulated control group event rates for all important outcomes for each of the 10 CVD primary prevention trials (Table 10) and used RRs for each outcome from pooling the same trials to estimate absolute effects of ASA for those at low, median, or high baseline risk. These results provided a range of likely outcomes across individuals enrolled in the primary prevention trials. For some outcomes (e.g., bleeding), trial-based rates have been questioned for potentially underestimating risks in clinical practice since trials exclude many individuals at increased bleeding risk from participation. Cohort estimates of baseline bleeding rates may more accurately reflect expectations for use in community practice by addressing less selected populations. We found that estimates from community-dwelling individuals are relatively sparse, particularly for low-dose ASA use alone. Precise exposure data can be difficult to capture for a ubiquitous over-the-counter and prescription medication such as ASA. Further, data on ulcers were much more sparse, and some previous approaches have included ulcers and dyspepsia alongside bleeding in their estimates of upper GI complications (although bleeding alone was 80% of events).95 To represent the harm associated with bleeding, we compared trial and cohort data to address the degree to which trial estimates of population bleeding rates for GI and intracranial bleeding would be likely to underestimate those that would be seen in community practice.

### Variation in Estimated Population Rates of Baseline Bleeding Events Without Aspirin Use Between Trials and Cohort Studies

#### Baseline Population Bleeding Rates From CVD Primary Prevention Trials

Although very few trials originally reported time-to-event analyses, time-to-event outcomes were available from the ATT Collaboration meta-analyses using IPD from six of the CVD primary prevention trials.87 Combining these trials, major extracranial bleeding rates (mainly GI) in those not taking ASA averaged 0.07 percent per year (0.7 events per 1,000 person-years), but control group rates in individual trials suggested a considerable range. In the only two trials with at least 100 events (for reasonably stable estimates), baseline serious extracranial bleeding rates ranged four-fold, from 0.4 per 1,000 in low-risk middle-aged female health professionals60 to 1.8 per 1,000 in older adults with hypertension.67 We found a similarly broad range (2- to 4-fold differences in baseline extracranial bleeding risk) between trials when applying our person-years approximation method to the larger set of 10 CVD primary prevention trials. Control group bleeding estimates also tended to be higher in trials not restricted to CVD primary prevention populations. In mixed CVD primary and secondary prevention trials, the pooled control group rate of major extracranial bleeding events tended to be higher than in primary prevention trials (0.3% per year or 3 events per 1,000 person-years). Similarly, a meta-analysis of 24 mostly CVD secondary prevention trials, 1.4 percent of the overall placebo control group experienced GI hemorrhage of any severity over an average of 28 months (approximately 6 events per 1,000 person-years).96 Thus, there was a fair amount of variation exhibited in baseline bleeding rates, even among trials with selective participant enrollment.

#### Baseline Population Bleeding Rates From Cohort Studies

Among the included cohort studies, rates of hospitalization for first major bleeding event (GI or intracranial) were estimated at 3.6 events per 1,000 person-years among never-users of low-dose ASA (≤300 mg), but showed considerable variability among subgroups (Table 14). The highest rates were almost four-fold higher (12.0 events per 1,000 person-years) and seen in those with prior GI hospitalizations. Although these absolute rates were crude and may reflect other bleeding risk factors, they illustrate a broad array of baseline bleeding rates. These rates also combine major cerebral as well as extracerebral bleeding events, limiting direct comparisons with estimates from trials. Since about two thirds of first bleeding events were GI bleeding, however, we calculated that cohort data suggest roughly 2.4 major GI bleeding events per 1,000 person-years in contrast to 0.7 events per 1,000 person-years from CVD primary prevention trials. Although intracranial bleeding was so rare that variation across trials couldn't be examined, control group rate estimates were again four- to five-fold higher when our calculated rate from cohort data (1.2 major intracranial bleeding events per 1,000 person-years) was compared to estimates from CVD primary prevention trials (0.27 events per 1,000 person-years).87

In an earlier systematic review of 12 population-based studies, the incidence rates of serious upper GI complications (bleeding, perforation, death, hospitalization, or visit to a specialist) were estimated at 1 case per 1,000 person-years based on relatively short-term observational studies in nonusers of prescription NSAIDs.95 Incidence rates were shown to vary considerably by age and, to a lesser extent, sex.95 Many others have used this review's incidence rate of 1 case per 1,000 person-years for estimating baseline serious upper GI complications, and assumed one to two excess cases of upper GI complications per 1,000 person-years of low-dose ASA use based on applying a range of RRs for bleeding with ASA use from observational studies97 to this estimate. In a later publication, however, these same authors pointed out that this baseline bleeding rate assumption primarily represents a relatively low-risk group (men age <60 years or women age <70 years, all with no prior history of GI pain, ulcer, or concurrent use of NSAIDs) and would underrepresent excess cases if applied to others.98

#### Simulated Ranges for Population Event Rates

Table 10 represents events prevented and caused for those at low, medium, or high baseline risk for each major outcome, as represented by the lowest, median, and highest simulated control group event rates for that outcome seen in the CVD primary prevention trials. The events that were prevented were modest for cancer incidence or mortality for all levels of baseline event rates represented in these trials (and based on nonstatistically significant results from meta-analyses). Relatively larger numbers of nonfatal MI events would be prevented in those with medium or high baseline event rates compared to those with lower baseline event rates, as would also be true for major CVD events (which incorporates total MI, total stroke, and CVD mortality). However, for those represented by the medium cardiovascular event rate as well as the highest trial-based bleeding event rate, estimated increases in major bleeding events would be similar or greater than major CVD events or nonfatal MIs prevented. If higher baseline bleeding event rates, as suggested by cohort studies, are substituted, major bleeding events caused (GI bleeding plus intracranial hemorrhage, including hemorrhagic stroke) could exceed or come close to matching cardiovascular events prevented, even for those with medium or high baseline cardiovascular event rates.

From these exercises, it is clear that crude simulations are unable to capture individual variability in baseline risks across multiple outcomes. It is also clear that baseline risk estimates for cardiovascular events, as well as for bleeding with and without ASA use, are very important in determining subpopulation and/or individual net benefit from low-dose ASA use. It is also clear that data to estimate extracranial bleeding rates are more robust than for intracranial bleeding, and that not all considerations of net benefit have therefore included these effects. Finally, cohort data suggest higher baseline bleeding rates than the median rates suggested by trials and are likely more applicable. The highest baseline rate of bleeding from trials just equals the previously derived baseline rate (i.e., 1 event per 1,000 person-years), which applies to middle-aged adults without significant risks. Substituting a somewhat higher baseline rate derived from cohort data (1.4 to 2.0 GI bleeding events per 1,000 person-years) still results in relatively low numbers of excess cases, well within the 1 to 2 excess cases projected elsewhere to apply only to a relatively low-risk population.98 As we will next explore, however, excess cases estimates, at least for GI bleeding, can be projected to be much more variable than this based on known risk factors.

#### Estimating Bleeding Risks With Aspirin Use Among Subgroups

It has been clear for some time that age and sex are major factors in determining differences in bleeding risks associated with ASA use. The previous USPSTF recommendation carefully considered variations in bleeding risks with ASA use by age and sex. Increased bleeding risk due to ASA use can have a greater absolute impact when baseline factors (such as age or previous medical history) that increase bleeding risk are present, or if such patient factors enhance the harms of low-dose ASA use. Almost 20 years ago, Hallas and colleagues pointed out the importance of cohort data for estimating “excess risks” associated with ASA and other NSAID use.93 Excess risk distinguishes between increased bleeding due to baseline factors (such as age or previous medical history) and bleeding attributable to low-dose ASA use alone. The excess risk for bleeding represents the absolute difference in bleeding incidence between users and nonusers of low-dose ASA who are otherwise similar. Some individuals may have such high baseline bleeding risks that ASA use may not be advisable. In some cases, factors that increase baseline bleeding risk (particularly when due to other medication use) may interact with ASA use, potentially modifying the relative effect of ASA. To address these related but separate issues, we have tried to distinguish between subgroups with greater ASA bleeding risks that are due to differing baseline bleeding risks from subgroup findings that represent potential effect modification (i.e., different RR for a bleeding outcome). While available data do not always support these distinctions, they may be conceptually important in projecting net impact.

##### Baseline Bleeding Rate Variation by Age and Sex

Age conferred strong, independent risk for extracranial bleeding in the IPD meta-analysis (adjusted RR, 2.15 [95% CI, 1.93 to 2.39 per decade]) as well as for intracranial bleeding (adjusted RR, 1.59 [95% CI, 1.33 to 1.90 per decade]).87 Rates of hospitalizations for major bleeding events in never-users of ASA varied with other factors, but particularly with increasing age. Very low rates were seen in those younger than age 50 years and increased with age.85 These cohort data suggested a similarly increased relative rate of hospitalization for major bleeding events for each subsequent decade after age 50 years. Trial and cohort data reviewed here and elsewhere95 support about a doubling of the RR of upper GI bleeding or complications for men compared to women, with a somewhat attenuated effect or no sex difference in intracranial bleeding.

##### Changes in RR of ASA-Induced Bleeding by Age and Sex

While it is widely recognized that bleeding risks vary among individuals, based on factors such as age and sex, available data did not suggest effect modification for the increased risk of bleeding with low-dose ASA use by sex. Cohort data showed a trend for the RR of bleeding with ASA use to be higher in ages younger than 60 years, reflecting the relatively greater impact of ASA on bleeding in the context of very low baseline bleeding rates in those younger than age 60 years. Nonetheless, absolute bleeding events were quite low in those younger than age 60 years compared to older ages (Table 14).

##### Baseline Bleeding Rate Variation by Previous GI Bleeding or Ulcers

Previous GI bleeding history was often an exclusion criterion in trials, along with history (or current diagnosis of) peptic ulcers. In one large cohort study in our review, the highest rates of major bleeding events occurred in those with or without a history of GI hospitalization with ASA.85 After adjusting for bleeding risk factors, including ASA use, previous GI hospitalization increased the relative incidence rate of hospitalizations for major bleeding more than any other factor (IRR, 2.87). A previous review of cohort data suggested that history of GI pain/dyspepsia, uncomplicated ulcer, or complicated ulcer increased baseline risk for upper GI complications by two-, six-, and 10-fold, respectively. Previous ulcers or GI bleeding may be considered as relative or absolute contraindications to ASA use for primary chemoprevention, particularly in the absence of other medications to modify associated GI risk.

##### Changes in RR of ASA-Induced Bleeding by Medical History of GI Bleeding or Ulcers

In one large cohort study in this review,85 there was no significant difference in the RR of major bleeding events with ASA use between those with and without a history of previous hospitalization for GI issues (a weak proxy for ulcer/previous bleeding). A separate systematic review including ASA cotreatment comparisons also found limited data on GI bleeding or ulcer-related history, but found an approximately 50 percent higher risk of major GI bleeding in studies that did not exclude patients with a history of GI bleeding compared to those that did.16 Studies in CVD secondary prevention populations have confirmed the greatly increased risk associated with ASA use in those with GI bleeding or ulcer history.99,100

##### Baseline Bleeding Rate Variation by Diabetes or Other CVD Risk Factors

In the 2009 IPD meta-analysis of six CVD primary prevention trials by the ATT Collaboration, authors noted that CVD risk factors were also associated with increased bleeding risk.87 Control group rates of extracranial bleeding events (but not intracranial bleeding) were available for subgroups. Baseline bleeding rates tended to be at least three times higher in subgroups based upon prior diabetes, age older than 65 years, prior vascular disease, predicted 5-year cardiovascular risk greater than 10 percent, systolic blood pressure greater than 160 mm Hg, or diastolic blood pressure greater than 90 mm Hg. Baseline rates appeared about doubled in subgroups defined by current smoking, male sex, or body mass index greater than 30 kg/m^2^. Varying degrees of increased extracranial bleeding rates at baseline were suggested in all of subgroups examined, except cholesterol.87 In adjusted analyses of IPD, increasing age (per decade), male sex, diabetes mellitus, current smoking, and mean blood pressure per 20 mm Hg were all independently associated with increased rate ratios for major extracranial bleeding (after also adjusting for ASA use). Increasing age, mean blood pressure, and current smoking were associated with increased rates of hemorrhagic stroke after adjusting for ASA use.

##### Changes in RR of ASA-Induced Bleeding by Diabetes or Other CVD Risk Factors

An increased risk of major bleeding in patients with diabetes at baseline was apparent in adjusted analyses from an IPD meta-analysis of primary prevention trials and a very large cohort trial. Data were mixed as to whether low-dose ASA further increased elevated bleeding risk above baseline. In one large cohort study, low-dose ASA significantly increased rates of hospitalization for bleeding in patients without diabetes, but did not increase them in those with diabetes above already elevated baseline levels. This resulted in a paradoxical reduction in RR associated with low-dose ASA use in patients with diabetes. In addition to increased risk of extracranial bleeding among patients with diabetes (rate ratio, 1.55 [95% CI, 1.13 to 2.14]), RR of hemorrhagic stroke also tended to be increased in an IPD meta-analysis by the ATT Collaboration87 (rate ratio, 1.74 [95% CI, 0.95 to 3.17]) after controlling for other risk factors, including ASA use. Net benefit determination is complicated in this important subpopulation given the potential increase in baseline bleeding risks in patients with diabetes for all bleeding outcomes and uncertainty about ASA's relative bleeding effects.

Available data were too sparse to clearly confirm or exclude a higher bleeding risk with ASA use in trials with previous CVD events (secondary prevention) compared to trials examining primary prevention. Similarly, among primary prevention trials, while risk-based data were limited, they suggested no statistically significant difference in ASA bleeding effects by 5-year coronary heart disease (CHD) risk.87 As will be discussed further, however, some uncertainty remains about whether those at increased CVD risk are also at increased bleeding risk (with or without ASA). Any relationship between increased CVD risk and increased bleeding risk could be critical in appropriately identifying individuals for primary prevention with low-dose ASA.

##### Baseline Bleeding Rate Variation by Concomitant Medication Use

Many recent studies outside this review have focused on the excess risks associated with ASA use in the context of other medications, particularly those commonly used with ASA in CVD secondary prevention populations, such as other antiplatelets or anticoagulants. This review focused on the impact of two commonly used medications—NSAIDs and SSRIs—that might be commonly used in a primary prevention population. Many of the studies we examined excluded users of NSAIDs and other medications associated with increased bleeding risks for reasons of safety. Those that included these patients rarely reported results stratified by medication use. In the large cohort study that compared low-dose ASA users to propensity-score matched never-users, a number of medications (NSAIDs, SSRIs, ASA as an analgesic, other antiplatelets, oral anticoagulants, systemic corticosteroids, PPIs, and statins) were examined. Baseline bleeding rates were increased in those taking SSRIs but not NSAIDs; however, combined use of SSRIs with ASA was not associated with increased hospitalization rates for major bleeding events above ASA use alone. These unadjusted data suggested no effect or at least a moderation of bleeding risk with ASA use in those taking SSRIs; SSRI use was also not an independent predictor of major bleeding events in adjusted analyses.

Other data on SSRIs and ASA are mixed, but largely consistent with a relatively modest overall effect of SSRIs on major bleeding that can be largely accounted for when controlling for other risk factors. SSRIs were reported to substantially increase upper GI bleeding risk, particularly among adults age 80 years and older or those with previous upper GI bleeding; excess GI bleeding due to SSRI use was estimated at 3.1 events per 1,000 person-years of use, if the association was causal.101 A separate nested case-control study in U.K. primary care also found that current users of SSRIs, as well as past users, experienced the same increased RR of upper GI bleeding (about 85%) that was no longer significant after adjustment for other risk factors.102 Nonetheless, a national retrospective cohort study in Taiwan suggests ongoing caution when prescribing SSRIs, particularly in older adults and those with previous GI bleeding, since users of “high-affinity SSRIs” had a 38 percent higher risk of severe GI events (bleeding ulcers) compared to users of “low-affinity SSRIs.” Analyses were adjusted for NSAIDs but not for ASA use.103

In cohort data in our review, combined ASA and NSAID users and ASA users alone both had similarly increased rates of hospitalization for major bleeding, with no effect modification. Use of NSAIDs retained a small (10%), but significant, impact on increased rates of bleeding hospitalizations in analyses adjusted for ASA use and other risk factors. Other studies have suggested more greatly increased GI bleeding risk with combined low-dose ASA and NSAID use. A recent nested case-control study from 2000 to 2007 found a doubling of the RR for upper GI bleeding in users of combined NSAIDs and low-dose ASA (75 to 300 mg) compared to age-sex-time period matched low-dose ASA users alone.102 Similarly, after excluding individuals at risk of bleeding, an earlier population-based cohort study in Sweden confirmed that concurrent use of NSAIDs in low-dose ASA users more than doubled the incidence of first upper GI bleeding compared to users of 100 to 150 mg ASA and users of low-dose ASA alone.104 Cohort data cannot control for other bleeding risk differences, and when consistent, confirm increased risks with cotreatments, but are less useful for precise estimates of additional risks. Taken as a whole, available data suggest that excess major bleeding events are likely with NSAIDs in combination with low-dose ASA, although magnitude of effects may vary between specific types and dosages.

Although relatively modest impacts were found for the primary medications we examined, the large cohort study did suggest interactive effects for other medications more typically used in CVD secondary prevention situations (i.e., antiplatelets, oral anticoagulants). Combined ASA and other antiplatelet users had significantly higher rates of hospitalization for major bleeding events than users of either agent alone, with a somewhat elevated IRR for ASA use (IRR, 1.85). Combined ASA and anticoagulant users had the highest absolute rates, but a reduced IRR for ASA use (IRR, 1.27), illustrating the complexity of these data. In adjusted analyses, both medications independently increased hospitalizations for major bleeding events.85

Results from the same large cohort study also suggested a possible protective role of statin use on crude baseline risk for hospitalization for major bleeding events with or without low-dose ASA use. Statin users experienced reduced hospitalization for major bleeding events incidence rates (33%) after multivariable adjustment. These findings were consistent in unadjusted as well as adjusted analyses.85 In contrast, a nested case-control study in a separate U.K. primary care population found that current statin use was associated with increased upper GI bleeding (70% to 95%) in both current and past users (over the last year) that was no longer present after adjusting for other risk factors.102 These data illustrate the potential confounding that can cause spurious associations (protective or harmful) in observational studies. Although largely beyond the scope of our review, these findings are intriguing and suggest future important areas for research and review.

#### Summary

Due to lack of data, we cannot reach firm conclusions about subgroup effects and how subgroup factors such as disease or risk factor status might interact with ASA use and/or other subgroup factors, such as age and sex. Data are clearest for elevated baseline bleeding rates by age, with further relative increases in men, and no apparent effect modification for ASA use by age or sex. Data are also clear for those with a previous history of GI bleeding or complications. In other subgroups defined by CVD risk factors, very limited data suggest elevated extracranial bleeding rates among many CVD risk factor subgroups, with a smaller set of risk factors possibly increasing intracranial bleeding rates. Although many separate patient factors appeared to be associated with increased bleeding risks, few showed clear effect modification with ASA use. With the exception of select medications, RR with ASA use apparently decreased in some subgroups with elevated baseline bleeding risk, such as individuals with diabetes. However, all of these comparisons examined each subgroup separately and without adjustment for other risk factors; further, findings were not completely consistent between trial and cohort data and deserve replication. Assumptions of higher baseline bleeding rates without significant effect modifications with ASA use are conservative, in that this approach will not underestimate important absolute differences.

Given the importance of characterizing bleeding risk across a population that might be candidates for ASA as a primary preventive agent, and the variability and complexity of effects among subgroups, we sought evidence for clinical tools that might individualize bleeding risk more accurately. Clinical tools available to support robust bleeding risk assessment for ASA use in this context are greatly needed, but remain very limited.

### Valid Risk Prediction Tools for Bleeding Risks With Aspirin Primary Prevention

We located no clearly validated risk prediction tools for bleeding risks associated with ASA for primary prevention of CVD or cancers. A single tool based on systematic review of risk estimations and event incidence for upper GI complications (primarily bleeding) and CHD risk with low-dose ASA use (through 2011) has been published and made available in the public domain.105 This tool does not address bleeding issues in sites other than the upper GI tract. The tool presumes a baseline incidence rate for upper GI complications of 1 event per 1,000 person-years, which is modified within 10-year age groups in those age 50 years and older (RR of 1.8, 2.4, 4.5, and 9.2 among ages 50 to 59, 60 to 69, 70 to 79, and 80 years and older, respectively,); other modifiers are male sex (RR, 2.1), past ulcer (RR, 5.9) or dyspepsia history (RR, 2.0), and use of certain medications (NSAIDs, warfarin, clopidogrel, and PPIs), some of which may be more common in secondary prevention. The baseline and relative risk estimates used in this tool can be compared to those from studies included in our systematic review (listed by source in Tables 14 and 15).

The tool uses a multiplicative model, assuming a constant two-fold increased risk associated with low-dose ASA use (≤325 mg) in all baseline risk groups, but that NSAID use is modified by the effect of certain other risk factors. When retrospectively applied to two groups of patients from a multicenter national registry (904 age- and sex-matched individuals on similar durations of long-term low-dose ASA with and without peptic ulcer GI bleeding), the calculator predicted a greater number of upper GI complication events per 10,000 persons years in low-dose ASA users who had developed peptic ulcer bleeding versus those who had not (286 vs. 228 events), but the 95% CI overlapped. The tool was not applied to individuals at risk, but in a case-control comparison, with more events predicted in the group who represented those with 100 percent rate of events versus the group with no events. Thus, much more information is needed as to how well this tool would work prospectively to assess bleeding risk among individuals considering low-dose ASA prophylaxis. In an earlier analysis, use of similar RR increases for age, male sex, ulcer history, and ASA use applied to the proportion of participants in each category within the control groups of three trials of NSAID use in osteoarthritis or rheumatoid arthritis predicted upper GI complications reasonably well (observed: 8.6, 14.5, and 9.1 events per 1,000 person-years, respectively; predicted: 7.0, 8.1, and 9.5 events per 1,000 person-years, respectively).98 In this instance, the tool was based on predicting risks at a population level and not applied to individuals at risk. In the same paper, the authors estimated an average of 5 excess cases of upper GI complications per 1,000 person-years among current users (likely including secondary as well as primary prevention) based on the prevalence of male sex, GI complications or ulcer history, and NSAID use among users of ASA for cardioprotection in population-based databases from the United Kingdom and Spain. However, excess cases were projected to vary substantially among individuals with varying levels of increased upper GI complications risk based on age, sex, medical history, and NSAID use.98 Thus, factoring in additional factors that could modify bleeding risk for individuals or subpopulations will be very important.

Of note, the published tool we found also encompasses CVD benefit—using the 10-year Framingham CHD sex-specific risk prediction equations considering age, diabetes, smoking, hypertension, total cholesterol, and low-density lipoprotein cholesterol—and further incorporates bleeding risk modification through usage of treatments (PPIs, Heliobacter pylori infection eradication). Modifications of predicted bleeding risks under various scenarios attempts to facilitate the management of ASA-associated bleeding risks as part of the overall balancing of individual benefits and risks in an individual clinical encounter. This presumes the willingness to use PPIs as part of a primary prevention strategy.

#### Targeting Appropriate ASA Use Without a Robust Clinical Tool

Estimating the likely impact of ASA use on bleeding events remains one of the most critical issues facing clinicians considering its use for primary prevention of CVD or cancers. Assessment of bleeding risk based on age and sex, and excluding those at increased risk due to medical history or NSAID use, was recognized by the USPSTF in 2009 as part of its recommendation for individuals considering ASA as primary prevention. Recent comments have reflected the growing understanding of the complexity of balancing the risk-benefit profile for low-dose ASA for primary prevention, in populations or individuals.106,107 Careful assessment of individual bleeding risk may be particularly challenging due to its possible association with many well-established cardiovascular risk factors, which have also been used to target those more likely to benefit from a cardiovascular perspective.108 Previous attempts to consider net benefits may underestimate bleeding risks if based on trial rather than cohort data.108 While benefits and risks of any treatment should be individualized to the extent possible, it is particularly important for ASA when used as a primary preventive agent, with potentially substantial side effects that may limit its recommended use or adherence once recommended.16

We attempted to clarify subgroup findings by distinguishing those that may primarily represent different baseline risks from those that represent potentially differential effects of low-dose ASA use. However, despite the call for this type of data more than 20 years ago, we found only a single cohort study and an IPD meta-analysis that reported data in this way. Ideally, these would have allowed us to consistently consider whether important patient factors increase baseline bleeding risk, moderate relative bleeding effects of ASA, or both. However, we lacked complete data across all potential risk factors. From our review, it is clear that subpopulations based on age and sex remain important for considering effects of ASA on bleeding, and that ASA's relative bleeding effects do not vary by these factors. However, other potentially important subgroups, including diabetes, hypertension, and smoking, have emerged for whom data are not so clear. Understanding whether and how overall CVD risk levels may vary in their bleeding risks, according to their combinations of various risk factors, and further considering the impact of other comedications (statins, NSAIDs, antiplatelets) seems important to inform potential widescale adoption of ASA for primary chemoprevention. Tables 14 and 15 summarize data from our review across major risk factors and major bleeding outcomes.

### How Does Increased CVD Risk in a Primary Prevention Population Relate to Bleeding Risk With Aspirin?

In adjusted analyses of IPD, increasing age (per decade), male sex, diabetes mellitus, current smoking, and mean blood pressure per 20 mm Hg were all independently associated with increased rate ratios for major extracranial bleeding and for probable ischemic stroke (after also adjusting for ASA use). The strongest single risk factor for extracranial bleeding was older age, in which risk doubled with each decade. These same risk factors were associated with major CVD outcomes, with some variability by outcome. Risk factors of smoking, hypertension, and older age were associated with both greater rates of MI and stroke (and other CVD outcomes) and with greater rates of hemorrhagic stroke and major extracranial bleeding.87 Hypertension and current smoking were associated with doubling of hemorrhagic stroke bleeding rates, the highest RRs of any factors examined, with a somewhat smaller impact on extracranial bleeding.

When diabetes or CVD risk factors were examined using cohort data, increased baseline bleeding rates in ASA never-users were reported for those with diabetes and those taking antihypertension medications; data on smoking status or other CVD risk factors were not provided. Diabetes, and to a lesser extent, hypertension, remained significant independent predictors of increased rates of hospitalizations for major bleeding events after controlling for other risk factors and for ASA use. For these two factors, the impact of ASA use on top of the increased baseline bleeding rate was uncertain, with similar absolute event rates and significantly reduced RRs of bleeding in those with either condition using ASA compared to no ASA.

If elevated bleeding risk is associated with elevated CVD risk factors, then it is plausible that elevated CVD risk levels at the same percentage threshold may not be equivalent, in terms of the expected net benefit, due to variable associated bleeding risks. For example, an increased CVD risk level largely based on older age, male sex, and current smoking may be particularly associated with elevated GI bleeding risks and possibly less net benefit with ASA prophylaxis than in those in whom elevated CVD risk levels are based on cholesterol, diabetes, and hypertension; even though the latter may increase hemorrhagic stroke risk, it is much rarer. More completely understanding the combined impact of some of these risk factors on the likelihood of harms as well as benefits is important.

### How Does Other Medication Use in a Primary Prevention Population Relate to Bleeding Risk With Aspirin?

One approach to limiting bleeding risk associated with comedications would be to limit low-dose ASA use as a primary preventive agent to individuals not taking other medications that increase bleeding risks, as many trials have done. Estimated bleeding risks with low-dose ASA use were presumed to exclude those taking other NSAIDs in the 2009 USPSTF review. In practice, however, combined use of medications that increase bleeding risk may be an issue not just at initiation of ASA chemoprevention, but in its proposed long-term use to achieve preventive benefits, particularly for cancer. A large prospective nationwide study among Swedish low-dose ASA users who were confirmed to be at least 80 percent adherent to prescribed ASA (75 to 160 mg) for the year prior to observation had relatively low use of GI-risk-associated drugs at ASA treatment initiation (1% used oral steroids, 1% warfarin, 2% NSAIDs, 2% clopidogrel).109 During 2.5 median years of observation, 28 percent received more than one prescription for an NSAID, while fewer were repeatedly prescribed clopidogrel (5%), warfarin (6%), or oral steroids (5%). Although there was no untreated control group, comparison with the lowest risk group (low-dose ASA users with continuous, high adherence PPI use) showed that addition of any GI-risk-associated drug (NSAIDs, clopidogrel, oral steroids, or warfarin) for longer than 3 months increased the risk of severe GI events (ulcers or bleeding) after adjustment for other bleeding risk factors (HR, 1.73 [95% CI, 1.60 to 1.86]). Another recent systematic review confirmed the benefit of PPI coadministration in low-dose ASA, but studies were focused on patients with a history of gastric bleeding or at risk due to using other medications, such as clopidogrel.16 Although data on the potential effect of PPIs were available from the large cohort study we reviewed, we did not formally consider concurrent PPI use to mitigate bleeding risks associated with low-dose ASA for primary prevention. Such an approach would complicate a primary preventive regimen, and there is no evidence to confirm that coadministration of long-term PPIs with ASA would confer the same benefits without additional harms. Finally, in terms of considering comedication usage, the potential for moderation of bleeding as well as CVD risks with statin use creates an additional uncertainty.

## Role of Aspirin Dosage, Duration, Frequency, and Recency of Use in Bleeding Risk

Data from our review addressing issues around ASA dosage, duration, frequency, or recency were limited. While the majority of evidence in our review supported dose-related increases in bleeding risks with ASA use, there may be fewer differences within the range of low-dose ASA usage commonly employed in primary prevention. Previous systematic reviews largely support these conclusions; however, the remaining uncertainties in the data would argue for using the lowest possible dosages and frequency of ASA possible to achieve prevention benefits.

A previous systematic review of eight trials (for secondary prevention) and three cohort studies examined within-study variation in dosages from 30 to 1,200 mg. In studies reporting within-study comparisons, results clearly indicated increased major or serious bleeding events with doses above 100 or 165 mg compared to lower within-study doses, without clear evidence of additional CVD benefit in higher dosages.110 Similarly, based on meta-analysis of 31 trials of ASA, authors concluded risks of hemorrhage (minor, total, stroke, and especially GI) were lowest in those taking the smallest dose of ASA (equivalent to ≤81 mg per day) compared to those taking higher dosages (equivalent to 325 mg per day).111 Earlier systematic reviews of epidemiologic studies confirmed dose-response relationships with upper GI complications across low- and high-dose ASA use; risk remained elevated with low-dose ASA use (≤325 mg per day compared to nonusers).97 When users were limited to 75 to 325 mg per day, however, dose-response relationships with upper GI complications were less clear.97,112 While another previous systematic review of 14 trials of 75 to 325 mg of ASA for primary or secondary CVD prevention found no significant effect by dosage above and below 162.5 mg on major GI bleeding, any major bleeding, or intracranial bleeding, the effect estimates were very imprecise due to small numbers, especially in higher-dose studies, and could have been confounded by other between-study differences.113 Thus, although data are not completely consistent, we believe that dose-response relationships are likely with the range of low-dose ASA use for at least some bleeding outcomes or some individuals. Using the lowest possible doses to achieve prevention benefits is prudent. Similarly, while less frequent usage may be associated with reduced bleeding risks, there are no experimental comparisons and few robust cohort comparisons. If alternate day use is equally effective for desired benefits, it may also be a prudent approach.

Although others have suggested reduction in risk of GI bleeding with longer duration of low-dose ASA use, we conclude that limited, but consistent, data suggest bleeding risks appear to be maintained, but not diminished, with long-term use.10 This conclusion is based on critical appraisal of included studies in the previous review, indirect data from long-term cohort studies, and recent longer-term direct data from WHS.

We found no data varying type of formulation within our review, but earlier studies have suggested no benefit, and perhaps harm, to substituting enteric or buffered ASA for plain ASA. One cohort and one case-control study have reported that enteric coating did not seem to modify the observed increased risk of hospitalization for upper GI bleeding with low-dose ASA use;104,112 cohort data suggest GI symptoms are not different in low-dose ASA users taking buffered instead of plain low-dose ASA (80 to 100 mg).114 These more recent data showing no impact of formulation somewhat contradict, but likely supplant the first landmark systematic review of epidemiologic studies97 that was not limited to lower ASA dosages and included some data reflecting nonASA NSAIDs.

Limited data within our review suggested a return to baseline bleeding rates sometime after discontinuation of low-dose ASA, which was also found in an earlier cohort study after the first year104 and in a recent nested case-control study showing reduced upper GI bleeding risk within 2 to 26 weeks after low-dose ASA discontinuation in secondary prevention users.99

### Persistence and Discontinuation of Aspirin

Available data suggest that, for cancer benefits with ASA use to accrue, use must be continued for at least 4 or 5 years. Data from trials showing cancer benefits had adherence rates of 64 to 90 percent at 4 to 5 years, as reported in a companion report;40 even within the ongoing support structure of trials, rates of discontinuation or nonadherence to recommended treatment were common across trials as treatment duration approached 4 or 5 years.

While we found no data on community rates of discontinuation of ASA for primary CVD or cancer prevention, one study examined discontinuation for at least 90 days among new users of low-dose ASA (75 to 300 mg per day) for secondary prevention in the Health Improvement Network primary care database in the United Kingdom from 2000 to 2007.^115^ During a mean followup of 9.8 months, 21.4 percent of patients discontinued ASA at a median time to discontinuation of 3.7 months. Less than 10 percent of new users continuously used PPIs during their low-dose ASA use. In those with data over the first year, 76 percent of PPI nonusers were continuing low-dose ASA at 12 months, while 80 percent of continuous PPI users were continuing. Only warfarin use increased the risk of discontinuation among a range of medications, although some other medications (i.e., statins) showed a protective effect, and none of the associations were controlled for other factors. In a separate cohort study109 of Swedish adults age 40 years or older receiving low-dose ASA (75 to 162 mg) for any reason, among those developing a GI or ulcer event (1.2% over 2.5 median years of followup), subsequent adherence to low-dose ASA was altered in two thirds, with 22 percent of those with adverse events discontinuing and 42 percent reducing their adherence to recommended usage.

## Limitations of the Review

Limited data were available to assess cancer-specific effects.8,60 Among men and women, cancer mortality data were most promising for GI sites and for mortality from adenocarcinomas, regardless of site. Future data should provide more precision as to any site-specific effects, and add further specification to minimal duration of required ASA use, dosage effects, and timing of cancer effects. We did not examine the evidence supporting the effect of low-dose ASA on metastatic disease, since this application would be considered disease management within the USPSTF rubric. Nonetheless, others may view this evidence as providing support to the overall consideration of ASA use in cancer prevention, since the findings are consistent mortality effects in prevention studies.

ASA is one of the most extensively studied medications with a worldwide literature. Setting exclusion criteria was necessary to manage the review scope. We did not search EMBASE formally, so we may have missed some international literature, although the primary trials are well known and we relied on IPD meta-analyses by others. We excluded case-control studies since prior research showed a much higher summary estimate of the relative effects of ASA on harms.97 Similarly, we excluded uncontrolled studies of ASA-related harms, since population differences in bleeding risks have been suggested.87 While we excluded nested case-control studies and other uncontrolled observational studies per protocol, to round out the available data, we covered some of these studies (with a focus on recent data or previous influential systematic reviews) in our discussion.

Through our inclusion/exclusion criteria and approach to the analyses, we attempted to focus our cancer, all-cause mortality, and harms results on those that would be expected in a CVD primary prevention population using appropriately low doses of ASA. We conducted series of sensitivity analyses to explore the impact of restrictions in ASA frequency or dosage. We conducted indirect comparisons between the CVD primary population and the larger set of included studies, as well as IPD meta-analysis by the ATT Collaboration and recent study-level meta-analyses by Seshasai and colleagues providing data that complemented our primary findings. While we tried to display tradeoffs, such as those between power and applicability and different conclusions based on different approaches to what would be considered relevant data, the breadth of previous work makes it likely that we have not captured all nuances. Likewise, the perspective of focusing only on the context of ASA in CVD primary prevention could be viewed by some as unnecessarily limiting, even in this context of informing a preventive services recommendation.

We did not consider moderation of GI bleeding risks through PPI use, as no studies have determined whether its combined use with low-dose ASA modifies the expected CVD benefits. Importantly, there may be potential long-term risks that would need to be clarified, including possible effects on bone mineral density, increased infections, nutritional deficiencies, and increased gastric/colon cancer risks, as well as potential drug-drug interactions; these would require clarification before its administration as a primary preventive agent to those without disease.116 Finally, the primary data for ASA effects on a range of health outcomes has not changed substantially over the last several years, but the field is poised to provide additional data in the near future. For example, two large trials in patients with diabetes are in progress (Appendix H) to address the issue of ASA use for primary prevention in those with diabetes: A Study of Cardiovascular Events in Diabetes (ASCEND)117 and Aspirin and Simvastatin Combination for Cardiovascular Events Prevention Trial in Diabetes (ACCEPT-D).118 The ongoing ASPREE trial has recruited 19,000 adults age 70 years or older and randomized to ASA 100 mg daily versus placebo with a primary outcome of all-cause mortality, dementia incidence, or physical disability.53 Other in-process ASA prevention trials may further clarify overall and subpopulation-specific all-cause mortality effects.

## Future Research Needs

- Bleeding risk assessment tools: Development of an externally validated bleeding risk tool informed by real-world events (i.e., population registries accounting for prescription and nonprescription use of ASA and other medications as well as a range of other patient factors) would be tremendously powerful at the point of care for shared decisionmaking. Most registry data of low-dose ASA use are limited in terms of their comprehensiveness for patient characteristics, medical history, cotreatments, ASA exposure, or the full range of outcomes. Over-the-counter availability in the United States further complicates tracking for ASA and important comedications. However, more complete and comprehensive data on the risks and moderators of ASA's effects on bleeding are critical for evidence-based preventive uses, including for cancers. Particularly given the rarity of many critical bleeding events, very large numbers of exposed lives are needed in these analyses. Since CVD risk factors also appear associated with increased bleeding risks (which may also vary somewhat between intracranial and extracranial sites), accurate risk tools that consider CVD risk and GI bleeding using the same variables would be most useful.
- Confirming the net impact of ASA in the context of CVD risk management with statins and/or lifestyle modification: Much of the data on ASA effects predates the use of statins and other approaches to moderate CVD risk for primary and secondary prevention. As noted in one IPD meta-analysis by the ATT Collaboration,87 other approaches to reducing CVD risk would reduce the absolute benefit from low-dose ASA use, while not clearly also modifying the bleeding risks. Thus, a robust understanding of the expected net impact in a population being managed under current recommendations for CVD risk factors through modeling or additional research is critical.
- Updated, longer-term followup of all CVD primary prevention trials for individual and total cancer incidence and mortality outcomes, CVD, serious bleeding, and other outcomes, with IPD meta-analyses: Our review illustrates the somewhat fragmented nature of the current data supporting a comprehensive understanding of the overall impact of low-dose ASA in populations, subpopulations, and individuals. There are about 100,000 lives represented in the current CVD primary prevention trials. Longer-term followup of these and updated IPD meta-analyses, including all trials and longer-term followup for major outcomes, would provide more continuity. Incorporating all relevant beneficial and harmful outcomes into the analysis of ongoing trials of ASA use, if not already planned, might be possible and would be very useful. Similarly, any resolution possible to reduce the diversity of bleeding outcome categorizations between studies would be very helpful.
- Determining the net impact of strategies to modify bleeding risk (on CVD/cancer benefits): Much recent literature focuses on approaches to moderate increased bleeding risk with low-dose ASA use, such as PPIs or H. pylori eradication. Experts suggest the application of these strategies to those at higher risk for bleeding, but confirm limited data on overall impact. Further research on the overall impact of cotherapies in CVD primary prevention populations would be extremely informative. Incorporation of these perspectives into the analysis of ongoing trials of ASA use, if not already planned, would be very useful.
- Determining whether there is a clinically separate population for cancer prevention through low-dose ASA: The strongly suggested mortality effects on colorectal and other cancers in selected trials with very long-term followup beg the question of whether there may be a separate clinical population for low-dose ASA to prevent specific cancers. As more data emerge on specific cancers (i.e., breast, pancreas) and on specific cancer sites (i.e., proximal vs. distal colon) and in specific populations (i.e., those with adenomas), a clearer picture for a discrete and separate population for ASA-related cancer chemoprevention could emerge. Similarly, as data on genetic factors associated with cancer benefits with ASA use emerge, as they are beginning to in CRC, more specific targeting to minimize risks and maximize benefits may be possible.

## Conclusion

In CVD primary prevention populations taking low-dose ASA for chemoprevention, a beneficial effect on cancer mortality or incidence is not clearly established. Data remain too limited for specific cancer effects, except perhaps for CRC, which is covered in a separate review. Data on specific factors that modify cancer risk, such as family history, were generally unavailable, since these data were primarily derived from CVD-oriented trials. Similarly, although a statistically significant beneficial effect on all-cause mortality has been shown in CVD secondary prevention populations and in some meta-analysis of CVD primary prevention trials, the 95% CI includes a range of effects that may reflect imprecision or a range of effects among subpopulations. Baseline bleeding risks and the effects of low-dose ASA alone or in combination with other common medications are not well studied in community-dwelling ambulatory populations who would be candidates for primary CVD or cancer prevention. Nonetheless, estimation of bleeding risks is increasingly recognized as critically important for valid assessment of expected net effects of ASA in primary prevention for cancer, CVD, and perhaps other conditions. No validated risk assessment tool is available for assessing bleeding risk for primary ASA chemoprevention, although more data have become available on the impact of risk factors, such as age, sex, CVD risk factors, and comedications, and their effects on increased bleeding risks alone or with ASA use. While the potential for identifying a subpopulation for safe, long-term low-dose ASA use to prevent multiple diseases remains tantalizing, it should be further informed by the large body of ongoing research.