# Results

## Literature Search and Included Studies

From our review of 4,393 abstracts and 336 full-text articles (Appendix A Figure 1), we identified 34 studies (30 RCTs and four cohort studies) reported in 82 publications for inclusion. From our included studies, 19 RCTS evaluated cancer mortality (KQ 1),51,57-74 27 RCTs evaluated all-cause mortality (KQ 1),53,54,57-81 12 RCTs evaluated cancer incidence (KQ 2),54,57,58, 60-62,66-68,72, 75,77 and 30 RCTs51-54,57-82 and four cohort studies83-86 evaluated adverse effects (KQ 6). A brief description of included trials and cohort studies can be found in Tables 6 and 7, respectively.

Table 6 Brief Description of Included Trials

Prevention | Author, Year Quality | Design | Country | Mean Follow-up (years) | Population | N rand | Mean Age and Range (years) | % Female | % Diabetes | % Current Smokers | ASA Dose, Concomitant Treatment, and Frequency | KQ1 | KQ2 | KQ6
CVD Primary Prevention | Belch, 2008 (POPADAD)57 Fair | RCT, 2×2 factorial | Scotland | 6.7^†^ | Males and females w/diabetes and ABI ≤ 0.99 | 1,276 | 60.3 (≥ 40) | 55.9 | 100 | 31.1 | 100 mg alone or with antioxidants qd | ✓ | ✓ | ✓
CVD Primary Prevention | Cook, 2005 (WHS)60 Good (KQ1,KQ2); Fair (KQ6) | RCT, 2×2×2 factorial | United States | 10.1 | Female health professionals | 39,876 | 54.6 (≥ 45) | 100 | 2.6 | 13.1 | 100 mg alone or with vitamin E or beta-carotene qod | ✓ | ✓ | ✓
CVD Primary Prevention | de Gaetano, 2001 (PPP)61 Fair | RCT, 2×2 factorial | Italy | 3.6 | Males and females w/ ≥ 1 CVD risk factor | 4,495 | 64.4 (≥ 50) | 57.5 | 16.5 | 14.8 | 100 mg alone or with 300 mg vitamin E qd | ✓ | ✓ | ✓
CVD Primary Prevention | ETDRS, 1992^64^ Good | RCT, 2×2 factorial | United States | 5 | Males and females w/diabetes and diabetic retinopathy | 3,711 | NR (18-70) | 43.5 | 100 | NR | 650 mg qd | ✓ | | ✓
CVD Primary Prevention | Fowkes, 2010 (AAA)66 Good | RCT | United Kingdom | 8.2 | Males and females w/ ABI ≤ 0.95 | 3,350 | 62.0 (50-75) | 71.5 | 2.6 | 32.4 | 100 mg qd | ✓ | ✓ | ✓
CVD Primary Prevention | Hansson, 1998 (HOT)67 Fair | RCT, 2×2 factorial | International (Europe, North and South America, Asia) | 3.8 | Males and females w/hypertension | 19,193 | 61.5 (50-80) | 47 | 8 | 15.9 | 75 mg qd | ✓ | ✓ | ✓
CVD Primary Prevention | MRC, 1998 (TPT)69 Good | RCT, 2×2 factorial | United Kingdom | 6.8^†^ | Males at high-risk for IHD | 2,540 | 57.5 (45-69) | 0 | NR | 41.3 | 75 mg qd | ✓ | | ✓
CVD Primary Prevention | Ogawa, 2008 (JPAD)70 Fair | RCT | Japan | 4.37^†^ | Males and females w/diabetes | 2,539 | 64.5 (30-85) | 45.4 | 100 | 21.2 | 81 or 100 mg qd | ✓ | | ✓
CVD Primary Prevention | Peto, 1988 (BMD)72 Fair | RCT | United Kingdom | 6 | Male physicians | 5,139 | 61.6 (NR) | 0 | 2 | 12.9 | 500 mg, or 300 mg if requested qd | ✓ | ✓ | ✓
CVD Primary Prevention | PHS, 1989^73^ Good (KQ1); Fair (KQ6) | RCT, 2×2 factorial | United States | 5.0 | Male physicians | 22,071 | 53.2 (40-84) | 0 | 2.4 | 11 | 325 mg alone or with 50 mg beta-carotene qod | ✓ | | ✓
CVD Primary Prevention^*^ | DAMAD, 1989^51^ Fair | RCT | France, United Kingdom | 3 | Males and females w/diabetics and diabetic retinopathy | 314 | 46.7 (17-67) | 35.4 | 100 | NR | 330 mg (990 mg total per day) tid | ✓ | | ✓
CVD Primary Prevention^*^ | Nelson, 2008 (ASPREE)53 Fair | RCT | Australia | 1 | Males and females aged ≥ 70 years | 209 | 76.2 (≥ 70) | 59.3 | 0 | 4.3 | 100 mg qd | ✓ | | ✓
CVD Primary Prevention^*^ | Silagy, 1993^52^ Fair | RCT | Australia | 1 | Males and females aged ≥ 70 years | 400 | 73 (70-90) | 51 | NR | 5.8 | 100 mg qd | | | ✓
CVD Secondary Prevention | AMIS, 1980 Fair | RCT | United States | 3.2 | Males and females w/ prior MI | 4,745 | 54.8 (30-69) | 11.1 | 10.6 | 27.3 | 0.5 g (1.0 g total per day) bid | ✓ | ✓ | ✓
CVD Secondary Prevention | Becattini, 2012 (WARFASA)78 Fair | RCT | Italy | 2.0^†^ | Males and females w/ prior DVT or PE | 403 | 62.0 (≥ 18) | 36.07 | NR | NR | 100 mg qd | ✓ | | ✓
CVD Secondary Prevention | Brighton, 2012 (ASPIRE)58 Good | RCT | Multinational (5 countries including Australia, New Zealand) | 3.1^†^ | Males and females w/prior DVT or PE | 822 | 54.5 (≥ 18) | 45.6 | NR | NR | 100 mg qd | ✓ | ✓ | ✓
CVD Secondary Prevention | CDPRG, 1980 (CDPA)59 Good | RCT | United States | 1.83 | Males w/ prior MI | 1,529 | NR (NR) | 0 | NR | NR | 324 mg (972 mg total per day) tid | ✓ | | ✓
CVD Secondary Prevention | Cote, 1995 (ACBS)79 Fair | RCT | Canada | 2.4 | Males and females w/ an audible cervical bruit | 372 | 66.7 (NR) | 53 | 23.7 | 36.8 | 325 mg qd | ✓ | | ✓
CVD Secondary Prevention | Diener, 1997 (ESPS-2)62 Good | RCT, 2×2 factorial | Europe (13 countries) | 2 | Males and females w/ prior TIA or stroke | 3,298 | 66.7 (≥ 18) | 42.2 | 14.5 | 23.5 | 25 mg (50 mg total per day) bid | ✓ | ✓ | ✓
CVD Secondary Prevention | EAFT, 1993^63^ Fair | RCT | Europe (13 countries), Israel | 2.3 | Males and females w/ prior TIA or stroke | 782 | 73 (> 25) | 44 | 13 | 19.1 | 300 mg qd | ✓ | | ✓
CVD Secondary Prevention | Farrell, 1991 (UK-TIA)65 Fair | RCT | United Kingdom | 4 | Males and females w/ prior TIA or stroke | 2,449 | 59.8 (≥ 40) | 26.9 | 4.4 | 53.1 | 150 mg (2 tablets; 300 mg total per day) bid or 300 mg (2 tablets; 1200 mg total per day) bid | ✓ | | ✓
CVD Secondary Prevention | Juul-Moller, 1992 (SAPAT)54 Fair | RCT | Sweden | 4.2 | Males and females w/stable angina | 2,035 | 67 (30-80) | 48 | NR | 16 | 75 mg qd | ✓ | ✓ | ✓
CVD Secondary Prevention | PARIS, 1980^71^ Good | RCT | United States, United Kingdom | 3.4 | Males and females w/ prior MI | 1,216 | 56.3 (30-74) | 13.2 | NR | 26.8 | 324 mg (972 mg total per day) tid | ✓ | | ✓
CVD Secondary Prevention | Petersen, 1989 (Copenhagen AFASAK)80 Fair | RCT | Denmark | 2 | Males and females w/ chronic AF | 672 | 74.9 (38-91) | 45.8 | 8.8 | 35.9 | 75 mg qd | ✓ | | ✓
CVD Secondary Prevention | SALT, 1991^74^ Good | RCT | Sweden | 2.67 | Males and females w/ prior TIA or stroke | 1,360 | 67 (50-79) | 34.2 | 12.9 | 25.4 | 75 mg qd | ✓ | | ✓
CVD Secondary Prevention | Sato, 2006 (JAST)81 Fair | RCT | Japan | 2.1 | Males and females w/ AF | 871 | 65.1 (NR) | 29.6 | 14 | 30.4 | 150-200 mg qd (or qod if 330 mg preferred) | ✓ | | ✓
CVD Secondary Prevention | SPAF, 1991^76^ Good | RCT | United States | 1.3 | Males and females w/ AF | 1,120 | 67 (NR) | 29.5 | 17.5 | 16 | 325 mg qd | ✓ | | ✓
Colorectal adenoma prevention | Baron, 2003 (AFPPS)77 Good (KQ1); Fair (KQ2, KQ6) | RCT, 3×2 factorial | United States | 2.7 | Males and females w/ prior colorectal adenoma | 1,121 | 57.5 (21-80) | 36.5 | NR | 14.9 | 81 or 325 mg qd | ✓ | ✓ | ✓
Colorectal adenoma prevention | Benamouzig, 2003 (APACC)82 Fair | RCT | France | 1 | Males and females w/ prior colorectal adenoma | 272 | 57.8 (18-75) | 30.1 | NR | 23.16 | 160 or 300 mg qd | | | ✓
Colorectal adenoma prevention | Logan, 2008 (ukCAP)68 Fair | RCT, 2×2 factorial | United Kingdom, Denmark | 3.4 | Males and females w/ prior colorectal adenoma | 945 | 57.8 (27.6-74.6) | 43.1 | NR | NR | 300 mg alone or with 0.5 mg folic acid qd | ✓ | ✓ | ✓

* These are three additional CVD primary prevention trials that were excluded from the companion systematic review as they reported no relevant outcomes41

† Median

Abbreviations: ABI = ankle brachial index; AF = atrial fibrillation; ASA= acetylsalicylic acid; bid= twice daily; CVD= cardiovascular disease; DVT= deep vein thrombosis; IHD = ischemic heart disease; KQ= key question; MI= myocardial infarction; mg= milligram(s); NR= not reported; PE= pulmonary embolism; qd= every day; qod= every other day; rand= randomized; RCT= randomized controlled trial; TIA = transient ischemic attack; tid= three times a day; w/= with

Table 7 Brief Description of Included Cohort Studies (KQ 6)

Author, Year Quality | Design | Country | Mean Followup (Years) | Population | N | Mean Age and Range (years) | % Female | % Diabetes | % Current Smokers | ASA Dose and Frequency
de Berardis, 2012^85^ Good | Cohort, Retrospective | Italy | 5.7^*^ | Males and females aged ≥ 30 years, new aspirin users vs. never users | 372,850 | 69.4 (30-95) | 53.1 | 15 | NR | ≤ 300 mg with most recent prescription filled ≥ 75 days prior to bleeding event
Ekstrom, 2013 (SNDR)86 Fair | Cohort, Prospective | Sweden | 3.9 | Males and females w/ diabetes | 18,646 | 62.3 (30-80) | 44.7 | 100 | 15.4 | 75 mg qd
Huang, 2010 (HPS)83 Fair | Cohort, Prospective | United States | 11.4 | Male health professionals | 32,989 | 60.9 (NR) | 0 | 5.4 | 5.2 | Any dose ≥ 2 times/week
Huang, 2011 (NHS)84 Fair | Cohort, Prospective | United States | 12.5 | Female nurses | 87,680 | 56.6 (30-55) | 100 | 5 | 17.6 | 325 mg ≥ 2 tablets/week

* Median

Abbreviations: ASA= acetylsalicylic acid; mg= milligrams; NR= not reported; qd= daily; w/= with

We also included the results from three publications that described IPD meta-analyses8,10,87 and one that described study-level meta-analyses.44 These meta-analyses provided additional unpublished data obtained from primary study investigators and included multiple meta-analyses on different subsets of trials to address sequential or differing hypotheses. We briefly describe the differences in inclusion and exclusion criteria for the main analyses from each publication relevant to our KQs in Table 8. We also identify which of the 10 main CVD primary prevention trials are included in each. Detailed study design, baseline demographics, and intervention characteristics of individual studies and meta-analyses are available in Appendix D and Appendix E Tables 1–3.

Table 8 Comparison of Inclusion Criteria of Included Meta-Analyses^*^

Criteria | Rothwell 2011 Analysis 1 | Rothwell 2011 Analysis 2 | Rothwell 2012 Analysis 1 | Rothwell 2012 Analysis 2 | ATT Collaboration, 2009^87^ | Seshasai, 2012^44^
Included populations | 1° and 2° CVD prevention | 1° and 2° CVD prevention | 1° and 2° CVD prevention | 1° CVD prevention | 1° CVD prevention (non-diabetics) and 2° CVD prevention | 1° CVD prevention
ASA dose | Any dose | Any dose | Any dose | < 300 mg/day | Any | Any
Frequency | Daily | Daily | Daily | Daily | Any | Any
Intervention duration | ≥ 4 years | ≥ 4 years | ≥ 90 days | ≥ 90 days | ≥ 2 years | ≥1 year
Total number of studies; participants; cancer outcomes | k=7, n=23,535; 657 cancer deaths | k=3; n=12,659^†^; 1,634 cancer deaths | k=34^‡^; n=69,224; 1,226 cancer deaths | k=6; n= 35,535; 1,632 incident cancers | k=22; n=112,000; no cancer outcomes | k=9, n=102,621; cancer deaths 1,512
1° CVD prevention studies | AAA, BMD, ETDRS, JPAD, POPADAD, TPT^§^ | BMD, TPT^§^ | AAA, BMD, ETDRS, HOT, JPAD, POPADAD, PPP, TPT | AAA, HOT, JPAD║, POPADAD, PPP, TPT | BMD, HOT, PHS, PPP, TPT, WHS | AAA, BMD, HOT, JPAD, PHS, POPADAD, PPP^¶^, TPT, WHS
2° CVD prevention studies | UK-TIA^**^ | UK-TIA | UK-TIA, EAFT, SALT, ESPS-2, SAPAT, 21 “small trials” | None | 16 trials | None

* All outcomes occurred during trials except in 2^nd^ analysis by Rothwell and colleagues (2011)8 who report 20 year mortality for BMD, TPT, and UK-TIA

† Also conducted sub-analyses on 10,502 patients who had 5 or more years of treatment.

‡ Also analyzed nonvascular death among 77,549 participants in 51 trials

§ Includes arms of TPT in which anticoagulant was co-administered with ASA.

║ Substituted cancer mortality for nonfatal cancer

¶ Not included for cancer mortality

** Included data from SAPAT for trial-level meta-analyses

Abbreviations: ASA = acetylsalicylic acid; CVD = cardiovascular disease; mg = milligram(s)

One or more outcomes relevant to our review were available from all 10 of the RCTs that were included in our companion systematic review41 of ASA for the primary prevention of CVD: the Primary Prevention Project (PPP),61 the Hypertension Optimal Treatment (HOT) study,67 the Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes (JPAD) study,70 PHS,73 the Early Treatment Diabetic Retinopathy Study (ETDRS),64 the British Medical Doctor (BMD) study,72 the Prevention of Progression of Arterial Disease and Diabetes (POPADAD) study,57 the Thrombosis Prevention Trial (TPT),69 the Aspirin for Asymptomatic Atherosclerosis (AAA) study,66 and the Women's Health Study (WHS).60 Three of these 10 trials were conducted among healthy male72,73 or female health professionals60 and the other seven among participants with increased levels of CVD risk due to conditions such as diabetes57,64,70 or hypertension.67 Only two of the trials of ASA for CVD primary prevention, WHS60 and PHS,73 also evaluated primary cancer prevention as a main study aim. We included three other CVD primary prevention trials that excluded patients who had apparent CVD at the time of enrollment that were not included by our companion review since CVD outcomes were not available.51-53

We included 13 trials that selected participants based on preexisting CVD (prior MI;59,71,75 stroke or transient ischemic attack;62,63,65,74 deep vein thrombosis or pulmonary emboli;58,78 stable angina,54 or atrial fibrillation76,80,81) and one that restricted enrollment to individuals with a cervical bruit and at least 50 percent carotid artery stenosis (though not symptomatic CVD).79 Three additional included trials focused on colorectal adenoma recurrence and CRC prevention among participants with prior colon adenomas.68,77,82

Three of the cohort studies included for adverse outcomes included presumed mixtures of primary and secondary CVD prevention populations83-85 and the fourth was restricted to persons with diabetes and no prior CVD.86

## KQ 1 Does Regular Aspirin Use Reduce Total Cancer Mortality or All-Cause Mortality in Adults Taking (or Eligible for) Aspirin for Primary Prevention?

### Cancer Mortality

Cancer mortality outcomes were available from end-of-trial reporting, data linkage, or additional posttrial followup from 19 fair- or good-quality RCTs comparing ASA to no ASA control groups (Appendix E Table 4).51,57-74 Cancer mortality outcomes were also available from two IPD meta-analyses conducted by Rothwell and colleagues (2011 and 2012)8,10 and by type (11 sites separately, several types of groups) in one of these IPD meta-analyses.8

End-of-trial cancer mortality outcomes were available from 10 of the RCTs57,60,61,64,66,67,69,70,72,73 that were included in our companion review on ASA for CVD primary prevention (n=103,787; 1,513 cancer deaths). Doses of ASA among these trials ranged from an average of 50 mg per day (prescribed as 100 mg every other day) to 650 mg per day and were intended to be delivered for an average of 3.6 to 10.1 years. WHS60 and PHS73 were the two largest trials, making up nearly 60 percent of all participants across the 10 CVD primary prevention trials and nearly 50 percent of cancer deaths. These were also the only two trials to evaluate low-dose ASA among healthy populations unselected for having cardiac risk factors, such as diabetes or hypertension. They differed from the other CVD primary prevention trials in ASA regimen, with ASA prescribed every other day instead of daily.

Across the 10 main CVD primary prevention trials, 760 of 52,724 participants randomized to ASA intervention and 753 of 51,063 participants randomized to control groups died from cancer (Figure 2). The risk of dying from cancer was 4 percent lower among patients allocated to ASA interventions compared to control groups, with no statistical heterogeneity (I^2^=0.0%; p=0.891), but differences were not statistically significant (RR, 0.96 [95% CI, 0.87 to 1.06]). The absolute reduction in cancer mortality risk for someone with a median level of baseline risk (median among our included trials) would be 0.14 fewer cancer deaths per 1,000 person-years for patients allocated to ASA compared to no ASA. The 95% CI, however, includes an increase of 0.21 cancer deaths per 1,000 person-years in those taking ASA. Among the seven trials of very low-dose ASA (≤100 mg per day), results were similar (RR, 0.95 [95% CI, 0.85 to 1.06]) (Table 9). In other sensitivity analyses, the greatest reduction in risk of cancer death among patients allocated to ASA compared to no ASA occurred when restricting to trials of daily-dose ASA that also had an average intended followup of 4 years or greater. These results, however, remained not statistically significantly different. Relatively short duration of intended treatment and followup periods for many trials may have limited their ability to detect a cancer effect.

Figure 2 Forest Plot of Cancer Mortality, CVD Primary Prevention Trials

Note: PHS and WHS are alternate day dosage studies (100 mg qod and 325 mg qod, respectively)

Abbreviations: ABI = ankle-brachial index; ASA = acetylsalicylic acid; CI = confidence interval; CVD = cardiovascular disease; IHD = ischemic heart disease; RR = relative risk; w/ = with

This figure is a forest plot of the relative risk of cancer mortality among CVD primary prevention trials.

Table 9 Sensitivity Analyses by Dosage and Frequency of Cancer Incidence, Cancer Mortality, and All-Cause Mortality

Outcome | Trials | Sensitivity Analysis | k | ASA (number of cases / number of participants) | No ASA (number of cases / number of participants) | Pooled RR (95% CI) | Pooled RR When Long-Term WHS Data Used^*^ | Names of Trials
Cancer mortality | CVD Primary Prevention Trials | All trials | 10 | 760/52,724 | 753/51,063 | 0.96 (0.87, 1.06) | 0.97 (0.90, 1.05) | PPP, HOT, JPAD, PHS, ETDRS, BMD, POPADAD, TPT, AAA, WHS
Cancer mortality | CVD Primary Prevention Trials | Dose ≤ 325 mg per day | 8 | 669/47,439 | 692/47,498 | 0.97 (0.87, 1.08) | 0.98 (0.90, 1.06) | PPP, HOT, JPAD, PHS, POPADAD, TPT, AAA, WHS
Cancer mortality | CVD Primary Prevention Trials | Dose ≤ 100 mg per day | 7 | 590/36,402 | 624/36,464 | 0.95 (0.85, 1.06) | 0.97 (0.89, 1.05) | PPP, HOT, JPAD, POPADAD, TPT, AAA, WHS
Cancer mortality | CVD Primary Prevention Trials | Daily dose | 8 | 397/21,753 | 386/20,087 | 0.93 (0.81, 1.07) | 0.93 (0.81, 1.07) | PPP, HOT, JPAD, ETDRS, BMD, POPADAD, TPT, AAA
Cancer mortality | CVD Primary Prevention Trials | Every other day dose | 2 | 363/30,971 | 367/30,976 | 0.99 (0.86, 1.14) | 0.99 (0.90, 1.09) | PHS, WHS
Cancer mortality | CVD Primary Prevention Trials | Followup ≥ 5 years | 7 | 606/39,837 | 600/38,126 | 0.94 (0.84, 1.06) | 0.96 (0.89, 1.05) | WHS, TPT, POPADAD, AAA, PHS, BMD, ETDRS
Cancer mortality | CVD Primary Prevention Trials | Followup ≥ 4 years | 8 | 621/41,099 | 619/39,403 | 0.94 (0.84, 1.05) | 0.96 (0.88, 1.04) | WHS, TPT, JPAD, POPADAD, AAA, PHS, BMD, ETDRS
Cancer mortality | CVD Primary Prevention Trials | Followup ≥ 4 years and daily dose | 6 | 258/10,128 | 252/8,427 | 0.87 (0.73, 1.03) | 0.87 (0.73, 1.03) | TPT, JPAD, POPADAD, AAA, BMD, ETDRS
Cancer mortality | All Included Trials | All trials | 19 | 842/59,683 | 841/56,801 | 0.93 (0.85, 1.03) | 0.95 (0.88, 1.03) | CDPA, ESPS-2, EAFT, SALT, DAMAD, ASPIRE, PARIS, ukCAP, PPP, HOT, UK-TIA, JPAD, PHS, ETDRS, BMD, POPADAD, TPT, AAA, WHS
Cancer mortality | All Included Trials | Dose ≤ 325 mg per day | 13 | 718/51,051 | 751/51,087 | 0.96 (0.86, 1.06) | 0.97 (0.90, 1.05) | ESPS-2, EAFT, SALT, ASPIRE, ukCAP, PPP, HOT, JPAD, PHS, POPADAD, TPT, AAA, WHS
Cancer mortality | All Included Trials | Dose ≤ 100 mg per day | 10 | 627/39,138 | 668/39,208 | 0.94 (0.84, 1.05) | 0.96 (0.88, 1.04) | ESPS-2, SALT, ASPIRE, PPP, HOT, JPAD, POPADAD, TPT, AAA, WHS
Cancer mortality | All Included Trials | Daily dose | 17 | 479/28,712 | 474/25,825 | 0.89 (0.79, 1.01) | 0.89 (0.79, 1.01) | CDPA, ESPS-2, EAFT, SALT, DAMAD, ASPIRE, PARIS, ukCAP, PPP, HOT, UK-TIA, JPAD, ETDRS, BMD, POPADAD, TPT, AAA
Cancer mortality | All Included Trials | Every other day dose | 2 | 363/30,971 | 367/30,976 | 0.99 (0.86, 1.14) | 0.99 (0.90, 1.09) | PHS, WHS
Cancer mortality | All Included Trials | Dose ≤ 325 mg per day and daily dose | 11 | 355/20,080 | 384/20,111 | 0.93 (0.80, 1.07) | 0.93 (0.80, 1.07) | ESPS-2, EAFT, SALT, ASPIRE, ukCAP, PPP, HOT, JPAD, POPADAD, TPT, AAA
Cancer mortality | All Included Trials | Followup ≥ 4 years | 9 | 645/42,720 | 644/40,217 | 0.92 (0.82, 1.02) | 0.95 (0.87, 1.03) | WHS, TPT, JPAD, POPADAD, AAA, PHS, UK-TIA, BMD, ETDRS
Cancer mortality | All Included Trials | Followup ≥ 4 years and daily dose | 7 | 282/11,749 | 277/9,241 | 0.83 (0.70, 0.98) | 0.83 (0.70, 0.98) | TPT, JPAD, POPADAD, AAA, UK-TIA, BMD, ETDRS
All-cause mortality | CVD Primary Prevention Trials | All trials | 10 | 2,199/52,724 | 2,204/51,063 | 0.94 (0.88, 0.99) | 0.97 (0.93, 1.02) | PPP, HOT, JPAD, PHS, ETDRS, BMD, POPADAD, TPT, AAA, WHS
All-cause mortality | CVD Primary Prevention Trials | Dose ≤ 325 mg per day | 8 | 1,589/47,439 | 1,687/47,498 | 0.94 (0.88, 1.01) | 0.98 (0.93, 1.03) | PPP, HOT, JPAD, PHS, POPADAD, TPT, AAA, WHS
All-cause mortality | CVD Primary Prevention Trials | Dose ≤ 100 mg per day | 7 | 1,372/36,402 | 1,460/36,464 | 0.94 (0.88, 1.01) | 0.99 (0.93, 1.04) | PPP, HOT, JPAD, POPADAD, TPT, AAA, WHS
All-cause mortality | CVD Primary Prevention Trials | Daily dose | 8 | 1,373/21,753 | 1,335/20,087 | 0.93 (0.86, 1.00) | 0.93 (0.86, 1.00) | PPP, HOT, JPAD, ETDRS, BMD, POPADAD, TPT, AAA
All-cause mortality | CVD Primary Prevention Trials | Every other day dose | 2 | 826/30,971 | 869/30,976 | 0.95 (0.87, 1.04) | 1.00 (0.94, 1.07) | PHS, WHS
All-cause mortality | CVD Primary Prevention Trials | Followup ≥ 5 years | 7 | 1,819/39,837 | 1,783/38,126 | 0.94 (0.89, 1.00) | 0.98 (0.93, 1.03) | PHS, ETDRS, BMD, POPADAD, TPT, AAA, WHS
All-cause mortality | CVD Primary Prevention Trials | Followup ≥ 4 years | 8 | 1,853/41,099 | 1,821/39,403 | 0.94 (0.89, 1.00) | 0.98 (0.93, 1.03) | JPAD, PHS, ETDRS, BMD, POPADAD, TPT, AAA, WHS
All-cause mortality | CVD Primary Prevention Trials | Followup ≥ 4 years and daily dose | 6 | 1,027/10,128 | 952/8,427 | 0.93 (0.86, 1.02) | 0.93 (0.86, 1.02) | JPAD, ETDRS, BMD, POPADAD, TPT, AAA
All-cause mortality | All Included Trials | All trials | 25 | 3,322/64,921 | 3,246/61,692 | 0.93 (0.89, 0.98) | 0.96 (0.92, 1.00) | SPAF, CDPA, WARFASA, ESPS-2, JAST, EAFT, ACBS, SALT, AFPPS, ASPIRE, AMIS, ukCAP, PARIS, PPP, HOT, UK-TIA, SAPAT, JPAD, PHS, ETDRS, BMD, POPADAD, TPT, AAA, WHS
All-cause mortality | All Included Trials | Dose ≤ 325 mg per day | 20 | 2,226/54,986 | 2,394/54,693 | 0.93 (0.88, 0.98) | 0.96 (0.92, 1.01) | SPAF, WARFASA, ESPS-2, JAST, EAFT, ACBS, SALT, AFPPS, ASPIRE, ukCAP, PPP, HOT, UK-TIA (300 mg arm only), SAPAT, JPAD, PHS, POPADAD, TPT, AAA, WHS
All-cause mortality | All Included Trials | Dose ≤ 100 mg per day | 13 | 1,722/40,729 | 1,863/40,803 | 0.93 (0.87, 0.99) | 0.97 (0.92, 1.02) | ESPS-2, WARFASA, SALT, AFPPS (81 mg arm only), ASPIRE, PPP, HOT, SAPAT, JPAD, POPADAD, TPT, AAA, WHS
All-cause mortality | All Included Trials | Daily dose | 23 | 2,496/33,950 | 2,377/30,716 | 0.93 (0.88, 0.98) | 0.93 (0.88, 0.98) | SPAF, CDPA, WARFASA, ESPS-2, JAST, EAFT, ACBS, SALT, AFPPS, ASPIRE, AMIS, ukCAP, PARIS, PPP, HOT, UK-TIA, SAPAT, JPAD, ETDRS, BMD, POPADAD, TPT, AAA
All-cause mortality | All Included Trials | Every other day dose | 2 | 826/30,971 | 869/30,976 | 0.95 (0.87, 1.04) | 1.00 (0.94, 1.07) | PHS, WHS
All-cause mortality | All Included Trials | Dose ≤ 325 mg per day and daily dose | 18 | 1,400/24,015 | 1,525/23,717 | 0.92 (0.85, 0.98) | 0.92 (0.85, 0.98) | SPAF, WARFASA, ESPS-2, JAST, EAFT, ACBS, SALT, AFPPS, ASPIRE, ukCAP, PPP, HOT, UK-TIA, SAPAT, JPAD, POPADAD, TPT, AAA
All-cause mortality | All Included Trials | Followup ≥ 4 years | 10 | 2,156/43,729 | 2,049/41,243 | 0.93 (0.88, 0.99) | 0.97 (0.93, 1.02) | UK-TIA, SAPAT, JPAD, PHS, ETDRS, BMD, POPADAD, TPT, AAA, WHS
All-cause mortality | All Included Trials | Followup ≥ 4 years and daily dose | 8 | 1,330/12,758 | 1,180/10,267 | 0.92 (0.85, 0.99) | 0.92 (0.85, 0.99) | UK-TIA, SAPAT, JPAD, ETDRS, BMD, POPADAD, TPT, AAA
Cancer incidence | CVD Primary Prevention Trials | All trials | 6 | 2,155/37,301 | 2,139/35,625 | 0.98 (0.93, 1.04) | 0.97 (0.92, 1.01) | WHS, HOT, AAA, PPP, POPADAD, BMD
Cancer incidence | CVD Primary Prevention Trials | Dose ≤ 325 mg per day | 5 | 2,036/33,872 | 2,081/33,915 | 0.98 (0.92, 1.04) | 0.97 (0.92, 1.01) | PPP, HOT, POPADAD, AAA, WHS
Cancer incidence | CVD Primary Prevention Trials | Dose ≤ 100 mg per day | 5 | 2,036/33,872 | 2,081/33,915 | 0.98 (0.92, 1.04) | 0.97 (0.92, 1.01) | PPP, HOT, POPADAD, AAA, WHS
Cancer incidence | CVD Primary Prevention Trials | Daily dose | 5 | 717/17,367 | 712/15,683 | 0.93 (0.84, 1.03) | 0.93 (0.84, 1.03) | PPP, HOT, BMD, POPADAD, AAA
Cancer incidence | CVD Primary Prevention Trials | Every other day dose | 1 | 1438/19934 | 1427/19,942 | 1.01 (0.94, 1.08) | 0.98 (0.93, 1.03) | WHS
Cancer incidence | CVD Primary Prevention Trials | Followup ≥ 5 years | 4 | 1,768/25,676 | 1,739/23,965 | 0.98 (0.92, 1.05) | 0.97 (0.92, 1.02) | WHS, POPADAD, AAA, BMD
Cancer incidence | CVD Primary Prevention Trials | Followup ≥ 4 years | 4 | 1,768/25,676 | 1,739/23,965 | 0.98 (0.92, 1.05) | 0.97 (0.92, 1.02) | WHS, POPADAD, AAA, BMD
Cancer incidence | CVD Primary Prevention Trials | Followup ≥ 4 years and daily dose | 3 | 330/5,742 | 312/4,023 | 0.88 (0.75, 1.02) | 0.88 (0.75, 1.02) | POPADAD, AAA, BMD
Cancer incidence | All Included Trials | All trials | 12 | 2,288/43,858 | 2,269/41,707 | 0.98 (0.93, 1.04) | 0.97 (0.93, 1.01) | AFPPS, ESPS-2, SAPAT, AMIS, HOT, BMD, PPP, ukCAP, ASPIRE, WHS, POPADAD, AAA
Cancer incidence | All Included Trials | Dose ≤ 325 mg per day | 10 | 2,119/38,162 | 2,168/37,740 | 0.97 (0.92, 1.03) | 0.96 (0.92, 1.01) | ESPS-2, AFPPS, ASPIRE, ukCAP, PPP, HOT, SAPAT, POPADAD, AAA, WHS
Cancer incidence | All Included Trials | Dose ≤ 100 mg per day | 9 | 2,107/37,690 | 2,153/37,373 | 0.98 (0.92, 1.04) | 0.97 (0.92, 1.01) | ESPS-2, AFPPS, ASPIRE, PPP, HOT, SAPAT, POPADAD, AAA, WHS
Cancer incidence | All Included Trials | Daily dose | 11 | 850/23,924 | 842/21,765 | 0.94 (0.85, 1.02) | 0.94 (0.85, 1.02) | ESPS-2, AFPPS, ASPIRE, AMIS, ukCAP, PPP, HOT, SAPAT, BMD, POPADAD, AAA
Cancer incidence | All Included Trials | Every other day dose | 1 | 1,438/19,934 | 1,427/19,942 | 1.01 (0.94, 1.08) | 0.98 (0.93, 1.03) | WHS
Cancer incidence | All Included Trials | Dose ≤ 325 mg per day and daily dose | 9 | 681/18,228 | 741/17,798 | 0.91 (0.82, 1.01) | 0.91 (0.82, 1.01) | ESPS-2, AFPPS, ASPIRE, ukCAP, PPP, HOT, SAPAT, POPADAD, AAA
Cancer incidence | All Included Trials | Followup ≥ 4 years | 5 | 1,778/26,685 | 1,758/24,991 | 0.98 (0.92, 1.04) | 0.96 (0.92, 1.01) | WHS, SAPAT, AAA, POPADAD, BMD
Cancer incidence | All Included Trials | Followup ≥ 4 years and daily dose | 4 | 340/6,751 | 331/5,049 | 0.86 (0.74, 0.99) | 0.86 (0.74, 0.99) | SAPAT, POPADAD, AAA, BMD

* Raw data to left columns do not reflect this analysis

Abbreviations: ASA = acetylsalicylic acid; CI = confidence interval; CVD = cardiovascular disease; mg = milligram(s); RR = relative risk

Nine additional fair- or good-quality CVD secondary prevention or colorectal adenoma prevention RCTs51,58,59,62,63,65,68,71,74 provided cancer mortality outcomes. These trials were all relatively short term (1.8 to 4 years average followup), contributing just 12,697 additional study participants and 170 cancer deaths. Nonetheless, overall absolute cancer death rates in the separate study populations were similar (1.46% over 3 to 10 years in a CVD primary prevention population and 1.34% over 1 to 4 years in a secondary prevention population), suggesting a higher short-term cancer death risk in nonprimary prevention populations. ASA doses ranged from 50 to 1,200 mg per day and four trials tested doses greater than 900 mg per day.51,59,65,71 Across all 19 trials (n=116,484; 1,683 cancer deaths), cancer mortality among participants randomized to ASA compared to no ASA remained nonstatistically significant and imprecise (RR, 0.93 [95% CI, 0.85 to 1.03]) (Figure 3). In sensitivity analyses, a statistically significant risk reduction occurred only after restricting to trials of daily ASA that also had 4 years of followup or greater (k=7 RCTs; n=20,990; 559 cancer deaths) (Table 9). None of the trials in this subset evaluated low-dose ASA (≤325 mg) interventions in healthy adults without cardiac risk factors.

Figure 3 Forest Plot of Cancer Mortality, All Included Trials

* Trials included two separate ASA arms which were combined for analysis

Note: PHS and WHS are alternate day dosage studies (100 mg qod and 325 mg qod, respectively)

Abbreviations: ABI = ankle-brachial index; ASA = acetylsalicylic acid; CI = confidence interval; CVD = cardiovascular disease; DVT = deep vein thrombosis; IHD = ischemic heart disease; MI = myocardial infarction; RR = relative risk; PE = pulmonary emboli; TIA = transient ischemic attack; w/ = with

This figure is a forest plot of the relative risk of cancer mortality among all included trials.

In an IPD meta-analysis by Rothwell and colleagues (2012) of 51 trials of any daily dose of ASA for longer than 90 days in any population (except secondary prevention of cancer or polyps), end-of-trial cancer deaths were reduced significantly (OR, 0.85 [95% CI, 0.76 to 0.96]), with similar results when analyses used nonvascular deaths as a surrogate when cancer-specific deaths were not reported.10 Significant effects were confined to time periods of 5 years or longer after randomization (vs. 0 to 2.9 years or 3.0 to 4.9 years) when analyses were stratified by time of followup (32 trials contributing data), with support for an effect before 3 years only with higher-dose (≥300 mg) daily ASA. End-of-trial cancer deaths were not reported separately for the six low-dose CVD primary prevention trials, and analyses for cancer types mixed fatal and nonfatal cancers. As such, these data are reported as part of cancer incidence.

Rothwell and colleagues (2011) summarized cancer mortality effects in a separate time-to-event IPD meta-analysis of seven trials of any dosage of ASA with at least 4 years scheduled treatment duration (allowing cotreatments [e.g., warfarin] if both groups received them) in primary and secondary CVD prevention populations.8 In 23,535 patients with 657 deaths (and a somewhat higher overall rate of cancer deaths of 2.8%), ASA reduced overall cancer mortality (hazard ratio [HR], 0.82 [95% CI, 0.70 to 1.06]), with effects beginning mainly after 5 years. Cancer-specific findings were limited by few cases and limited power due to reporting within followup periods only. Nonetheless, fewer lymphomas and CRC deaths were reported.

Findings differ from our primary analyses since Rothwell and colleagues (2011) represent time-to-event data, although a meta-analysis of event rates reported in the same publication (OR, 0.79 [95% CI, 0.68 to 0.92]) also differs from our findings. A more likely explanation relates to differences in included studies; just six of 10 studies in our CVD primary prevention trial analyses were represented in the Rothwell and colleagues analysis (TPT, JPAD, AAA, POPADAD, BMD, and ETDRS).57,64,66,69,70,72 The additional trials in our analysis represent studies in CVD primary prevention populations with a median duration of scheduled treatment of less than 4 years (3.8 and 3.6 years for HOT and PPP, respectively)61,67 or with every other day ASA treatment (WHS and PHS).60,73 We excluded the other two additional studies in the analysis by Rothwell and colleagues54,65 since they were CVD secondary prevention trials. For one trial, we included the outcome for cancer incidence (not mortality) since the outcome was the number of persons discontinuing treatment for a cancer diagnosis (SAPAT).54 One final difference between the analyses was that Rothwell and colleagues' (2011) cancer mortality data also represented participants treated with warfarin (TPT).69

For our analysis of both primary and secondary prevention trials, all studies in Rothwell and colleagues (2011)8 are included, but represent just seven of the 19 trials we pooled.57,64-66,69,70,72 Our other 12 trials had treatment durations of less than 4 years or used alternate day ASA dosing.

We conducted a series of sensitivity analyses examining various aspirin regimens (Table 9). Restricting our analyses to the eight CVD primary prevention trials with at least 4 years treatment duration, like Rothwell and colleagues (2011), slightly changed our results. By further restricting our analysis to only studies with daily use and a minimum treatment duration, our cancer mortality results came closer to those of Rothwell and colleagues (13% nonstatistically significant benefit in our data compared to 21% statistically significant reduction in their data), despite excluding SAPAT, UK-TIA, and the warfarin arm of TPT. By adding a secondary prevention trial (UK-TIA), we essentially reproduced Rothwell and colleague's analysis (18% statistically significant reduction in cancer mortality; data not shown).

Thus, differences between meta-analyses of overall cancer mortality in our review and in Rothwell and colleagues' review (2011) primarily reflect choices for included studies, particularly our inclusion of WHS and PHS, which represent alternate day ASA use. Longer-term followup of WHS data (17.5 median years followup after 10.1 median years of scheduled alternate day 100 mg ASA) suggests delayed impact on any cancer outcome beyond 10 years, and confirmed an effect on invasive CRC incidence only, but not cancer incidence or mortality.88 These data support expectation of some cancer effects from nondaily ASA use.

In an additional IPD meta-analysis, Rothwell and colleagues (2011)8 reported 20-year cancer mortality for patients in three U.K.-based trials with at least 5 years of scheduled treatment.65,69,72 Two trials were CVD primary prevention trials conducted exclusively in men.69,72 The third trial was nearly three quarters male and restricted to patients with a prior transient ischemic attack or stroke.65 Doses of ASA evaluated were 75, 300, 500, and 1,200 mg per day. At the time of randomization, 31 to 53 percent of participants were current smokers. Over 20 years, 1,378 cancer deaths occurred among 10,502 patients (13.1% overall cancer death rate). During the first 10 years of observation, patients allocated to ASA had 21 percent lower risk of cancer mortality compared to patients allocated to no ASA (HR, 0.79 [95% CI, 0.66 to 0.93]). Similar results were found for cancer mortality risk at 10 to 20 years (HR, 0.77 [95% CI, 0.67 to 0.89]) or for the entire period (HR, 0.78 [95% CI, 0.70 to 0.87]).

We focused on overall cancer mortality, since cancer-specific deaths from trial data applicable to low-dose CVD primary prevention populations were limited by power (i.e., few cases and data only within stratified time periods, not cumulative).8 Nonetheless, in Rothwell and colleagues' (2011) IPD meta-analysis representing daily ASA use for 4 years or greater in mostly CVD primary prevention users, type-specific mortality was unaffected for any individual cancer within 5 years of followup, but reduced HRs were seen after 5 years or greater for solid GI cancer deaths (specifically, pancreatic cancer (HR, 0.25 [95% CI, 0.07 to 0.92]) and CRC (HR, 0.41 [95% CI, 0.17 to 1.00]), but not for solid nonGI or hematological cancers. By histological type, only incidence of adenocarcinomas was reduced in daily ASA users after at least 5 years of followup (HR, 0.53 [95% CI, 0.35 to 0.81]). No subtype analyses had interaction terms or statistical correction for multiple comparisons, and thus are most compatible with hypothesis generation.

### All-Cause Mortality

All-cause mortality outcomes for participants randomized to ASA or no ASA were available from 27 fair- or good-quality RCTs (Appendix E Table 5).53,54,57-81 Results were also available from two IPD meta-analyses.10,87

End-of-trial all-cause mortality outcomes were available from each of the 10 main CVD primary prevention RCTs (n=103,787; 4,403 deaths) (Figure 4).57,60,61,64,66,67,69,70,72,73 Doses of ASA ranged from an average of 50 to 650 mg per day and were intended to be delivered for an average of 3.6 to 10.1 years. Overall, 2,199 of 52,724 patients allocated to ASA and 2,204 of 51,063 patients allocated to no ASA died from any cause.57,60,61,64,66,67,69,70,72,73 The risk of mortality was 6 percent lower for the ASA group compared to the no ASA group and the difference was statistically significantly different (RR, 0.94 [95% CI, 0.88 to 0.99). Statistical heterogeneity across trials was minimal (I^2^=0.0%; p=0.995). For a population with an annual mortality risk similar to the median control group risk (9.55 deaths per 1,000 person-years) among these included trials, ASA intervention would lead to 0.57 fewer deaths per 1,000 person-years. The number needed to treat for 1 year to benefit would be 1,754 (Table 10). Sensitivity analyses conducted in the CVD primary prevention review using Peto's OR found similar results (OR, 0.93 [95% CI, 0.88 to 0.99]).41 When restricting by dose, dose frequency, or minimum length of followup or when substituting longer-term mortality effects at 17.5 years from WHS, however, all-cause mortality outcomes were no longer statistically significantly different (Table 9).

Figure 4 Forest Plot of All-Cause Mortality, CVD Primary Prevention Trials

Note: PHS and WHS are alternate day dosage studies (100 mg qod and 325 mg qod, respectively)

Abbreviations: ABI = ankle-brachial index; ASA = acetylsalicylic acid; CI = confidence interval; CVD = cardiovascular disease; IHD = ischemic heart disease; RR = relative risk; w/ = with

This figure is a forest plot of the relative risk of all-cause mortality among CVD primary prevention trials.

Table 10 Absolute Risk Reduction and Number Needed to Treat or Harm With ASA, CVD Primary Prevention Trials

Included ASA Doses | Outcome | Risk Level^‡^ | Baseline Risk of Outcome, Events per 10,000 p-y | Baseline Risk of Outcome, Events per 1,000 p-y | Events prevented per 10,000 p-y (95% CI) | Events prevented per 1,000 p-y (95% CI) | NNT-B per Year (95% CI)^†^ | NNT-H per Year (95% CI)^†^
All ASA doses | All-cause mortality^*^ | Low | 31.9 | 3.19 | 1.9 (0.3 to 3.8) | 0.19 (0.03 to 0.38) | 5,263 (2,632 to 33,333) | --
All ASA doses | All-cause mortality^*^ | Med | 95.5 | 9.55 | 5.7 (1.0 to 11.5) | 0.57 (0.10 to 1.15) | 1,754 (870 to 10,000) | --
All ASA doses | All-cause mortality^*^ | High | 135.4 | 13.54 | 8.1 (1.4 to 16.3) | 0.81 (0.14 to 1.63) | 1,235 (613 to 7,143) | --
All ASA doses | Fatal CVD (fatal MI/coronary, fatal stroke, and CVD mortality)^*^ | Low | 6.3 | 0.63 | 0.4 (-0.2 to 0.9) | 0.04 (-0.02 to 0.09) | -- | --
All ASA doses | Fatal CVD (fatal MI/coronary, fatal stroke, and CVD mortality)^*^ | Med | 38.0 | 3.80 | 2.3 (-1.1 to 5.7) | 0.23 (-0.11 to 0.57) | -- | --
All ASA doses | Fatal CVD (fatal MI/coronary, fatal stroke, and CVD mortality)^*^ | High | 46.2 | 4.62 | 2.8 (-1.4 to 6.9) | 0.28 (-0.14 to 0.69) | -- | --
All ASA doses | Nonfatal stroke^*^ | Low | 12.1 | 1.21 | 0.7 (-0.7 to 1.9) | 0.07 (-0.07 to 0.19) | -- | --
All ASA doses | Nonfatal stroke^*^ | Med | 27.7 | 2.77 | 1.7 (-1.7 to 4.4) | 0.17 (-0.17 to 0.44) | -- | --
All ASA doses | Nonfatal stroke^*^ | High | 48.4 | 4.84 | 2.9 (-2.9 to 7.7) | 0.29 (-0.29 to 0.77) | -- | --
All ASA doses | Nonfatal MI/coronary^*^ | Low | 9.0 | 0.90 | 1.8 (1.1 to 2.5) | 0.18 (0.11 to 0.25) | 5,556 (4,000 to 9,091) | --
All ASA doses | Nonfatal MI/coronary^*^ | Med | 29.3 | 2.93 | 5.9 (3.5 to 8.2) | 0.59 (0.35 to 0.82) | 1,695 (1,220 to 2,857) | --
All ASA doses | Nonfatal MI/coronary^*^ | High | 84.4 | 8.44 | 16.9 (10.1 to 23.6) | 1.69 (1.01 to 2.36) | 592 (424 to 990) | --
All ASA doses | Major CVD events^*^ | Low | 25.9 | 2.59 | 2.9 (1.3 to 4.1) | 0.29 (0.13 to 0.41) | 3,448 (2,439 to 7,692) | --
All ASA doses | Major CVD events^*^ | Med | 90.8 | 9.08 | 10.0 (4.5 to 14.5) | 1.00 (0.45 to 1.45) | 1,000 (690 to 2,222) | --
All ASA doses | Major CVD events^*^ | High | 159.5 | 15.95 | 17.5 (8.0 to 25.5) | 1.75 (0.80 to 2.55) | 571 (392 to 1,250) | --
All ASA doses | Cancer incidence | Low | 56.5 | 5.65 | 1.1 (-2.3 to 4.0) | 0.11 (-0.23 to 0.40) | -- | --
All ASA doses | Cancer incidence | Med | 98.1 | 9.81 | 2.0 (-3.9 to 6.9) | 0.20 (-0.39 to 0.69) | -- | --
All ASA doses | Cancer incidence | High | 141.2 | 14.12 | 2.8 (-5.6 to 9.9) | 0.28 (-0.56 to 0.99) | -- | --
All ASA doses | Cancer mortality | Low | 12.3 | 1.23 | 0.5 (-0.7 to 1.6) | 0.05 (-0.07 to 0.16) | -- | --
All ASA doses | Cancer mortality | Median | 34.8 | 3.48 | 1.4 (-2.1 to 4.5) | 0.14 (-0.21 to 0.45) | -- | --
All ASA doses | Cancer mortality | High | 72.5 | 7.25 | 2.9 (-4.4 to 9.4) | 0.29 (-0.44 to 0.94) | -- | --
All ASA doses | Major GI bleeding | Low | 2.3 | 0.23 | -1.4 (-2.1 to -0.7) | -0.14 (-0.21 to -0.07) | -- | 7,143 (4,762 to 14,286)
All ASA doses | Major GI bleeding | Median | 4.9 | 0.49 | -2.9 (-4.4 to -1.6) | -0.29 (-0.44 to -0.16) | -- | 3,448 (2,273 to 6,250)
All ASA doses | Major GI bleeding | High | 10.4 | 1.04 | -6.1 (-9.4 to -3.3) | -0.61 (-0.94 to -0.33) | -- | 1,639 (1,064 to 3,030)
All ASA doses | Major GI bleeding | High^‡^ | 14.0^‡^ | 1.40^‡^ | -8.3 (-12.7 to -4.5) | -0.83 (-1.27 to -0.45) | -- | 1,205 (787 to 2,222)
All ASA doses | Major GI bleeding | High^‡^ | 20.0^‡^ | 2.00^‡^ | -11.8 (-18.2 to -6.4) | -1.18 (-1.82 to -0.64) | -- | 847 (549 to 1,563)
All ASA doses | ICH including hemorrhagic stroke | Low | 2.0 | 0.20 | -0.6 (-1.3 to 0.0) | -0.06 (-0.13 to 0.00) | -- | --
All ASA doses | ICH including hemorrhagic stroke | Med | 4.2 | 0.42 | -1.1 (-2.8 to 0.1) | -0.11 (-0.28 to 0.01) | -- | --
All ASA doses | ICH including hemorrhagic stroke | High | 12.5 | 1.25 | -3.4 (-8.3 to 0.3) | -0.34 (-0.83 to 0.03) | -- | --
All ASA doses | ICH including hemorrhagic stroke | High^‡^ | 17.0^‡^ | 1.70^‡^ | -4.6 (-11.2 to 0.3) | -0.46 (-1.12 to 0.03) | -- | --
ASA dose ≤ 100 mg per day | All-cause mortality^*^ | Low | 31.9 | 3.19 | 1.9 (-0.3 to 3.8) | 0.19 (-0.03 to 0.38) | -- | --
ASA dose ≤ 100 mg per day | All-cause mortality^*^ | Med | 95.5 | 9.55 | 5.7 (-1.0 to 11.5) | 0.57 (-0.10 to 1.15) | -- | --
ASA dose ≤ 100 mg per day | All-cause mortality^*^ | High | 135.4 | 13.54 | 8.1 (-1.4 to 16.3) | 0.81 (-0.14 to 1.63) | -- | --
ASA dose ≤ 100 mg per day | Fatal CVD (fatal MI/coronary, fatal stroke, and CVD mortality)^*,*^ | Low | 6.3 | 0.63 | 0.3 (-0.7 to 1.0) | 0.03 (-0.07 to 0.10) | -- | --
ASA dose ≤ 100 mg per day | Fatal CVD (fatal MI/coronary, fatal stroke, and CVD mortality)^*,*^ | Med | 38.0 | 3.80 | 1.5 (-4.2 to 6.1) | 0.15 (-0.42 to 0.61) | -- | --
ASA dose ≤ 100 mg per day | Fatal CVD (fatal MI/coronary, fatal stroke, and CVD mortality)^*,*^ | High | 46.2 | 4.62 | 1.8 (-5.1 to 7.4) | 0.18 (-0.51 to 0.74) | -- | --
ASA dose ≤ 100 mg per day | Nonfatal stroke^*^ | Low | 12.1 | 1.21 | 2.2 (0.6 to 3.5) | 0.22 (0.06 to 0.35) | 4,545 (2,857 to 16,667) | --
ASA dose ≤ 100 mg per day | Nonfatal stroke^*^ | Med | 27.7 | 2.77 | 5.0 (1.4 to 8.0) | 0.50 (0.14 to 0.80) | 2,000 (1,250 to 7,143) | --
ASA dose ≤ 100 mg per day | Nonfatal stroke^*^ | High | 48.4 | 4.84 | 8.7 (2.4 to 14.0) | 0.87 (0.24 to 1.40) | 1,149 (714 to 4,167) | --
ASA dose ≤ 100 mg per day | Nonfatal MI/coronary^*^ | Low | 9.0 | 0.90 | 1.3 (0.3 to 2.2) | 0.13 (0.03 to 0.22) | 7,692 (4,545 to 33,333) | --
ASA dose ≤ 100 mg per day | Nonfatal MI/coronary^*^ | Med | 29.3 | 2.93 | 4.4 (0.9 to 7.3) | 0.44 (0.09 to 0.73) | 2,273 (1,370 to 11,111) | --
ASA dose ≤ 100 mg per day | Nonfatal MI/coronary^*^ | High | 84.4 | 8.44 | 12.7 (2.5 to 21.1) | 1.27 (0.25 to 2.11) | 787 (474 to 4,000) | --
ASA dose ≤ 100 mg per day | Major CVD events^*^ | Low | 25.9 | 2.59 | 3.1 (1.3 to 4.7) | 0.31 (0.13 to 0.47) | 3,226 (2,128 to 7,692) | --
ASA dose ≤ 100 mg per day | Major CVD events^*^ | Med | 90.8 | 9.08 | 10.9 (4.5 to 16.3) | 1.09 (0.45 to 1.63) | 917 (613 to 2,222) | --
ASA dose ≤ 100 mg per day | Major CVD events^*^ | High | 159.5 | 15.95 | 19.1 (8.0 to 28.7) | 1.91 (0.80 to 2.87) | 524 (348 to 1,250) | --
ASA dose ≤ 100 mg per day | Cancer incidence | Low | 56.5 | 5.65 | 1.1 (-2.3 to 4.5) | 0.11 (-0.23 to 0.45) | -- | --
ASA dose ≤ 100 mg per day | Cancer incidence | Med | 98.1 | 9.81 | 2.0 (-3.9 to 7.8) | 0.20 (-0.39 to 0.78) | -- | --
ASA dose ≤ 100 mg per day | Cancer incidence | High | 141.2 | 14.12 | 2.8 (-5.6 to 11.3) | 0.28 (-0.56 to 1.13) | -- | --
ASA dose ≤ 100 mg per day | Cancer mortality | Low | 12.3 | 1.23 | 0.6 (-0.7 to 1.8) | 0.06 (-0.07 to 0.18) | -- | --
ASA dose ≤ 100 mg per day | Cancer mortality | Med | 34.8 | 3.48 | 1.7 (-2.1 to 5.2) | 0.17 (-0.21 to 0.52) | -- | --
ASA dose ≤ 100 mg per day | Cancer mortality | High | 72.5 | 7.25 | 3.6 (-4.4 to 10.9) | 0.36 (-0.44 to 1.09) | -- | --
ASA dose ≤ 100 mg per day | Major GI bleeding | Low | 2.3 | 0.23 | -1.3 (-2.2 to -0.7) | -0.13 (-0.22 to -0.07) | -- | 7,692 (4,545 to 14,286)
ASA dose ≤ 100 mg per day | Major GI bleeding | Med | 4.9 | 0.49 | -2.8 (-4.6 to -1.4) | -0.28 (-0.46 to -0.14) | -- | 3,571 (2,174 to 7,143)
ASA dose ≤ 100 mg per day | Major GI bleeding | High | 10.4 | 1.04 | -6.0 (-9.9 to -3.0) | -0.60 (-0.99 to -0.30) | -- | 1,667 (1,010 to 3,333)
ASA dose ≤ 100 mg per day | ICH including hemorrhagic stroke | Low | 2.0 | 0.20 | -0.4 (-1.2 to 0.2) | -0.04 (-0.12 to 0.02) | -- | --
ASA dose ≤ 100 mg per day | ICH including hemorrhagic stroke | Med | 4.2 | 0.42 | -0.8 (-2.6 to 0.5) | -0.08 (-0.26 to 0.05) | -- | --
ASA dose ≤ 100 mg per day | ICH including hemorrhagic stroke | High | 12.5 | 1.25 | -2.4 (-7.6 to 1.5) | -0.24 (-0.76 to 0.15) | -- | --

* Data from companion systematic review on CVD primary prevention41

† Only outcomes with statistically significant results had NNT calculated

‡ Minimum, maximum, and median control group rate for each outcome, excluding zeros and outliers, from the set of CVD primary prevention trials

Abbreviations: ARR = absolute risk reduction; ASA = acetylsalicylic acid; CI = confidence interval; CVD = cardiovascular disease; GI = gastrointestinal; ICH = intracranial hemorrhage; mg – milligram(S); MI = myocardial infarction; NNT-B = number need to treat to benefit; NNT-H = number need to treat to harm; p-y = person-years

All-cause mortality results were available for 17 additional fair- or good-quality RCTs.53,54,58,59,62, 63,65,68,71,74-81 One of these, the Copenhagen Atrial Fibrillation, Aspirin, and Anticoagulation study, reported no significant difference in mortality between groups, but did not report the actual number of deaths per group.80 The ongoing Aspirin in Reducing Events in Elder (ASPREE) study reported that no deaths occurred in either group during its initial year.53 Neither of these two trials could be used in our meta-analysis. The remaining 15 trials included 22,826 randomized participants and 2,165 deaths. Average doses ranged from 50 to 1,200 mg ASA per day and average intended duration ranged from 1 to 4 years. Frequency of dosing was at least once per day for all additional trials.

When these additional trials were pooled with the 10 main CVD primary prevention trials (k=25 RCTs; n=126,613; 6,568 deaths), the relative reduction in risk of mortality for participants allocated to ASA compared to no ASA was similar to when analyses were restricted to the 10 CVD primary prevention trials, but slightly more precise (RR, 0.93 [95% CI, 0.89 to 0.98]) (Figure 5). Among the 13 trials of very low-dose ASA (≤100 mg/day), the results were similar (RR, 0.93 [95% CI, 0.87 to 0.99]). Results also remained similar in magnitude and statistically significantly different between ASA and no ASA groups in our other sensitivity analyses except when restricting to trials of every other day dosing or when substituting longer-term mortality effects at 17.5 years from WHS (Table 9).

Figure 5 Forest Plot of All-Cause Mortality, All Included Trials

* Trials included two separate ASA arms which were combined for analysis

Note: PHS and WHS are alternate day dosage studies (100 mg qod and 325 mg qod, respectively)

Abbreviations: ABI = ankle-brachial index; AF = atrial fibrillation; ASA = acetylsalicylic acid; CI = confidence interval; CVD = cardiovascular disease; DVT = deep vein thrombosis; IHD = ischemic heart disease; MI = myocardial infarction; RR = relative risk; PE = pulmonary emboli; TIA = transient ischemic attack; w/ = with

This figure is a forest plot of the relative risk of all-cause mortality among all included trials.

In an IPD meta-analysis conducted by the Antithrombotic Trialists (ATT) Collaboration, all-cause mortality was not significantly affected in six trials of CVD primary prevention (RR, 0.95 [95% CI, 0.88 to 1.02]), but was reduced in secondary prevention trials (RR, 0.90 [95% CI, 0.82 to 0.99]) through an effect on vascular mortality, but not other mortality.87

All-cause mortality was not examined in any analysis of the set of 51 trials of any dose of daily ASA for primary or secondary CVD prevention assembled by Rothwell and colleagues (2012).10 An analysis of 12 trials of mostly primary prevention using any dose of daily ASA (nine trials of ≤100 mg per day; three trials of 325, 500, or 1,000 mg daily) suggested 96 fewer deaths within those allocated to ASA over 1.3 to 8.2 years of ASA use. This result is primarily due to decreased nonvascular deaths (87 fewer deaths; OR, 0.88 [95% CI, 0.78 to 0.98]), as opposed to vascular deaths (9 fewer deaths; OR, 0.99 [95% CI, 0.87 to 1.12]). The majority of all deaths (n=2,426) were nonvascular (55%). Ascertainment methods were described and may have been different across studies (i.e., some but not all studies were updated based on data from a previous IPD meta-analysis by the ATT Collaboration87 or using data provided by the study's authors). While this might have underestimated death rates, it would not clearly introduce any bias in determining cause of death (vascular vs. nonvascular). While relevant, these data may not be directly applicable to low-dose ASA use in a CVD primary prevention population.

## KQ 2 Does Regular Aspirin Use Reduce the Incidence of Cancers in Adults Taking (or Eligible for) Aspirin for Primary Prevention?

### Cancer Incidence

All cancer incidence outcomes were available from 12 fair- to good-quality RCTs54,57,58,60-62, 66-68,72, 75,77 (Appendix E Table 6). Only one trial (WHS) reported on incidence of specific cancers (14 sites separately or five grouped types), and this was among the 89 percent of survivors who opted for longer followup after a median of 10.1 years of very low-dose ASA (100 mg) every other day.88 Cancer incidence, overall and by time to diagnosis, was reported by type (combining fatal and nonfatal cancers) in a separate IPD meta-analysis by Rothwell and colleagues (2012) of 32 trials of any dose of daily ASA.10

Six of the 10 CVD primary prevention trials had outcomes available for cancer incidence (n=72,926; 4,294 incident cancers) during the 3.8 to 10.1 years of average intended intervention.57,60,61,66,67,72 All trials tested very low-dose ASA (≤100 mg) interventions except one that tested 500 mg ASA per day.72 WHS evaluated every other day dosing,60 whereas the other five trials evaluated daily dosing. Cancer occurred among 2,155 of 37,301 participants allocated to ASA groups and 2,139 of 35,625 participants allocated to no ASA control groups. Overall, the risk of cancer was 2 percent lower among those allocated to ASA compared to no ASA, with no statistically significant difference between groups (RR, 0.98 [95% CI, 0.93 to 1.04]) (Figure 6).

Figure 6 Forest Plot of Cancer Incidence, CVD Primary Prevention Trials

Note: PHS and WHS are alternate day dosage studies (100 mg qod and 325 mg qod, respectively)

Abbreviations: ABI = ankle-brachial index; ASA = acetylsalicylic acid; CI = confidence interval; CVD = cardiovascular disease; RR = relative risk; w/ = with

This figure is a forest plot of the relative risk of cancer incidence among CVD primary prevention trials.

Heterogeneity across trials was minimal (I^2^=1.5%; p=0.406). For a population with a baseline annual risk of cancer corresponding to the median control group rate in these trials (9.81 cancers per 1,000 person-years), about 0.2 fewer cancers per 1,000 person-years would be expected with ASA use, but 95% CI for the absolute change in risk ranged from a reduction of 0.69 cases per 1,000 person-years to an increase of 0.39 cases per 1,000 person-years for those allocated to ASA compared to no ASA (Table 10). None of the sensitivity analyses of the end-of-trial data from CVD primary prevention trials resulted in a statistically significant impact of ASA use on cancer (Table 9).

In the one CVD primary prevention trial with posttrial followup (WHS), overall cancer incidence (5,071 cases, excluding nonmelanoma skin cancers) was not reduced among ASA users in age-adjusted analyses (HR, 0.97 [95% CI, 0.92 to 1.03]) after a median of 17.5 years followup, whether data were cumulative or considered within-trial or posttrial periods separately.88 Most cancers were breast cancers (2,070), followed by CRC (451) and lung cancers (431). Of these most common cancers, only CRC incidence was reduced (cumulative HR, 0.80 [95% CI, 0.67 to 0.97]), with a delay of effect beginning only in the posttrial period (i.e., >10 years). For the only other cancer with at least 400 cases—uterine cancer (455 cases)—ASA use was not associated with reduced incidence (HR, 1.00 [95% CI, 0.83 to 1.20]). Other cancer types were relatively uncommon and the lack of significant findings may be due to lack of statistical power. Even when grouped by type, only GI cancer incidence was reduced in the posttrial followup period, while incidence of urinary tract, respiratory tract, reproductive tract, and hematologic cancers was unaffected.

We identified six additional CVD secondary prevention or colorectal adenoma prevention trials for which data on cancer incidence were available (Figure 7) during average intended interventions that ranged from 2 to 4 years.54,58,62,68,75,77 These trials contributed a total of 12,639 additional participants and 263 cancer cases. Five trials evaluated low-dose ASA interventions (≤325 mg/day),54,58,62,68,77 of which four had a very low-dose ASA arm (≤100 mg/day),54,58,62,77 and one trial (Aspirin Myocardial Infarction Study) evaluated 1,000 mg ASA total per day.75 ASA was prescribed as either daily or more frequent dosing (split into two doses per day in two trials).62,75 A meta-analysis of all 12 trials showed results similar to those among the CVD primary prevention trials alone and remained nonstatistically significant and imprecise (Table 9). In sensitivity analyses, the greatest reduction in risk of cancer incidence was seen when restricting to trials of daily or more frequent dosing and at least 4 years of intended duration of treatment (k=4; n=11,800; 671 cancer cases) (Table 9). In this subanalysis, the risk of cancer among patients allocated to ASA was 14 percent lower than among those allocated to no ASA and the difference was marginally statistically significant.

Figure 7 Forest Plot of Cancer Incidence, All Included Trials

* Trials included two separate ASA arms which were combined for analysis

Note: PHS and WHS are alternate day dosage studies (100 mg qod and 325 mg qod, respectively)

Abbreviations: ABI = ankle-brachial index; ASA = acetylsalicylic acid; CI = confidence interval; CVD = cardiovascular disease; DVT = deep vein thrombosis; MI = myocardial infarction; RR = relative risk; PE = pulmonary emboli; TIA = transient ischemic attack; w/ = with

This figure is a forest plot of the relative risk of cancer incidence among all included trials.

In time-to-event IPD meta-analysis by Rothwell and colleagues (2012) of 32 trials of any dose of daily ASA, overall cancer risk (combining fatal and nonfatal cancers) was reduced only after greater than 3 years of followup (OR, 0.79 [95% CI, 0.70 to 0.90]), and then only for grouped reproductive cancers (OR, 0.54 [95% CI, 0.36 to 0.82]). All site-specific cancers, however, were relatively rare (<1,000 cancer cases of all types with >3 years followup) and, as such, there was insufficient power for smaller effects.10

## KQs 1a and 2a Does the Effect of Aspirin Vary by a Priori Subgroups: Age, Sex, Race/Ethnicity, Baseline Cancer Risk, and Comorbidities?

Overall, few trials assessed for variability in the effect of ASA on cancer mortality, all-cause mortality, or cancer incidence by our a priori subgroups. Among trials that completed these assessments, risk of these outcomes was not statistically significantly different between ASA and no ASA groups within any of the subgroups examined. In addition, only one trial (WHS)60 reported results of testing between subgroups for statistical interactions, as is recommended.89,90 Several individual included trials restricted enrollment to one subgroup based on sex, nationality, history of colon adenoma, or diabetes mellitus diagnosis; however, these trials also differed in terms of other important potentially confounding study- and patient-level characteristics, making indirect comparisons of results across trials difficult to interpret. Additional data relevant to variation in effect by age and sex subgroups (cancer incidence only) were available from an IPD meta-analysis that pooled outcomes from the six CVD primary prevention trials (n=35,535) that tested daily ASA interventions at doses less than 300 mg per day only.10 Tables showing data relevant to a priori selected subgroups are presented in Appendix F.

### Cancer Mortality and All-Cause Mortality

Cancer mortality outcomes for ASA and no ASA groups were reported separately by sex subgroups for one trial (Appendix F Table 1).65 In this trial, the RR of cancer mortality was nonstatistically significantly lower for participants in ASA groups compared to no ASA groups, for both men and women. Results of statistical testing are not reported for either sex. For all-cause mortality, outcomes were reported separately by sex in four trials,64,65,67,75 by age group in two trials,65,75 and by presence or absence of diabetes diagnosis in one trial (Appendix F Table 2).61 No statistically significant differences in risk of all-cause mortality between ASA and no ASA groups were reported within any of the subgroups examined in any of the trials. Trends for the RR of all-cause mortality for ASA compared to no ASA groups were different between men and women in two trials65,67 (nonstatistically significant risk reduction with ASA for men and nonstatistically significant risk increase for women). Results were different between patients with and without diabetes in one trial61 (nonstatistically significant risk reduction in all-cause mortality with ASA for patients without diabetes and nonstatistically significant risk increase for patients with diabetes); however, results by age or sex were too sparse and mixed for any overall conclusions. Testing for statistical interactions was not reported. Available evidence was insufficient to determine if effects of ASA compared to no ASA on all-cause mortality vary between men and women or patients with and without diabetes.

### Cancer Incidence

For cancer incidence, stratified analyses for subgroups based on age and family history of cancer were available from WHS, the largest single included trial, which enrolled nearly 40,000 women (Appendix F Table 3).60 Cancer incidence was not statistically significantly different between ASA and no ASA groups within any subgroup. Results of testing for statistical interactions were nonsignificant (p>0.30 for both age and family history of cancer). Results were also available for cancer incidence in age and sex subgroups from an IPD meta-analysis by Rothwell and colleagues (2012) of six trials of ASA doses of less than 300 mg for CVD primary prevention.10 Cancer occurring at 3 years or later after randomization was reduced by about 20 to 30 percent among ASA compared to no ASA groups within each age and sex subgroup. These results overall indicate that the effect of ASA compared to no ASA on cancer incidence was not different for subgroups based on age, sex, or family history of cancer.

## KQs 1b and 2b Does the Effect of Aspirin Vary by Delivery of Intervention (e.g., Dose, Frequency, Duration, Formulation, and Recency of Use)?

Results relevant to variation of the effect of ASA on cancer mortality, all-cause mortality, and cancer incidence were available from our sensitivity analyses (relevant to dose, frequency, and duration) (Table 9) and also from two IPD meta-analyses by Rothwell and colleagues (relevant to duration).8,10 The IPD meta-analyses were restricted to daily dose interventions and therefore could not evaluate potential variation in effect of ASA with dose frequency (i.e., daily vs. every other day). Data were limited to address type-specific cancer effects and insufficient to address variation in effect related to ASA formulation or recency of use.

### Dose

In our sensitivity analyses, restricting to trials of low- (≤325 mg/day) or very low-dose (≤100 mg/day) ASA did not impact our estimates of the RR of cancer mortality, all-cause mortality, or cancer incidence except for slightly reducing the precision of the estimates (Table 9). For all-cause mortality, the statistically significant 6 to 7 percent reduction in risk among ASA compared to no ASA groups (when including trials of all doses) was no longer statistically significant among the CVD primary prevention trials when restricting to low- (≤325 mg/day) or very low-dose (≤100 mg/day) ASA only. This result remained similar in magnitude to the estimate that included all trials, suggesting reduced power rather than differences in effect by dosage. Exploratory analyses by Rothwell and colleagues (2011) suggested no difference in low-(75 mg) versus higher-dose (≥300 mg) ASA on reduced risk of adenocarcinoma deaths, but these results could be confounded and need confirmation.

### Duration

Results of the two IPD meta-analyses by Rothwell and colleagues (2011 and 2012) indicate that the effects of daily ASA on cancer mortality and cancer incidence vary based on the duration of ASA treatment.8,10 Data for time from randomization to cancer death during the trials were available for participants in 32 of 51 primary or secondary CVD prevention trials testing daily ASA compared to no ASA for 90 days or greater (n=65,973 patients; 85% of patients in all 51 trials). The risk of cancer death from 0 to 2.9 years and 3 to 4.9 years after randomization was not different between groups. The risk of cancer death occurring at 5 years or later after randomization, however, was 37 percent lower for patients allocated to ASA compared to no ASA (OR, 0.63 [95% CI, 0.49 to 0.82]).10 A separate analysis by Rothwell and colleagues (2011) of seven primary or secondary CVD prevention trials with at least 4 years of mean or median scheduled treatment found the same pattern.8 Results of testing for statistical interactions between ASA and duration of treatment were not reported for either of these two analyses. In posttrial followup of three trials, longer treatment duration was significantly related to decreased 20-year risk of nonhematological cancers (p=0.01 for interaction), with no benefit for less than 5 years intended use and greatest benefit for 7.5 years or greater. Exploratory analyses suggested minimal treatment duration (≥5 to 10 years) and latency to mortality reduction (5 to 20 years) may vary for specific cancers, but studies were too methodologically and clinically heterogeneous for strong conclusions. Analyses on variation in the effect of ASA on all-cause mortality with duration of treatment were not reported.

Rothwell and colleagues (2012) examined time from randomization to cancer incidence during trial followup among participants in the six CVD primary prevention trials of daily ASA of less than 300 mg per day versus no ASA (n=35,535).10 Risk of cancer incidence was similar between groups during the first 3 years after randomization, but was 19 percent lower among patients allocated to ASA versus no ASA at 3 to 4.9 years and 29 percent reduced at 5 years or greater (0 to 2.9 years: HR, 1.00 [95% CI, 0.88 to 1.15]; 3 to 4.9 years: HR, 0.81 [95% CI, 0.67 to 0.98]; ≥5 years: HR, 0.71 [95% CI, 0.57 to 0.89]). Testing for interaction between ASA and duration of followup beyond 3 years was significant (p=0.04). For one of the five trials,70 data on cancer mortality were substituted for cancer incidence.

In our sensitivity analyses, outcomes between ASA and no ASA groups remained similar to main findings for cancer mortality, all-cause mortality, and cancer incidence when analyses were restricted to trials of 4 years or greater average duration (Table 9). We do not have data on the length of time after randomization to these outcomes, however, so cannot distinguish between events that occurred after shorter versus longer periods of intervention.

### Frequency

In our sensitivity analyses restricting to trials of daily-dose ASA, the magnitude of RR reduction in cancer mortality and cancer incidence for ASA compared to no ASA groups tended to be greater than in our main analyses that included all trials (two with every other day dosing), but neither approaches yielded a statistically significant difference between treatment groups (Table 9). When restricting to trials of daily dose ASA in which the average intended duration was 4 years or greater and also including secondary CVD prevention or colon adenoma populations, the relative reduction in cancer mortality and cancer incidence became statistically significant for ASA groups compared to no ASA groups (cancer mortality: RR, 0.83 [95% CI, 0.70 to 0.98]; cancer incidence: RR, 0.86 [95% CI, 0.74 to 0.99]); these findings, however, were not statistically significant when limited to CVD primary prevention trials. For all-cause mortality, findings among trials of daily dose ASA were similar in magnitude to main results and remained statistically significant, regardless of duration considerations.

## KQ 6 What Are the Serious Harms of Regular Aspirin Use for the Primary Prevention of Cancer (i.e., at the Dosage and Duration Required to Achieve a Preventive Health Effect) in Adults Appropriate for Aspirin Chemoprevention?

We identified 30 RCTs that reported on associated harms with ASA use in populations seeking benefits for primary and secondary CVD prevention or for CRC/adenoma prevention (Table 6; Appendix E Tables 1–3). Thirteen were in CVD primary prevention populations (including the 10 from the other ASA review on the topic),41 14 were in CVD secondary prevention populations, and three were in CRC/adenoma prevention populations. Dosages ranged from 50 to 1,200 mg per day on average, with a duration of use from 1 to 10.1 years. Given the overall findings on CVD,41 all-cause mortality, and cancer incidence and mortality, the most applicable evidence on harms represents lower-dose ASA use (<325 mg per day or every other day) up through about 10 years.

In addition, we identified four recent fair- or good-quality cohort studies reporting on bleeding risks in individuals with and without low-dose ASA use (Table 7; Appendix E Tables 1–3).83-86 Three cohort studies included a presumed mixture of primary and secondary CVD prevention populations,83-85 while the fourth was limited to patients with diabetes and no prior CVD;86 this study was quite limited in the types of bleeding outcomes reported. Dosages ranged from 75 to 300 mg per day and duration of followup from 3.9 to 11.4 years. We limited cohort data to those examining lower-dose ASA use (≤325 mg) or those reporting data separately among lower-dose users, with no active cotreatments. Limited specificity about ASA exposure (e.g., providing average weekly intake in categories of tablet sizes) prevented us from using two cohort studies for estimating absolute rates of harms with low-dose ASA,83,84 although these cohort studies were useful in examining effect modification.

We also included the most recent IPD meta-analysis by Rothwell and colleagues (2012)10 and the ATT Collaboration87 and recent study-level meta-analysis by Seshasai and colleagues focused on trials;44 each of these reported harms in ways that complement our findings from primary studies.

### Major GI Bleeding

Among the 10 CVD primary prevention trials, seven reported major GI bleeding events (defined as any GI bleeding requiring transfusion, requiring hospitalization, leading to death, or defined as major by the study investigators) with ASA use (Figure 8; Appendix E Table 7).60,66,67,69,70,72,73 Dosages ranged from 50 to 162.5 mg per day in all but one trial (500 mg per day).72 Duration of use and followup ranged from 4 to 10.1 years. Among ASA users, major GI bleeding risk was increased (Peto OR, 1.59 [95% CI, 1.32 to 1.91]), with low heterogeneity in the pooled result (I^2^=22.2%). Absolute bleeding would be increased by 0.29 events per 1,000 person-years of exposure to ASA intervention for a population with a baseline risk similar to the median level among our included trials (Table 10). Sensitivity analyses (Table 11) excluding the two trials with dosages above 100 mg essentially did not change the pooled estimate. When we pooled all primary and secondary prevention trials with major GI bleeding outcomes (k=15) (Figure 9), absolute bleeding risks were somewhat higher, with no heterogeneity (Peto OR, 1.63 [95% CI, 1.37 to 1.95]; I^2^=0%). In sensitivity analyses (Table 11) that excluded six studies63,65,72,73,75,79 with dosages above 100 mg, bleeding estimates for all trials were reduced to those in the CVD primary prevention studies. Although pooled results for all 15 trials, when stratified by primary versus secondary CVD prevention, suggested somewhat higher bleeding risks in secondary prevention trials, there was no statistically significant interaction by prevention type, and the two groups of trials varied in dosage and time frame for ASA administration (data not shown).

Figure 8 Forest Plot of Major GI Bleeding, CVD Primary Prevention Trials

Note: PHS and WHS are alternate day dosage studies (100 mg qod and 325 mg qod, respectively)

Abbreviations: ABI = ankle-brachial index; ASA = acetylsalicylic acid; CI = confidence interval; IHD = ischemic heart disease; OR = odds ratio; w/ = with

This figure is a forest plot of the odds ratio of major GI bleeding among CVD primary prevention trials.

Table 11 Sensitivity Analyses by Dosage and Frequency of Major GI and Intracranial Bleeding, Including Hemorrhagic Stroke

Outcome | Trials | Sensitivity Analysis | k | ASA (number of cases / number of participants) | No ASA (number of cases / number of participants) | Pooled OR (95% CI) | Names of Trials
Major GI bleeding | CVD Primary Prevention Trials | All trials | 7 | 277/48,005 | 172/46,302 | 1.59 (1.32, 1.91) | HOT, JPAD, PHS, BMD, TPT, AAA, WHS
Major GI bleeding | CVD Primary Prevention Trials | Dose ≤ 325 mg per day | 6 | 274/44,576 | 169/44,592 | 1.61 (1.34, 1.94) | HOT, JPAD, PHS, TPT, AAA, WHS
Major GI bleeding | CVD Primary Prevention Trials | Dose ≤ 100 mg per day | 5 | 225/33,539 | 141/33,558 | 1.58 (1.29, 1.95) | HOT, JPAD, TPT, AAA, WHS
Major GI bleeding | CVD Primary Prevention Trials | Daily dose | 5 | 99/17,034 | 50/15,326 | 1.91 (1.37, 2.67) | HOT, JPAD, BMD, TPT, AAA
Major GI bleeding | CVD Primary Prevention Trials | Every other day dose | 2 | 178/30,971 | 122/30,976 | 1.46 (1.16, 1.84) | PHS, WHS
Major GI bleeding | All Included Trials | All trials | 15 | 319/54,306 | 190/52,219 | 1.63 (1.37, 1.95) | Silagy, EAFT, ACBS, SALT, AFPPS, AMIS, HOT, UK-TIA, SAPAT, JPAD, PHS, BMD, TPT, AAA, WHS
Major GI bleeding | All Included Trials | Dose ≤ 325 mg per day | 13 | 315/48,609 | 187/48,251 | 1.65 (1.39, 1.97) | Silagy, EAFT, ACBS, SALT, AFPPS, HOT, UK-TIA, SAPAT, JPAD, PHS, TPT, AAA, WHS
Major GI bleeding | All Included Trials | Dose ≤ 100 mg per day | 9 | 249/35,802 | 155/35,841 | 1.60 (1.31, 1.94) | Silagy, SALT, AFPPS, HOT, SAPAT, JPAD, TPT, AAA, WHS
Major GI bleeding | All Included Trials | Daily dose | 13 | 141/23,335 | 68/21,243 | 1.97 (1.48, 2.62) | Silagy, EAFT, ACBS, SALT, AFPPS, AMIS, HOT, UK-TIA, SAPAT, JPAD, BMD, TPT, AAA
Major GI bleeding | All Included Trials | Every other day dose | 2 | 178/30,971 | 122/30,976 | 1.46 (1.16, 1.84) | PHS, WHS
Intracranial bleeding including hemorrhagic stroke | CVD Primary Prevention Trials | All trials | 9 | 129/50,868 | 96/49,208 | 1.27 (0.98, 1.66) | PPP, TPT, HOT, JPAD, PHS, BMD, POPADAD, AAA, WHS
Intracranial bleeding including hemorrhagic stroke | CVD Primary Prevention Trials | Dose ≤ 325 mg per day | 8 | 116/47,439 | 90/47,498 | 1.29 (0.98, 1.70) | PPP, TPT, HOT, JPAD, PHS, POPADAD, AAA, WHS
Intracranial bleeding including hemorrhagic stroke | CVD Primary Prevention Trials | Dose ≤ 100 mg per day | 7 | 93/36,402 | 78/36,464 | 1.19 (0.88, 1.61) | PPP, TPT, HOT, JPAD, POPADAD, AAA, WHS
Intracranial bleeding including hemorrhagic stroke | CVD Primary Prevention Trials | Daily dose | 7 | 55/19,897 | 43/18,232 | 1.13 (0.76, 1.69) | PPP, TPT, HOT, JPAD, BMD, POPADAD, AAA
Intracranial bleeding including hemorrhagic stroke | CVD Primary Prevention Trials | Every other day dose | 2 | 74/30,971 | 53/30,976 | 1.39 (0.98, 1.97) | PHS, WHS
Intracranial bleeding including hemorrhagic stroke | All Included Trials | All trials | 19 | 165/56,491 | 110/54,487 | 1.43 (1.12, 1.81) | SPAF, Copenhagen AFASAK, JAST, EAFT, ACBS, SALT, AFPPS, ukCAP, PPP, HOT, TPT, UK-TIA, SAPAT, JPAD, PHS, BMD, POPADAD, AAA, WHS
Intracranial bleeding including hemorrhagic stroke | All Included Trials | Dose ≤ 325 mg per day | 18 | 152/53,062 | 104/52,777 | 1.45 (1.14, 1.86) | SPAF, Copenhagen AFASAK, JAST, EAFT, ACBS, SALT, AFPPS, ukCAP, PPP, HOT, TPT, UK-TIA, SAPAT, JPAD, PHS, POPADAD, AAA, WHS
Intracranial bleeding including hemorrhagic stroke | All Included Trials | Dose ≤ 100 mg per day | 11 | 112/38,802 | 85/38,884 | 1.32 (1.00, 1.75) | Copenhagen AFASAK, SALT, AFPPS, PPP, HOT, TPT, SAPAT, JPAD, POPADAD, AAA, WHS
Intracranial bleeding including hemorrhagic stroke | All Included Trials | Daily dose | 17 | 91/25,520 | 57/23,511 | 1.46 (1.05, 2.01) | SPAF, Copenhagen AFASAK, JAST, EAFT, ACBS, SALT, AFPPS, ukCAP, PPP, HOT, TPT, UK-TIA, SAPAT, JPAD, BMD, POPADAD, AAA
Intracranial bleeding including hemorrhagic stroke | All Included Trials | Every other day dose | 2 | 74/30,971 | 53/30,976 | 1.39 (0.98, 1.97) | PHS, WHS

Abbreviations: ASA = acetylsalicylic acid; CI = confidence interval; CVD = cardiovascular disease; mg = milligram(s); RR = relative risk

Figure 9 Forest Plot of Major GI Bleeding, All Included Trials

* Trial included two separate ASA arms which were combined for analysis

Note: PHS and WHS are alternate day dosage studies (100 mg qod and 325 mg qod, respectively)

Abbreviations: ABI = ankle-brachial index; ASA = acetylsalicylic acid; CI = confidence interval; MI = myocardial infarction; OR = odds ratio; TIA = transient ischemic attack; w/ = with

This figure is a forest plot of the odds ratio of major GI bleeding among all included trials.

An IPD meta-analysis conducted by the ATT Collaboration87 of six primary prevention trials60,61, 67,69,72,73 reported major extracranial bleeding defined as mainly GI and usually requiring transfusion or resulting in death. Five of six trials were also represented in our major study-level GI bleeding meta-analysis reported above. We excluded the one trial included by the ATT Collaboration87 because it did not report outcomes compatible with our definition;61 we were able to include two additional trials due to a later publication date.66,70 The rate of major extracranial bleeding reported for the control group in each trial in the IPD meta-analysis of six primary prevention trials ranged from 0.04 to 0.18 percent per year (0.4 to 1.8 events per 1,000 person-years). There were a total of 554 major extracranial bleeding events in all six studies over 3.7 to 10.1 years of followup. Overall, ASA use increased major extracranial bleeding from 0.07 to 0.10 percent per year (rate ratio, 1.54 [95% CI, 1.30 to 1.82]). This difference translated to an average of 0.3 more major extracranial bleeding events per 1,000 persons taking ASA for 1 year. We approximated person-years of followup for the larger range of CVD primary prevention trials available for our review. Our method yielded similar estimates, tending to be lower if different from the IPD meta-analysis by the ATT Collaboration87 (Table 14). As an example, in the two studies with at least 100 total major bleeding events (WHS and HOT) included in both approaches, our approximate estimates were quite similar to those from the IPD meta-analysis (i.e., we calculated 0.47 vs. 0.5 per 1,000 person-years for WHS and the IPD meta-analysis, respectively; we calculated 1.04 vs. 1.8 per 1,000 person-years for HOT and the IPD meta-analysis, respectively). With either method, baseline major extracranial bleeding rates between CVD primary prevention populations varied widely—by four- to five-fold.

Table 14 Absolute Bleeding Rates Among NonASA Control Groups, Overall and by Subpopulation, From Trials and Cohort Studies

Baseline Characteristic | Major GI/Extracranial Bleeding^‡^ from ATT Collaboration, 2009^87^; events per 1,000 person-years | Intracranial Bleeding/Hemorrhagic Stroke from ATT Collaboration, 2009^87^; events per 1,000 person-years | Hospitalizations for Major Bleeding Event^§^ from cohort studies (de Berardis85); events per 1,000 person-years (95% CI)
All control group participants | 0.7 | 0.3 | 3.60 (3.48 to 3.72) Major extracranial bleeding (approx..): 2.40 Major intracranial bleeding (approx.): 1.20
Age subgroups | < 65 years: 0.5 65+ years: 1.7 | -- | < 50 years: 0.61 (0.41 to 0.91) 50-59 years: 1.40 (1.24 to 1.58) 60-69 years: 2.58 (2.40 to 2.77) 70-79 years: 4.61 (4.39 to 4.85) 80+ years: 6.93 (6.51 to 7.38)
Sex subgroups | Male: 1.0 Female: 0.5 | -- | Male: 4.50 (4.3 to 4.70) Female: 2.86 (2.72 to 3.01)

‡ Resulting in hospitalization, transfusion or death

§ Combined GI bleeding and intracranial hemorrhage/hemorrhagic stroke

Abbreviations: ATT = Antithrombotic Trialists; CI = confidence interval; GI = gastrointestinal

Major extracranial bleeding events tended to be higher in secondary prevention studies, although relatively few CVD secondary prevention trials (five of 16) reported major bleeding events, with imprecise results (rate ratio, 2.69 [95% CI, 1.25 to 5.76]) and similar potential for confounding, as noted for our stratified meta-analyses.

A subsequent IPD meta-analysis by Rothwell and colleagues (2012)10 of six primary prevention trials57,61,66,67,69,70 of daily low-dose ASA (75 to 100 mg per day) shared just three trials with the previous IPD meta-analysis and four with our analysis due to its focus on very low-dose daily ASA use only. First events of major extracranial bleeding events, as previously defined, were found to differ significantly by time to followup (2.9 years or earlier vs. 3.0 years or later; p=0.006), with increased odds of bleeding confined to the earlier time period only (OR, 1.95 [95% CI, 1.47 to 2.59]). The average followup, however, was less than 5 years in three of the trials (3.6, 3.8, and 4.4 years for PPP, HOT, and JPAD, respectively), which made ascertainment unequal between the two time periods.

De Berardis and colleagues examined hospitalizations for major bleeding events (including hospitalizations for intracranial as well as extracranial bleeding) in a population of 372,850 community-dwelling individuals in Italy (186,425 new users of ASA [≤300 mg] ages 30 to 95 years, matched using propensity scoring to 186,425 never-users). Bleeding rates reflected 1.6 million person-years of observations and a median followup of 5.7 years (interquartile range, 2.4 to 6.0 years).85 Among never-users of ASA, there were on average 3.60 major bleeding events per 1,000 person-years (95% CI, 3.48 to 3.72). However, unadjusted baseline major bleeding event rates among never-users of ASA varied from a low of 0.61 per 1,000 person-years in those younger than age 50 years to a high of 12.00 per 1,000 person-years in those with previous hospitalization for GI problems. To be considered a current user, studies required an ASA prescription within 2.5 months of bleeding events, and former users were excluded from analyses. The never-user group and current-user group differed at baseline on a number of sociodemographic characteristics, but major bleeding event rates differed only slightly over 6 years (1.8% vs. 1.9%, respectively). There were 6,907 first hospitalizations for major bleeding events, of which about two thirds (4,487) were GI bleeding, one third (2,464) were intracranial hemorrhages, and a few (44) included both sites. Incidence rates for hospitalizations for major bleeding events were 5.58 (95% CI, 5.39 to 5.77) per 1,000 person-years in ASA users compared to 3.60 (95% CI, 3.48 to 3.72) in nonusers. Incidence rate ratios (IRRs) increased with ASA use (IRR, 1.55 [95% CI, 1.48 to 1.63]) overall, with no difference in effect size by bleeding site (i.e., GI vs. intracranial).

Ekstrom and colleagues examined “ventricular hemorrhage” (International Statistical Classification of Diseases and Related Health Problems [ICD], 10th revision codes K92.0-92.2 corresponding to hematemesis, melena, GI hemorrhage, unspecified) in 18,646 patients with diabetes in Sweden (4,608 with continuous low-dose ASA use and 14,038 without ASA treatment) for a mean followup of 3.9 years.86 There were no statistically significant increases in risk of fatal and nonfatal ventricular hemorrhage among those taking ASA (adjusted HR, 1.27 [95% CI, 0.77 to 2.09]); ICD codes examined did not include all types of GI hemorrhage, such as those associated with ulcers.

### Intracranial Bleeding, Including Hemorrhagic Stroke

Nine of the 10 CVD primary prevention trials reported rates of intracranial bleeding, including hemorrhagic strokes (Figure 10; Appendix E Table 8). Across all studies, absolute rates tended to be higher among those taking ASA (129 events per 50,868 individuals) compared to those not taking ASA (96 events per 49,208 individuals), although with relatively minimal differences (0.1 additional intracranial bleeding events per 1,000 persons taking ASA for about 1 year). The risk was increased 27 percent, not a statistically different result, with no heterogeneity (Peto OR, 1.27 [95% CI, 0.98 to 1.66]; I^2^=0.0%). In sensitivity analyses restricting to trials with 100 mg of ASA or less (Table 11), bleeding risk with ASA tended to decrease (Peto OR, 1.19 [95% CI, 0.88 to 1.61]). When secondary CVD and other prevention trials were combined with CVD primary prevention trials of any dosage (Figure 11), however, the OR of intracranial bleeding was significantly increased (OR, 1.43 [95% CI, 1.12 to 1.81]), with no heterogeneity. Absolute differences would be 0.18 additional bleeding events per 1,000 persons taking ASA for 1 year. When combined studies were limited to 100 mg or less (Table 11), the risk tended to decrease (Peto OR, 1.32 [95% CI, 1.00 to 1.75]).

Figure 10 Forest Plot of Intracranial Bleeding, Including Hemorrhagic Stroke, CVD Primary Prevention Trials

Note: PHS and WHS are alternate day dosage studies (100 mg qod and 325 mg qod, respectively)

Abbreviations: ABI = ankle-brachial index; ASA = acetylsalicylic acid; CI = confidence interval; CVD = cardiovascular disease; IHD = ischemic heart disease; OR = odds ratio; w/ = with

This figure is a forest plot of the odds ratio of intracranial bleeding among CVD primary prevention trials.

Figure 11 Forest Plot of Intracranial Bleeding, Including Hemorrhagic Stroke, All Included Trials

* Trial included two separate ASA arms which were combined for analysis

Note: PHS and WHS are alternate day dosage studies (100 mg qod and 325 mg qod, respectively)

Abbreviations: ABI = ankle-brachial index; AF = atrial fibrillation; ASA = acetylsalicylic acid; CI = confidence interval; CVD = cardiovascular disease; IHD = ischemic heart disease; MI = myocardial infarction; OR = odds ratio; TIA = transient ischemic attack; w/ = with

This figure is a forest plot of the odds ratio of intracranial bleeding among all included trials.

In the large Italian cohort study described above, IRRs for intracranial hemorrhage increased with ASA use (IRR, 1.54 [95% CI, 1.43 to 1.67]), which is very similar to the IRR for major bleeding events overall or for GI bleeding.85 About one third of first episodes of hospitalization for major bleeding events were for intracranial hemorrhages. In the Swedish cohort study, HRs for fatal and/or nonfatal cerebral hemorrhage were increased, but not statistically significantly (fatal and nonfatal: adjusted HR, 1.26 [95% CI, 0.70 to 2.25]; fatal: adjusted HR, 1.60 [95% CI, 0.51 to 6.05]).86 One IPD meta-analysis of six primary prevention trials from the ATT Collaboration found a relative increase in the yearly event rates for hemorrhagic strokes (RR, 1.32 [95% CI, 1.00 to 1.75]).87

### Other Bleeding Outcomes

Seshasai and colleagues conducted a study-level meta-analysis of bleeding outcomes, including nine of the 10 CVD primary prevention trials.44 They calculated the number of “nontrivial” bleeding events in each trial arm by adding the number of participants who had fatal bleeding from any site; cerebrovascular or retinal bleeding; bleeding from a hollow viscus; bleeding requiring hospitalization and/or transfusion; or study-defined major bleeding, regardless of source. Among 102,621 participants with mean followup of 6.0 years, those allocated to ASA had an excess risk of nontrivial bleeding events (9.7 events per 1,000 person-years) compared to those allocated to placebo or no ASA (7.4 events per 1,000 person-years; random effects OR, 1.31 [95% CI, 1.14 to 1.50]). When excluding the higher dosage study (BMD),72 the risk was similar (OR, 1.31 [95% CI, 1.14 to 1.51]). The results were also similar—but the magnitude tended to be higher (OR, 1.39 [95% CI, 1.11 to 1.73])—when restricting to trials of low-dose ASA (i.e., <100 mg per day).

Quantitatively measured heterogeneity for nontrivial bleeding events across the trials was considerable (I^2^=65.7% [95% CI, 30.3 to 83.1]) and was explored by Seshasai and colleagues44 for possible sources through stratified analyses of studies in groupings based on differing trial characteristics (Table 12). Results indicated that publication period (before 2000), number of bleeding events per study (<500), and daily ASA use were each significantly associated with a greater effect of ASA on nontrivial bleeding events (Table 12). The authors concluded, however, that these study-level characteristics could not sufficiently explain the heterogeneity observed. There were about five times the number of total bleeding as nontrivial bleeding events, and the risk of having any bleeding event among participants in the ASA group compared to the control groups was also increased, but heterogeneity for this estimate was extremely high (I^2^=98.0% [95% CI, 97.3 to 98.5]). Since individual factors (i.e., age, male sex, diabetes, current smoking) have been shown to be significantly related to bleeding risks in IPD meta-analyses of a subset of these studies,87 explaining the residual heterogeneity would likely require IPD meta-analysis. Without such data, average estimates for these other bleeding outcomes would not be clearly clinically applicable. In the single CVD primary prevention trial that provided time-based bleeding risks for within-trial and posttrial periods,88 cumulative incidence of GI bleeding events (any type, not just major) increased linearly over the within-trial period to a cumulative GI bleeding risk of about 6.5 percent over a median of 10.1 years in placebo users. Among participants allocated to ASA, cumulative bleeding events increased linearly to about 7.5 percent over 10.1 years (HR, 1.15 [95% CI, 1.07 to 1.24]). The absolute difference was 1 percent at about 10 years, and no further differences accrued posttrial. GI bleeding rates were markedly reduced and to similarly low levels in posttrial followup participants (cumulative incidence of 0.9% over a median posttrial followup of 7.2 years).88

Table 12 Nontrivial Bleeding According to Various Study-Level Characteristics44

Characteristics | Subgroup | OR (95% CI) | P-value for interaction
Period of publication | After the year 2000 | 1.33 (0.97 to 1.83) | 0.004
Period of publication | Before the year 2000 | 1.37 (1.16 to 1.61) | 0.004
Number of participants per study | ≥ 5,000 participants | 1.26 (1.07 to 1.47) | 0.06
Number of participants per study | < 5,000 participants | 1.43 (1.05 to 1.93) | 0.06
Number of events per study | ≥ 500 events | 1.16 (1.05 to 1.29) | 0.002
Number of events per study | < 500 events | 1.48 (1.17 to 1.86) | 0.002
Average daily dose of ASA | ≥ 100 mg | 1.26 (0.99 to 1.61) | 0.12
Average daily dose of ASA | < 100 mg | 1.40 (1.08 to 1.82) | 0.12
Schedule of ASA treatment | Daily | 1.48 (1.17 to 1.86) | 0.002
Schedule of ASA treatment | Alternate day | 1.16 (1.05 to 1.29) | 0.002
Concomitant treatment | Yes | 1.33 (1.05 to 1.69) | 0.08
Concomitant treatment | No | 1.26 (1.14 to 1.39) | 0.08

Abbreviations: ASA = acetylsalicylic acid; CI = confidence interval; mg = milligrams; OR = odds ratio

### Ulcers

We identified four trials that examined the occurrence of GI ulcers among the CVD primary prevention trials (Appendix E Table 9). We rated one as good-quality66 and three as fair-quality for harms outcomes.72,73,88 Ulcers were reported among 0.5 to 4.7 percent of control group participants during the course of the trials (Table 13). While the reason for variation in the control group rates may have reflected differing time points of followup (4.7% represented cumulative cases over 10 years, most others were around 5 years), trials also differed in terms of whether participants with GI ulcers at baseline were clearly excluded (in two trials only),72,73 the percent of female participants (0% to 100%), and the method of ascertaining adverse events (e.g., self-report vs. physician confirmation). In all of the studies, GI ulcers were more common among patients randomized to the ASA group compared to the control group, ranging from 20 to 75 percent higher risk. The increased RR was statistically significant in two of the four trials.72,88 Similar patterns were seen among the secondary prevention and cohort studies.

Table 13 Results of Included CVD Primary Prevention Trials, Ulcers

Type of Ulcer | Study | Outcome (unit) | Followup (years) | N Analyzed | Group | Results | Between Group Difference
Peptic ulcer | Cook, 2013 (companion publication to Cook, 2005)88 Good (KQ1,2); Fair (KQ6) | Ulcer, peptic (number of cases) | 10 | 19934 | ASA | 1115 (5.6%) | ASA vs. No ASA: HR 1.20 (95% CI, 1.10 to 1.31), p≤0.001^†^
Peptic ulcer | Cook, 2013 (companion publication to Cook, 2005)88 Good (KQ1,2); Fair (KQ6) | Ulcer, peptic (number of cases) | 10 | 19942 | No ASA | 931 (4.7%) | ASA vs. No ASA: HR 1.20 (95% CI, 1.10 to 1.31), p≤0.001^†^
Peptic ulcer | Peto, 1988 (BMD)72 Fair | Ulcer, peptic (number of participants) | 6 | 3429 | ASA | 88 (2.6%) | ASA vs. No ASA: RR 1.57 (95% CI, 1.03 to 2.39)^*^, p≤0.05
Peptic ulcer | Peto, 1988 (BMD)72 Fair | Ulcer, peptic (number of participants) | 6 | 1710 | No ASA | 28 (1.6%) | ASA vs. No ASA: RR 1.57 (95% CI, 1.03 to 2.39)^*^, p≤0.05
Peptic ulcer | PHS, 1989^73^ Good (KQ1); Fair (KQ6) | Ulcer, peptic (number of participants) | 5 | 11037 | ASA | 156 (1.4%) | ASA vs. Placebo: RR 1.21 (95% CI, 0.96 to 1.52)^*^, p=0.11^‡^
GI ulcer | Fowkes, 2010 (AAA)66 Good | Ulcer, GI (number of participants) | 8.2 | 1675 | ASA | 14 (0.8%) | ASA vs. Placebo: RR 1.75 (95% CI, 0.74 to 4.16)^*^
GI ulcer | Fowkes, 2010 (AAA)66 Good | Ulcer, GI (number of participants) | 8.2 | 1675 | Placebo | 8 (0.5%) | ASA vs. Placebo: RR 1.75 (95% CI, 0.74 to 4.16)^*^
GI ulcer | PHS, 1989^73^ Good (KQ1); Fair (KQ6) | Ulcer, upper GI (number of participants) | 5 | 11037 | ASA | 169 (1.5%) | ASA vs. Placebo: RR 1.22 (95% CI, 0.98 to 1.53), p=0.08^‡^
GI ulcer | PHS, 1989^73^ Good (KQ1); Fair (KQ6) | Ulcer, upper GI (number of participants) | 5 | 11034 | Placebo | 138 (1.3%) | ASA vs. Placebo: RR 1.22 (95% CI, 0.98 to 1.53), p=0.08^‡^

* Calculated

† Adjusted by age, vitamin E and beta-carotene treatment assignment

‡ Adjusted by age and beta-carotene assignment

Abbreviations: ASA = acetylsalicylic acid; CI = confidence interval; GI = gastrointestinal; HR = hazard ratio; KQ = key question; RR = relative risk

### ARMD

ARMD outcomes were reported for two good-quality RCTs (Appendix E Table 10), the female-only WHS91 and male-only PHS.92 Both were 2×2 factorial trials evaluating alternate day ASA (100 mg in WHS and 325 mg in PHS) with or without vitamin E among health professionals. Neither trial reported statistically significant increased risk of ARMD (with or without vision loss) or visually significant ARMD (defined as 20/30 or worse and attributable to ARMD) among those allocated to the ASA group compared to those allocated to the control group. In both trials, self-reported ARMD diagnoses were confirmed by review of medical records, although blinding of outcome assessment was reported only for WHS. Results were calculated using Cox proportional hazard regression models for both studies, adjusting for age and vitamin E random allocation (both studies) and beta-carotene random allocation (WHS only).

In PHS, 117 cases of ARMD (with or without vision loss) were confirmed among 21,216 male participants. Fifty-one cases occurred in the ASA group and 66 in the placebo group (adjusted RR, 0.77 [95% CI, 0.54 to 1.11]). Visually significant ARMD occurred among 25 men in the ASA group and 32 in the placebo group (adjusted RR, 0.78 [95% CI, 0.46 to 1.32]). In subgroup analyses by age, the RRs tended to be lower among older men, but the interaction effects were not statistically significant. Baseline hypertension (defined as systolic blood pressure ≥160 mm Hg, diastolic blood pressure ≥95 mm Hg, or treatment for hypertension) had a statistically significant interaction with the relationship between ASA and ARMD, with or without vision loss (p=0.04 for interaction). Among men reporting baseline hypertension, ASA group assignment was associated with a reduced risk of ARMD (adjusted RR, 0.35 [95% CI, 0.15 to 0.83]). Among men without hypertension, there was no significant association between ASA group and ARMD (RR, 0.95 [95% CI, 0.63 to 1.44]). Analyses of ARMD in the PHS data were restricted to participants who reported no ARMD at baseline and who had at least 7 years of observation.

In WHS, 693 cases of ARMD (with or without vision loss) were confirmed among 39,421 female participants over an average of 10 years. Assignment to the ASA group was not associated with the development of ARMD (adjusted HR, 1.03 [95% CI, 0.88 to 1.21]). The risk of ARMD with vision loss was nonsignificantly reduced among the ASA group (111 vs. 134 cases in the ASA and control groups, respectively; adjusted HR, 0.82 [95% CI, 0.64 to 1.06]). Women allocated to the ASA group had a nonsignificant 10 percent reduced risk of developing advanced ARMD compared to the placebo group (26 vs. 29 cases in the ASA and placebo groups, respectively; adjusted HR, 0.90 [95% CI, 0.53 to 1.52]). The relationship between ASA group assignment and ARMD appeared to be modified by self-reported use of multivitamins. Among multivitamin current nonusers, the risk of ARMD was significantly reduced by 32 percent within the ASA group compared to the control group (HR, 0.68 [95% CI, 0.49 to 0.95]). Among multivitamin users, in contrast, there was a nonsignificant 14 percent increase among the ASA group compared to the control group (HR, 1.14 [95% CI, 0.76 to 1.70]; p=0.053 for interaction). In WHS, ARMD was diagnosed by blinded review of medical records. Analyses were conducted using Cox proportional hazard regression, adjusting results for age at baseline and randomized vitamin E and beta-carotene assignments.

## KQ 6a Does the Effect of Aspirin Vary by a Priori Subgroups (Age, Sex, Race/Ethnicity, Baseline Cancer Risk, Comorbid Conditions, or Concomitant Medication Use)?

Few trials evaluated variability in harmful effects of ASA by our a priori subgroups. We had some data to evaluate age, sex, and diabetes subgroups, but no information on subgroups based on cancer risk or liver disease and little on previous ulcer disease or GI bleeding. In fact, many trials restricted patient enrollment to those without bleeding risk factors, excluding those: with a history of ASA intolerance or contraindications (22 of 30 trials [eight of the CVD primary prevention trials]); with a history of prior GI or other bleeding (nine of 30 trials [three of the CVD primary prevention trials]) or history of ulcer (13 of 30 trials [six of the CVD primary prevention trials]); or who indicated current or possible future use of other NSAIDS (10 of 30 trials [one CVD primary prevention trial]) or antiplatelets/anticoagulants (22 of 30 trials [six of the CVD primary prevention trials]). Others focused exclusively on subpopulations, such as persons with diabetes.57,64,70

Among the two prospective cohort studies with sufficient ASA exposure documentation to allow reasonably precise exposure outcome estimates, one excluded history of hemorrhagic stroke or any medical condition or medication predisposing to such bleeding.86 The other study85 excluded former ASA users, but otherwise reported bleeding risks associated with many of these factors in a relatively unselected cohort of new low-dose ASA users matched to controls. Although ASA exposures were measured in ways that prevented precise risk estimates associated with ASA use in the other two large cohort studies,83,84 these studies were used to examine effect modification within strata of ASA exposure. Overall, bleeding risks associated with ASA in this review largely reflect the fact that many individuals at increased risk had limited or no representation in the included studies; further, assessment of individualized bleeding risks associated with ASA use was limited by lack of detailed study reporting and relatively limited IPD meta-analysis addressing bleeding harms.

Even where reported, subgroup findings related to differential bleeding harms with ASA use must be carefully considered, since these may reflect underlying (baseline) differences in risk of bleeding in that subgroup or actual effect modification, wherein ASA differently affects RRs of bleeding in that subgroup of users compared to the larger group of ASA users versus nonusers. The “excess risk” of harm with ASA use (above baseline risks and attributable to ASA) is of most interest to decisionmakers interested in ASA chemoprevention.93 These issues would be best separated by considering both the absolute and relative risks of bleeding (baseline risk) among nonusers of ASA overall and for a priori subgroups, as well as a priori subgroup-specific absolute and relative risks of bleeding among low-dose ASA users versus nonusers. Accordingly, we report data for these measures where available, clarifying differences between data estimating baseline risks (Table 14) and those estimating excess risks wherever possible (Table 15). Further, since harms estimates may vary by population type and characteristics of the ASA regimen (dose, frequency, duration), as well as by study design (study type, duration of followup), we also consider these factors in a companion question below.

Table 15 Relative Rate Ratios for Bleeding Among Subpopulations From Trials and Cohort Studies

Baseline Characteristic | Major GI/Extracranial Bleeding^‡^ from ATT Collaboration, 2009^87^ Adjusted Rate Ratio (95% CI) | Intracranial Bleeding/Hemorrhagic Stroke from ATT Collaboration, 2009^87^ Adjusted Rate Ratio (95% CI) | Hospitalizations for Major Bleeding Event^§^ from cohort study (de Berardis85) Adjusted Incidence Rate Ratio (95% CI)
Age | 2.15 (1.93 to 2.39) per decade | 1.59 (1.33 to 1.90) per decade | 1.05 (1.05 to 1.05) per year
Male sex (vs. female) | 1.99 (1.45 to 2.73) | 1.11 (0.52 to 2.34) | 1.69 (1.61 to 1.79)
Diabetes (yes vs. no) | 1.55 (1.13 to 2.14) | 1.74 (0.95 to 3.17) | 1.36 (1.28 to 1.44)
Current Smoker (yes vs. no) | 1.56 (1.25 to 1.94) | 2.18 (1.57 to 3.02)
Mean BP (per 20 mm Hg) | 1.32 (1.09 to 1.58) | 2.18 (1.62 to 2.87)
Cholesterol (per 1 mmol/L) | 0.99 (0.90 to 1.08 | 0.90 (0.77 to 1.07)
BMI (per 5 kilograms): | 1.24 (1.13 to1.35) | 0.85 (0.71 to 1.02)
Previous GI hospitalization (yes vs no) | --- | --- | 2.87 (2.46 to 3.35)
Medication use (yes vs no):
NSAIDS | | | 1.10 (1.05 to 1.16)
ASA^†^ | | | 1.55 (1.48 to 1.63)^*^ 1.61 (1.54 to 1.69)║
Any antihypertensive | | | 1.14 (1.08 to 1.19)
Statins | | | 0.67 (0.62 to 0.71)
PPI | | | 0.84 (0.80 to 0.88)

* Crude incidence rate ratio (95% CI)

† Used as an analgesic

‡ Resulting in hospitalization, transfusion or death

§ Combined GI bleeding and intracranial hemorrhage/hemorrhagic stroke

║ Adjusted incidence rate ratio

Abbreviations: ASA = acetylsalicylic acid; BMI = body mass index; CI = confidence interval; GI = gastrointestinal; mmol/L = millmoles per liter; mm Hg = millimeters of mercury; NSAID = nonsteroidal anti-inflammatory drugs; PPI = proton pump inhibitor; vs = versus

### Age

#### Major Bleeding (GI and Cerebral)

Absolute rates of hospitalization for major bleeding events (GI and cerebral) from adequately sized studies were available for age-specific subgroups in one very large population-based cohort study with greater than 1.6 million person-years of observation comparing new users of ≤300 mg ASA per day (presumably for either primary and secondary prevention) with propensity-score matched never-users.85 Among never-users, unadjusted incidence rates of hospitalization for major bleeding events over 6 years increased significantly during each age decile after 50 years from a low of 0.61 events (95% CI, 0.41 to 0.91) per 1,000 person-years in those ages 30 to 50 years to a high of 6.93 events (95% CI, 6.51 to 7.38) per 1,000 person-years in those age 80 years or older (Table 14). During each decade, incidence rates among never-users approximately doubled, ranging from 1.40 events (95% CI, 1.24 to 1.58) per 1,000 person-years in those ages 50 to 59 years, to 2.58 events (95% CI, 2.40 to 2.77) per 1,000 person-years in those ages 60 to 69 years, to 4.61 events (95% CI, 4.39 to 4.85) per 1,000 person-years in those ages 70 to 79 years. Among current ASA users, absolute incidence rates of hospitalization for major bleeding events also increased with each decade of older age, from 2.48 events (95% CI, 2.19 to 2.82) per 1,000 person-years in those ages 50 to 59 years to 10.60 events (95% CI, 9.91 to 11.23) per 1,000 person-years in those age 80 years or older. For each age decade, incidence rates for hospitalization for major bleeding events among low-dose ASA users were comparable to those of nonASA users one decade older. Thus, the unadjusted baseline risk of hospitalization for major bleeding events increased with age, as did the excess risk with ASA use, particularly among those age 70 years and older, in whom excess major bleeding events exceeded 2.0 per 1,000 person-years of ASA use.

The effect of ASA on major bleeding risk (IRRs in ASA users vs. never-users) differed significantly by age (p=0.009 for interaction).85 Low-dose ASA users younger than age 50 years had a significantly elevated IRR (3.17 [95% CI, 1.99 to 5.05]). IRRs of major bleeding with ASA use were also consistently increased about 1.5 times in those age 60 years and older (ages 60 to 69 years: IRR, 1.53 [95% CI, 1.38 to 1.69]; ages 70 to 79 years: 1.49 [95% CI, 1.38 to 1.60]; age ≥80 years: 1.52 [95% CI, 1.39 to 1.66]), but was lower in magnitude than in younger users. Thus, age modified the RR associated with ASA use due to very low baseline risks in younger adults. After adjusting for multiple factors, including ASA use, each additional year of age was associated with a 5 percent higher incidence rate for hospitalization for major bleeding events (IRR, 1.05) (Table 15).

#### Major GI/Extracranial Bleeding

In a separate IPD meta-analysis of six CVD primary prevention trials by the ATT Collaboration, absolute yearly incidence of bleeding increased with each decade of age after adjusting for multiple baseline risk factors, including allocation to ASA use (Table 15).87 For each subsequent decade, rate ratios increased for major extracranial bleeding (2.15 [95% CI, 1.93 to 2.39]). One of these trials that included about 7 percent of all participants taking low-dose ASA included in this analysis, however, used a higher dose (500 mg) of ASA, which could modestly inflate these estimates.72 As a whole, available data reflect increased baseline risk for bleeding with aging, controlling for ASA use, in a primary prevention population. The effect of ASA versus no ASA on major extracranial bleeding, however, was similar among participants younger than 65 age years (rate ratio, 1.53 [95% CI, 1.16 to 2.03]) and among those age 65 years or older (rate ratio, 1.55 [95% CI, 1.08 to 2.21]; p=1.0 for interaction).

Prospective cohort studies also found no difference in HRs for major GI bleeding with ASA use by those younger than age 60 years compared to older men or women (p>0.50 for interaction).83,84 These two studies, however, are not strong evidence against age-based effect modification, since ASA exposure in these studies was likely insufficient to sensitively detect differing effects.

#### Intracranial Bleeding, Including Hemorrhagic Stroke

One IPD meta-analysis by the ATT Collaboration of six CVD primary prevention studies suggested age (per decade) (Table 15) increased hemorrhagic stroke risk by 59 percent in analyses adjusting for other risks and ASA use (rate ratio, 1.59 [95% CI, 1.33 to 1.90]).87

### Sex

Sex-specific absolute rates of GI bleeding were reported in two sex-specific trials in CVD primary prevention populations.60,73 Bleeding events (serious or otherwise) were generally defined too differently in the two trials to be comparable, except for fatal GI hemorrhages, which were exceedingly rare and therefore imprecise.

In IPD meta-analysis conducted by the ATT Collaboration87 of six CVD primary prevention trials, adjusted for multiple baseline risk factors, including allocation to ASA use, rates of major extracranial bleeding were about twice as high in men than women; no sex differences were seen in hemorrhagic stroke rates.87 These data reflect increased baseline risk for bleeding with male sex, controlling for other risk factors (Table 15).

Based on cohort data from the previously described Italian population-based cohort study comparing new ASA users of 300 mg or less per day with propensity-score matched never-users,85 unadjusted absolute rates for hospitalization for major bleeding events in male never-users were elevated (4.50 per 1,000 person-years [95% CI, 4.30 to 4.70]) whether compared to female never-users (2.86 per 1,000 person-years [95% CI, 2.72 to 3.01]) or all never-users (3.60 [95% CI, 3.48 to 3.72]) (Table 14). Among current ASA users, men experienced 6.42 hospitalizations for major bleeding events (95% CI, 6.14 to 6.72) per 1,000 person-years, with an excess of 1.63 hospitalizations compared to women. This excess event rate was similar to that between male and female nonusers, suggesting that male sex was associated with increased bleeding risk that was maintained, but not further modified, with low-dose ASA use.

Within sex-specific categories in the same cohort study, IRRs in ASA users versus nonusers were significantly different in men compared to women (p=0.001 for interaction) and slightly lower (1.43 vs. 1.67), although both estimates hovered around 1.5 times, and absolute differences with ASA use were virtually the same (1.92 vs. 1.93 hospitalizations for major bleeding events per 1,000 person-years). These relative effect differences likely reflect the baseline difference in bleeding risk between men and women, which was confirmed by the persistence of an increased IRR for men compared to women (1.69 [95% CI, 1.61 to 1.79]) after adjusting for multiple other risk factors, including ASA use (Table 15).

A separate cohort study in persons with diabetes found no differences between men and women in any bleeding outcomes, although event rates were small, limiting firm conclusions.86

### Race/Ethnicity

Race/ethnicity status for enrolled populations was reported in relatively few trials (k=9).59,64,70,71, 75,77,78,81 No bleeding risks were stratified by race/ethnicity. Thus, racial/ethnic minorities (i.e., those of Hispanic, African, Native and Pacific Islander, and Asian other than Japanese descent) are clearly underrepresented in trials reporting these population characteristics, and likely underrepresented in most others, given their geographical location. The baseline rate of intracranial hemorrhage among control group participants was the highest in the single Japanese CVD primary prevention trial (1.25 events per 1,000 person-years), among all of the CVD primary prevention trials, based on our method of estimating control group rates. This estimate, however, represents only seven events and therefore is not stable. Participants in the trial had a high prevalence of several risk factors for intracranial hemorrhage (mean age of 64.5 years, >50% with hypertension, and >50% current or former smokers). Because of this, the independent role of race/ethnicity cannot be determined with the available data.

### Diabetes Mellitus

Four CVD primary prevention trials51,57,64,70 and one cohort study86 limited their study populations to those with diabetes mellitus. One primary prevention trial61 and one cohort study85 included a broader population and reported harms results in the subpopulation of those with diabetes mellitus.

Based on limited data (due to low study event rates and use of different bleeding outcomes), many trials limited to populations with diabetes could not be used to estimate absolute bleeding risks in patients with diabetes, with or without ASA use. Relative upper GI bleeding risks (number of events or per person), however, were increased about three-fold in ASA users with diabetes compared to nonusers with diabetes in one of the two trials reporting this outcome,70 but not the other.57 In one CVD primary prevention trial that reported subgroup effects among the population with diabetes, nonfatal GI bleeding events over 3.7 years tended to be exaggerated with ASA use (7 times greater in diabetic ASA users vs. nonusers compared to 4 times greater in the whole population of ASA users vs. nonusers), although event rates were too sparse to allow for robust statistical comparisons.61

One IPD meta-analysis by the ATT Collaboration of six CVD primary prevention studies found no apparent modification of ASA's effect on major extracranial bleeding by prior diabetes status, although less than 10 percent of the population had prior diabetes diagnoses, which limits the statistical power. In adjusted analyses, diabetes mellitus increased major extracranial bleeding by 55 percent (95% CI, 13% to 214%) after adjusting for ASA use, and also tended toward increased hemorrhagic stroke risk, but these estimates were more imprecise (74% [95% CI, -5% to 317%]) due to small numbers of events (Table 15).87

Absolute bleeding risks among persons with diabetes could be estimated in two cohort studies.85,86 Among never-users of ASA from the large Italian cohort, unadjusted incidence rates for hospitalization for major bleeding events were 5.35 (95% CI, 4.97 to 5.76) per 1,000 person-years in patients with diabetes compared to 3.32 (95% CI, 3.20 to 3.45) in those without diabetes (IRR, 1.61 [95% CI, 1.49 to 1.75]).85 In contrast, among current low-dose ASA users, incidence rates for hospitalization for major bleeding events were high, but were similar between those with and without diabetes (5.83 and 5.53 per 1,000 person-years, respectively). The IRRs indicated a very similar increase in bleeding risk (61% to 66%) from having diabetes (vs. not) in those not taking ASA, and from taking ASA (vs. not) in those without diabetes (IRR, 1.61 to 1.66). These data would indicate that baseline risk of bleeding among persons with diabetes is elevated, but there may be little excess risk associated with ASA use. Diabetes status itself could be associated with other bleeding risks. In an analysis adjusted for multiple other baseline risk factors and ASA use, diabetes status alone was still associated with increased rates of hospitalization for major bleeding events, but more modestly (36% increase [95% CI, 28% to 44%]). Among 18,646 Swedish patients with diabetes known to be free of CVD, absolute bleeding events for all fatal and nonfatal hemorrhages (cerebral or gastric) were 2.4 per 1,000 person-years.86 Adjusted HRs showed a trend toward further increased risk in those taking low-dose ASA (1.41 [95% CI, 0.99 to 1.99]), which indicates an approximate rate of 1.7 events per 1,000 person-years for fatal/nonfatal hemorrhages in nonASA users. Events were too rare (157 total hemorrhages) to subdivide further with much precision. This cohort study is further limited in estimating benefits or harms, since each individual was censored after incidence of their first outcome, regardless of type.

In summary, adjusted analyses from IPD meta-analysis of primary prevention trials and a very large cohort study indicate an increased risk of major bleeding in persons with diabetes (36% to 55%); data were mixed as to whether low-dose ASA further increased bleeding risk, and further research would be informative.

### Other Bleeding Risk Factors

Although not part of our a priori subgroups, we evaluated other major risk factors for CVD besides age, sex, and diabetes post hoc as potential risk factors for bleeding-associated harms, since an IPD meta-analysis by the ATT Collaboration of six CVD primary prevention trials found that risk factors for CVD outcomes (i.e., current smoking, hypertension) that would increase absolute benefits from ASA use were also associated with increased bleeding risks.87 We also considered whether overall CVD risk or indication (primary vs. secondary CVD prevention) was associated with bleeding risks.

#### Smoking

No data on current smoking and bleeding risk was reported in any included CVD primary prevention trial. Two cohort studies with relatively imprecise ASA exposure data reported no effect modification on GI bleeding risk by smoking status in women or men.83,84 Current smoking more than doubled hemorrhagic stroke rates (with a more modest 56% increased rate of major extracranial bleeding risk) in an IPD meta-analysis by the ATT Collaboration after adjusting for other risks and ASA use (Table 15).87

#### Hypertension

One CVD primary prevention trial67 and one cohort study85 considered whether hypertension status affected bleeding risks with ASA. Patients with hypertension were judged to be at medium (15% to 20%) or high (≥20%) 10-year risk of cardiovascular death, nonfatal stroke, or nonfatal MI. Major fatal and nonfatal bleeding events (204 events total) per 1,000 person-years were somewhat higher in the high CVD risk group taking placebo compared to the medium CVD risk group (3.0 vs. 1.4 events per 1,000 person-years, respectively), although treatment-subgroup interactions were not significant. With ASA use, both groups experienced an absolute risk increase of 1.3 to 1.5 events per 1,000 person-years.

In the analyses conducted by the ATT Collaboration of IPD adjusting for other risks and ASA use, increases in mean blood pressure (per 20 mm Hg) more than doubled hemorrhagic stroke rates (with a more modest 32% increased rate of major extracranial bleeding) (Table 15).87

In an Italian cohort study,85 absolute unadjusted rates of hospitalization for major bleeding events among never-users of ASA with hypertension were 4.23 (95% CI, 4.06 to 4.40) per 1,000 person-years compared to 2.74 (95% CI, 2.59 to 2.90) in never-users without hypertension (IRR, 1.54). In contrast, among current low-dose ASA users, incidence rates for hospitalization for major bleeding events were high, but quite similar between those with and without hypertension (5.69 and 5.42 per 1,000 person-years, respectively). Unlike in patients with diabetes, bleeding risks increased with ASA use in both those with and without hypertension (34% and 98%, respectively). In an analysis adjusted for multiple other baseline risk factors, hypertension status was associated with a more modest (14%) greater IRR for major bleeding events.

#### CVD Risk Categories

Few CVD primary prevention trials reported baseline CVD risk categories60,67,69 and only one reported bleeding risk by CVD risk status. This trial found increased event rates, but no treatment-subgroup interaction among patients with well-managed hypertension at medium or high CVD risk.67

#### Primary Versus Secondary Prevention

Among all 30 trials of ASA for any primary or secondary prevention use included in our review, 15 reported major GI bleeding events after 1 to 10 years of followup. In study-level meta-analyses stratified by population (CVD primary prevention, CVD secondary prevention, and CRC/adenoma prevention), RR estimates associated with ASA use appeared higher (after excluding ASA doses >300 mg), although the 95% CI overlapped and the p-value for interaction was not significant. Event rates were relatively low across all arms (0.27% to 0.64%), with much fewer participants and, therefore, fewer absolute events in the CVD secondary prevention trials. Our findings were consistent, but weaker, for intracranial hemorrhage due to even fewer events. Restricting to dosages of 100 mg or less, however, removed much of the distinction by population. A separate IPD meta-analysis by the ATT Collaboration was suggestive of increased risk of major extracranial bleeding in secondary prevention trials compared to primary prevention (rate ratio, 2.69 [95% CI, 1.25 to 5.70] and 1.54 [95% CI, 1.30 to 1.82], respectively), but were too sparsely reported (only five of 16 secondary prevention trials reporting a total of 30 events compared to 570 in primary prevention trials) to confirm whether these bleeding risks varied between these populations.87 A large population-based cohort study85 did not examine CVD risk, per se, but did find that a history of previous hospitalization for CVD problems (a weak surrogate for a secondary prevention population) significantly increased hospitalization for major bleeding events in ASA nonusers compared to either those without such a history or to all nonusers; multivariate analyses confirmed an independent increase in rates of major bleeding event hospitalization in those with prior CVD hospitalization (IRR, 1.29 [95% CI, 1.10 to 1.51]). Altogether, these data do not clearly confirm or exclude a higher bleeding risk with ASA use for those with selected cardiovascular risk factors or in CVD secondary prevention populations in general.

### Previous Ulcer or GI Bleeding History

One good-quality cohort study reported the impact of previous hospitalization for GI problems among never-users and current low-dose ASA users.85 Less than 1 percent of individuals had this history overall, with prior GI-related hospitalizations less common among current low-dose ASA users (0.67%) than among never-users (1.13%). Among never-users, unadjusted incidence rates for hospitalization for major bleeding events among those with a GI-hospitalization history were 12.00 events (95% CI, 10.03 to 14.44) per 1,000 person-years. Among low-dose ASA users with a GI-hospitalization history, unadjusted incidence rates were 14.00 events (95% CI, 10.70 to 18.24) per 1,000 person-years and not significantly higher than never-users (IRR, 1.16 [95% CI, 0.84 to 1.60]). After adjusting for other risk factors, including ASA use, previous hospitalization for GI problems had the largest impact on increased incidence rates for hospitalization for major bleeding events with an IRR of 2.87 (95% CI, 2.46 to 3.35), suggesting a relative contraindication for ASA use among these individuals (Table 15).

### Concomitant Medication Use

We specified a priori examination of the concurrent use of SSRIs and nonASA NSAIDs since these are likely in CVD primary prevention populations. None of the CVD primary prevention trials reported bleeding results considering comedication usage; many trials excluded those who were using or might use medications associated with increased bleeding risks, although few specifically excluded nonASA NSAIDs or SSRIs. Among the 10 CVD primary prevention trials, six reported baseline medication usage;57,60,61,66,70 these focused mainly on diabetes, hypertension, or lipid-lowering medications and none reported on SSRIs or nonASA NSAIDs. One additional CVD primary prevention study,51 five CVD secondary prevention trials,54,59,65,71, 75 and no adenoma prevention trials reported baseline medication usage. Three CVD secondary prevention trials from the 1980s or early 1990s reported that 6 to 15 percent of participants had regular, weekly, or daily ASA use at baseline.65,71,75

Among the included cohort studies, one included many participants taking comedications, including NSAIDs (35%), SSRIs (5%), antihypertensives (57%), oral anticoagulants (7%), systemic corticosteroids (9%), statins (25%), and proton pump inhibitors (PPIs) (46%).85 This good-quality cohort study reported the impact of NSAIDs, SSRIs, and other medications on bleeding risk in current users and never-users of low-dose ASA. Among never-users, those who used SSRIs had significantly increased unadjusted incidence rates for hospitalization for major bleeding events (4.09 events [95% CI, 3.90 to 4.28] per 1,000 person-years) compared to those who did not use SSRIs (3.61 events [95% CI, 3.49 to 3.73] per 1,000 person-years), but not those using NSAIDs or ASA as an analgesic compared to those not using those medications. Unadjusted absolute incidence rates of hospitalization for major bleeding events in ASA users did not appear to be modified by baseline NSAID use, although SSRI and low-dose ASA users had no increased risk above SSRI users alone. In this data set, the use of ASA as an analgesic (along with low-dose ASA) suggested a very high, but imprecisely estimated, risk for major bleeding hospitalization events (11.40 events [95% CI, 5.45 to 24.00] per 1,000 person-years). In multivariable adjusted analyses including ASA use and other risk factors, NSAID use independently increased major bleeding risk (adjusted IRR, 1.10 [95% CI, 1.05 to 1.16]) (Table 15); several other comedications also did so, and more strongly (e.g., anticoagulants and antiplatelets). These data suggest that the major bleeding event risks are mildly increased when NSAID use is combined with low-dose ASA. SSRIs do not appear to have a strong additional effect, and other comedication use could be of greater concern. Adjusted analyses suggested a protective effect of statins (IRR, 0.67 [95% CI, 0.62 to 0.71]) and PPIs (IRR, 0.84 [95% CI 0.80 to 0.88]). These results would be important to replicate.

Two cohort studies that could not be used to estimate absolute bleeding risks due to incomplete information on exposure evaluated whether there was effect modification by concurrent medication use in those who reported taking two or more 325-mg ASA tablets per week over the prior 2 years.83,84 Neither study found a significant interaction between NSAID use and increased risk of major GI bleeding with ASA use (p≥0.50),83,84 although imprecise exposure data could also affect these analyses.

## KQ 6b Does the Effect of Aspirin Vary by Delivery of Intervention (e.g., Dose, Frequency, Duration, Formulation, and Recency of Use)?

Although the body of literature evaluating ASA benefits and harms varies considerably in terms of ASA regimens assessed, most of the evidence to assess differences is indirect and subject to confounding by other between-study differences. One of the included trials purposefully evaluated variations in dosage,65 but none did so for frequency, duration, or formulation of low-dose ASA within their study designs. Cohort studies either restricted to a single low-dose,86 did not evaluate dosage effects within the included range of low-dose ASA,85 or could not provide precise dosage-related risk estimates due to exposure measurement issues.83,84 These studies, however, may address qualitative trends or effect modification within strata of ASA use.83,84

An IPD meta-analysis by Rothwell and colleagues (2012) did not primarily look at issues of intervention delivery, often restricting studies to reduce variability in intervention characteristics.10 One study-level meta-analysis of CVD primary prevention trials found that risks of nontrivial bleeding varied significantly by period of publication, with increased risks reported in earlier publications (before 2000), studies with fewer events (<500 total), and in regimens of daily versus alternate day ASA use, although frequency comparisons represent between-study rather than within-study differences.44 Any apparent differences between studies should be viewed cautiously due to potential confounding by other between-study differences (i.e., methodological as well as clinical heterogeneity).

### Dose

Only one trial varied ASA dosage and found that there was more GI bleeding in 1,200 mg users (11 events per 1,000 person-years) than in 300 mg users (7 events per 1,000 person-years) or those taking placebo (3 events per 1,000 person-years).65 In cohort data, major GI bleeding risks adjusted for age were increased (RR, 1.56 [95% CI, 1.41 to 1.73]) in women with regular ASA use (defined as two or more 325-mg tablets each week for the prior 2 years) compared to nonregular ASA users.84 After adjusting for duration of use, women taking the highest cumulative ASA dosage (>14 tablets per week) had more than twice the risk of major GI bleeding than nonASA users (RR, 2.24 [95% CI, 1.66 to 3.03]). Similarly, higher daily dosages of ASA use in men (325 vs. 81 mg) tended to be associated with higher rates of GI bleeding (3.5 vs. 2.7 events per 1,000 person-years, respectively), although multivariable adjusted RRs compared to nonASA users were not statistically significantly different between the two dosages (1.67 [95% CI, 1.20 to 2.33] vs. 1.17 [95% CI, 0.89 to 1.53]), perhaps due to limited event rates (146 events in ASA users and 139 events in nonusers).83 In both of these cohorts, trend analyses strongly supported the impact of increasing cumulative weekly dosage within both short- and long-term regular ASA users, for lower as well as upper GI bleeding. This was particularly true in women83,84 and for subarachnoid hemorrhages in men age 55 years and older.94 In contrast, a study-level meta-analysis of CVD primary prevention trials reported no difference in harmful effects between studies with 100 mg daily or more compared to lesser dosages; however, this study-level meta-regression did not control for other known study-level differences, including event rates, year of publication, and dosage frequency.44 Thus, while the majority of evidence in our review supports dose-related bleeding risks with ASA use, there may be fewer differences within the range of low-dose ASA usage commonly employed in primary prevention.

### Frequency

All CVD primary prevention trials evaluated daily ASA use, except two trials that evaluated 100 mg ASA every other day in women60 and 325 mg ASA every other day in men.73 However, apparent differences from other trials employing daily use could be confounded by other between-study differences, such as baseline rates of bleeding. When considered together in study-level meta-analysis, trials employing every other day ASA use had lower elevations in nontrivial bleeding risk (OR, 1.16 [95% CI, 1.05 to 1.29]) compared to trials in daily users (OR, 1.48 [95% CI, 1.17 to 1.86]; p=0.002 for interaction).44 These analyses, however, do not control for other between-study differences (baseline event rates, period of publication). In cohort studies, most bleeding cases in recent years in the Health Professional Study (2000 to 2008) were in those with daily use (106 of 146 participants), as opposed to less than daily use.83 In the Nurse's Health Study, there was a significant trend for GI bleeding with greater number of ASA tablets per week.84

### Duration

Bleeding risks associated with low-dose ASA use are apparent early on and likely persist throughout usage. In WHS, cumulative incidence of GI bleeding appeared to increase in those allocated to 100 mg of ASA every other day compared to those taking placebo throughout the median 10.1 years of followup.88 Other data has suggested bleeding risk may be most pronounced early on.

Stratified meta-analysis of major extracranial bleeding in an IPD meta-analysis by Rothwell and colleagues (2012) of six CVD primary prevention trials suggested greater risk at 0 to 2.9 years versus 3 years or later (OR, 1.95 [95% CI, 1.47 to 2.59] vs. 1.04 [95% CI, 0.73 to 1.49]; p=0.006), with a significant interaction between time as a continuous variable and major extracranial bleeding (p=0.003), without major heterogeneity in absolute annual risks.10 Risks decreased over time in the placebo group from 41 to 35 events per 10,000 person-years, suggesting something other than a diminution of ASA effect; this effect most likely represents reduced time at risk due to unequal followup in the 3 year or later time period compared to the up to 3 year time period in three of six trials (i.e., total mean/median years of followup: 3.6 years in PPP, 3.8 years in HOT, and 4.4 years in JPAD). We were unable to evaluate time-to-event data in our study-level meta-analysis.

Limited cohort data address whether the magnitude effect is the same throughout the periods of active ASA usage, also considering the degree of persistence. Among daily users (>6 days per week or six to 14 full-dose [325 mg] tablets per week), relative GI bleeding risks were similarly increased among those taking ASA for less than or greater than 5 years.83 Among regular users (two or more 325-mg ASA tablets per week), duration of ASA use for greater than 5 years did not alter the impact of increasing dosage on bleeding risk.84 Thus, limited but consistent data suggests bleeding risks appear to be maintained, not increased, but also not diminished with long-term use.

### Formulation

None of our included studies varied ASA formulations experimentally, although some allowed formulation changes as needed for individuals as part of the protocol. Formulations varied somewhat across studies (regular, controlled release, enteric coated, soluble), but many studies did not report the formulation and studies differed in many other aspects. No IPD meta-analysis examined the impact of formulation on risk of harms or benefits.

### Recency of Use

The only study with information on recency of use was the WHS trial,88 but data were highly limited due to poor quality of ascertaining most posttrial harms and by high cross-over during the posttrial period. Nonetheless, data from this study suggest relatively rapid attenuation of increased GI bleeding and ulcer risks after cessation of ASA.