# Methods

## Scope and Purpose

This review was commissioned by AHRQ alongside two separate reviews to support the USPSTF in updating its previous recommendations on ASA for the primary prevention of CRC and CVD.40,41 Specifically, this review undertook new Key Questions (KQs) assessing the effect of ASA on cancer incidence and mortality (as opposed to CRC incidence and mortality only, which is addressed in the companion review). In addition, this review served as an “umbrella” review, considering evidence from all three reviews to comprehensively address all-cause mortality and harms related to low-dose ASA use; this strategy was novel and was undertaken in recognition that ASA effects on these broader outcomes might be more appropriately or precisely estimated outside of a disease-specific perspective. Similarly, issues of bleeding risks with and without ASA use were assessed more comprehensively (i.e., considering data from included studies in both of the other reviews) and in more depth (considering observational studies) in this review than in the companion reviews.

## KQs and Analytic Framework

We developed an analytic framework (Figure 1) and seven KQs to guide our review in consultation with AHRQ staff and the members of the USPSTF. This review addressed only three of the KQs (1, 2, and 6) since the other four specifically addressed the effect of ASA use on CRC outcomes and were examined in a separate review.40

1 Does regular aspirin use reduce total cancer mortality or all-cause mortality in adults taking (or eligible for) aspirin for primary prevention?
  a. Does the effect of aspirin vary by a priori subgroups: age, sex, race/ethnicity, baseline cancer risk^a^, and comorbidities^b^?
    a Baseline cancer risk includes family history and potentially other cancer risk factors if specified in the literature.
    b We considered the following comorbid conditions, which are prevalent and/or may be differentially affected by ASA use in terms of benefits or harms: diabetes, liver disease, ulcer disease, and previous GI bleeding.
  b. Does the effect of aspirin vary by delivery of intervention (e.g., dose, frequency, duration, formulation, and recency of use)?
2 Does regular aspirin use reduce the incidence of cancers in adults taking (or eligible for) aspirin for primary prevention?
  a. Does the effect of aspirin vary by a priori subgroups: age, sex, race/ethnicity, baseline cancer risk^a^,and comorbidities^b^?
  b. Does the effect of aspirin vary by delivery of intervention (e.g., dose, frequency, duration, formulation, and recency of use)?
6 What are the serious harms of regular aspirin use for the primary prevention of cancer (i.e., at the dosage and duration required to achieve a preventive health effect) in adults appropriate for aspirin chemoprevention?
  a. Does the effect of aspirin vary by a priori subgroups: age, sex, race/ethnicity, baseline cancer risk^a^, comorbidities^b^, and concomitant medication use^c^?
    c Concurrent medications included nonASA NSAIDs and selective serotonin reuptake inhibitors.
  b. Does the effect of aspirin vary by delivery of intervention (e.g., dose, frequency, duration, formulation, and recency of use)?

Figure 1 Analytic Framework

Abbreviations: ASA = acetylsalicylic acid, CRC = colorectal cancer

Note: The numbers on the analytic framework correspond to the Key Questions listed in the Methods section

The figure is an analytic framework that depicts the Key Questions addressed in this report and a companion report on aspirin use to prevent colorectal cancer. The figure illustrates how aspirin use for primary prevention among adults aged 40 years or older may reduce all-cause and cancer-related e mortality (Key Question 1) including colorectal cancer (Key Question 2); the incidence of cancers (Key Question 2) including colorectal cancer (Key Question 4); and the incidence of colorectal adenomas (Key Question 5). The analytic framework also depicts the possible harms associated with aspirin use in the primary prevention of cancer (Key Question 6) or colorectal cancers specifically (Key Question 7). This report specifically addressed Key Questions 1, 2 and 6.

## Data Sources and Searches

We conducted a literature search to identify existing systematic reviews and meta-analyses on ASA for the primary prevention of cancers. Appendix A includes our literature search strategies. To locate existing systematic reviews, we searched PubMed, the Database of Abstracts of Reviews of Effects, Cochrane Database of Systematic Reviews, Health Technology Assessment Database, Institute of Medicine, BMJ Clinical Evidence, AHRQ Evidence-based Practice Center Program, National Health Service Health Technology Assessment Programme, and the National Institute for Health and Clinical Excellence for articles published from 2008 to May 3, 2013. We supplemented this search with references identified during the topic nomination and development process, as well as a separate literature search for systematic reviews of harms from ASA supplementation (Appendix A). From these searches, we identified high-quality systematic reviews and meta-analyses from which to bridge our primary literature searches.

For KQs 1 and 2 (benefits), we bridged our search from a 2012 meta-analysis conducted by Rothwell and colleagues that identified 51 randomized, controlled trials (RCTs) of the effects of daily ASA on cancer incidence, mortality, and nonvascular deaths from searches through May 2011.^10^ We supplemented this body of literature with newly identified trials through our own comprehensive literature search of PubMed, MEDLINE, and the Cochrane Central Register of Controlled Trials from January 1, 2011 to June 3, 2014. For KQ 6 (harms), we identified four relevant systematic reviews on bleeding events that collectively identified 19 trials.10,16,18,44 We supplemented this body of literature with newly identified trials through our own comprehensive search of PubMed, MEDLINE, and the Cochrane Central Registry of Controlled Trials from January 1, 2010 (bridging from the last search date [October 2010] of the most comprehensive review16) to June 3, 2014. For prospective cohort studies of harms, we bridged from the last search date of the 2006 USPSTF review on CRC,38 searching from January 1, 2006 to June 3, 2014 in PubMed and MEDLINE only.

We also reviewed the included and excluded studies of the previous USPSTF reviews on ASA for CRC38 and CVD prevention,45 as well as those of the ongoing updated reviews,40,41 to identify any relevant primary studies. We also reviewed the reference lists of included studies and other relevant reviews and meta-analyses to identify potentially relevant included studies that may not have been identified in our literature searches. We obtained additional references from expert reviewers and members of the public.

We managed all literature search results using the bibliographic management software program Reference Manager® version 12.0 (Thomason Reuters, New York, NY).

## Study Selection

Two investigators independently reviewed titles and abstracts using the screening platform Abstrackr.46 The same investigators reviewed full-text articles of studies against prespecified criteria (Appendix A Table 1) to determine the final inclusion or exclusion status. A list of excluded studies is provided in Appendix B.

For all KQs, we included studies conducted in adults (age ≥40 years) that examined the use of ASA for any indication (e.g., primary prevention of cancer, primary or secondary prevention of CVD) if they reported relevant outcomes (i.e., all-cause mortality, cancer mortality and incidence, or harms). We excluded studies that included adult populations with a personal history of cancer or a high incidence of familial cancer syndromes (e.g., Lynch syndrome). We also excluded studies that only reported on CRC incidence and CRC-related mortality because these are included in a separate review.40 We also did not include studies that only reported biomarkers, biologic or physiologic markers of cancer (e.g., breast density), precancerous markers, progression, metastasis, or recurrence. We included studies that reported on any serious GI bleeding and/or intracranial bleeding, including hemorrhagic stroke (fatal and nonfatal).

We included studies examining regular oral ASA use (minimum of 75 mg every other day) compared to no treatment or a placebo. We excluded studies that evaluated nonoral forms of ASA. We excluded interventions that included: nonASA antithrombotic medications (e.g., warfarin); ASA as a cotreatment with another chemopreventive (e.g., tamoxifen) or potentially chemopreventive agent; or lifestyle intervention. In addition, we excluded studies if authors did not report information on the dose of ASA used or if it was limited to irregular or occasional use. The duration of ASA treatment and study followup were restricted to 1 year or greater for all KQs.

For KQs 1 and 2 (benefits), we only included RCTs or controlled clinical trials reporting on relevant outcomes. For KQ 6 (harms), we included any trials or longitudinal cohort studies reporting on relevant harms. For all KQs, we excluded all other study designs (e.g., case-control, case report). We only included studies published in English and those conducted in countries with a “very high” Human Development Index in 2013.^47^

## Quality Assessment and Data Abstraction

Two investigators independently assessed the quality of included studies using criteria defined by the USPSTF.48 We supplemented this process with quality criteria for observational studies using the Newcastle-Ottawa Scale49 and the Assessment of Multiple Systematic Reviews (AMSTAR) for systematic reviews.50 We resolved disagreements in quality through discussion.

We excluded studies rated as poor quality according to these criteria (i.e., attrition >40%, differential attrition of >10%, other “fatal flaws,” or the cumulative effects of multiple minor flaws and/or mission important information significant enough to limit our confidence in the validity of results) (Appendix A Table 2). Good-quality studies were those with adequate randomization techniques or selection of a representative cohort; allocation concealment; blinding of outcome assessors; comparable groups at baseline with specified eligibility criteria; low attrition and adequate adherence to the intervention; and acceptable statistical methods. Good-quality systematic reviews included adequate inclusion and exclusion criteria, dual study selection, data extraction and quality assessment of included studies, comprehensive literature searches, descriptions of included studies, an assessment of publication bias, and appropriate meta-analytical methods. We downgraded our quality rating for studies and reviews to fair quality if they did not meet the majority of good-quality criteria.

One investigator abstracted data from all included studies into a customized Microsoft Access^®^ database (Microsoft Corporation, Redmond, WA). A second investigator checked the data for accuracy. We abstracted study design characteristics, population demographics, intervention details, health outcomes (e.g., mortality), adverse events, and subgroup analyses (as necessary).

## Data Synthesis and Analysis

Where possible, we examined stratified results by population: CVD primary prevention, CVD secondary prevention, and other (e.g., combined CVD prevention and CRC chemoprevention). CVD primary prevention included studies that enrolled patient populations without pre-existing CVD events, with or without CVD risk factors.41 Because our inclusion criteria emphasized different outcomes, we included a few studies51-53 in CVD primary prevention populations that could not be included in the companion review.41 For each outcome, we report our findings for specific groups of studies as follows: 1) the subset of 10 CVD primary prevention trials also reporting CVD outcomes for the companion review; 2) the entire set of included trials for this review, regardless of population; 3) cohort studies of harms (KQ 6 only); and 4) the most recent complementary IPD and/or study-level meta-analyses.

Outcome data for analyses were based on primary trial reporting with a few exceptions. We used the number of participants with an outcome as reported by meta-analyses if none of the study's publications provided these data (e.g., Seshasai and colleagues reported on cancer deaths in the Physician's Health Study [PHS], which was not provided in any of the trial's publications). When study-level data provided in the meta-analyses differed from those available in the study publications, we chose data from the meta-analysis. The only exception was the data identified by Rothwell and colleagues8 as cancer mortality in the Swedish Angina Pectoris Aspirin Trial (SAPAT), which the study classified as “participants stopping treatment prematurely due to malignant disease,” and we treated as cancer incidence.54

For factorial trials with additional randomization to vitamins/antioxidants or placebo, we combined groups when there was no evidence of interaction since evidence from a recent systematic review supports no role for vitamins in the incidence of CVD.55 In trials with additional randomization to a nonASA antithrombotic medication (alone or in combination with ASA), we did not include data from arms in which the nonASA antithrombotic medication was prescribed as specified a priori.

We calculated the average daily dose of ASA. For trials using alternate day dosing, we divided the alternate day dose in half to generate the daily dose. We used the following dosage definitions in our analysis: 1) high-dose ASA as any dose greater than 325 mg per day, 2) low-dose ASA as any dose of 325 mg per day or less, and 3) very low-dose ASA as any dose of 100 mg per day or less.

We chose the Mantel-Haenszel fixed effects model as the primary statistical analysis method for outcomes to calculate relative risks (RRs) because most of the outcomes were rare (i.e., generally <10% of participants experienced any given event).56 For events with a control group rate of less than 1 percent, we used Peto's odds ratio (OR) method.56 For those outcomes with control groups rates between 1 and 5 percent (i.e., cancer mortality and all-cause mortality), we conducted sensitivity analyses using the Peto OR (data not shown).56 We used a continuity correction factor of 0.5 if an arm reported no events. We assessed statistical heterogeneity using the I^2^ statistic.

When events were reported as per unit of person-years and the number of person-years in each group was reported, we calculated the number of events in each group, as necessary.

For estimating net outcome effects, we calculated absolute effects across various types of outcomes (all-cause mortality; fatal CVD; nonfatal stroke; nonfatal MI/coronary event; major CVD event; cancer incidence; cancer mortality; major GI bleeding; and intracranial hemorrhage, including hemorrhagic stroke) for the 10 CVD primary prevention trials only. These trials differed in length of followup, so we first estimated total person-years of observation for each trial arm by multiplying the number of persons in each arm by the average length of followup. We simulated the control group rate for each outcome by dividing the total number of events in the control group by the total person-years of observation (Appendix C). We selected the minimum, maximum, and median control group rate for each outcome, excluding zeros and outliers, from the set of CVD primary prevention trials. To calculate the expected event rate with 95% confidence intervals (CIs) after ASA intervention, we multiplied each of the control group rates by the RR, and the upper and lower 95% CIs were calculated from pooling results from the CVD primary prevention trials or the CVD primary prevention trials in which ASA doses were 100 mg per day or less. We subtracted these values from the control group rate to calculate the absolute risk reduction (ARR) and 95% confidence limits. For outcomes in which the 95% CI for the ARR excluded zero, we calculated the number needed to treat to harm with 95% CI by dividing 1 by the ARR or its 95% confidence limits.

We limited our analysis of GI bleeding to major GI bleeding, defined as those requiring transfusion, requiring hospitalization, leading to death, or defined as major by the study investigators. If a trial reported transfusions and death from GI bleeding separately, we added these events together. If a trial only reported deaths from GI bleeding, we used the reported number for major GI bleeding (we recognize that these event rates will appear low compared to other studies also reporting nonfatal major GI bleeding). If a trial reported GI bleeding without any mention of severity, we did not include it in our analysis. In our analysis of intracranial bleeding, we included those defined as intracerebral, subdural, or subarachnoid hemorrhage or as hemorrhagic stroke (fatal and nonfatal).

We conducted sensitivity analyses removing the high-dose and/or the low-dose arms; very low-dose (≤100 mg per day) is the minimum dosage that showed a beneficial effect on CVD.41 The only exception was the complete exclusion of the United Kingdom Transient Ischemic Attack (UK-TIA) trial from the high-dose sensitivity analysis for cancer mortality, as the data reported by Rothwell and colleagues combined the low-dose (300 mg per day) and high-dose (1,200 mg per day) ASA arms. For harms, we excluded all high-dose studies and arms from the sensitivity analyses. We conducted additional sensitivity analyses including the removal of alternate-day dosing regimens and studies with followup of less than 4 and 5 years.

We explored prespecified subgroups of interest, including age, sex, race/ethnicity, baseline cancer risk (family history and other cancer risk factors), comorbid conditions (diabetes, liver disease, ulcer disease, and previous GI bleeding), and concomitant medications (nonASA NSAIDs and selective serotonin reuptake inhibitors [SSRIs]). We specifically abstracted relevant outcomes by subgroup, if reported (e.g., by sex). We were unable to pool results due to the limited number of contributing studies.

We also created funnel plots to explore publication bias for all outcomes (data not shown).

## Expert Review and Public Comment

The research plan for this review was available for public comment from June 13, 2013 to July 10, 2013 and was largely focused on ASA use to prevent CRC. Based on public comment, the scope was expanded to examine all cancers. The final version of the research plan was posted in October 2013. The draft version of this report was reviewed by experts and federal partners. We compiled and addressed comments received as appropriate.

## USPSTF Involvement

This research was funded by AHRQ under a contract to support the USPSTF. We consulted four USPSTF liaisons at key points in the review, including the development of the research plan (i.e., KQs, analytic framework, and inclusion/exclusion criteria), as well as finalizing the review. An AHRQ Medical Officer provided project oversight, reviewed the draft and final versions of the review, and assisted in the public comment on the draft research plan. The USPSTF and AHRQ had no role in the study selection, quality assessment, or drafting of the review.