# Introduction

## Rationale for Review

The U.S. Preventive Services Task Force (USPSTF) issued recommendations on aspirin (acetylsalicylic acid [ASA]) for primary prevention of cardiovascular disease (CVD) in 2009 and for prevention of colorectal cancer (CRC) in 2007. While planning the updates of these two topics, a nomination for ASA to prevent cancers was submitted as a new topic for the USPSTF. The USPSTF commissioned this new topic to be conducted simultaneously with the other reviews. The USPSTF wanted this review to determine whether additional outcomes related to cancer prevention might modify net benefit estimates among those taking ASA for primary prevention of CVD. This perspective for the systematic review was developed for several important reasons. First, the net benefit for ASA in CVD primary prevention is controversial,1 as reflected in conflicting international guidelines.2 This controversy stems from increased risks of bleeding alongside relatively modest cardiovascular benefits. Illuminating any additional cancer prevention effects of ASA might clarify whether (and for whom) long-term, low-dose ASA for primary prevention may offer an overall health benefit, a topic important for both clinicians and patients.3 Second, most of the currently available research investigating the impact of low-dose ASA on cancer comes from trials of primary and secondary CVD prevention. Thus, the current evidence on primary prevention of cancer is most applicable to those taking it for primary or secondary CVD prevention. Finally, since the use of low-dose ASA in CVD secondary prevention is already recommended, while a better understanding of additional cancer benefits might be of interest, it would not change currently recommended treatments in those with pre-existing CVD.

## Prevalence and Burden of Cancer

Cancer is defined as malignant neoplasia marked by the uncontrolled growth of cells, often with invasion of healthy tissues locally or throughout the body.4 Cancers are classified by the type of tissue and the primary site in which the cancer originates (Table 1).

Table 1 Classification of Cancers

Stage | Definition
Carcinoma | A malignant neoplasm of epithelial origin or cancer of the internal of external lining of the body. Included adenocarcinomas (carcinoma of an organ or gland) and squamous cell carcinoma (originating in the squamous epithelium).
Sarcoma | A cancer originating in the supporting and connective tissue (e.g., bones)
Myeloma | A cancer originating in the plasma cells of bone marrow
Leukemia | Cancer of the bone marrow (white blood cells)
Lymphoma | Cancer of the glands or nodes of the lymphatic system
Blastoma | A cancer originating in embryonic tissues or organs

In 2014, there were an estimated 1.7 million new cases of cancer in the United States.5 While the incidence of cancer is roughly 460 per 100,000 persons, rates are declining for most cancer sites.5 The most common cancers expected to occur in men and women include lung, colorectal, prostate, and breast cancer (Table 2). The lifetime probability of being diagnosed with an invasive cancer is higher for men (45%) than for women (38%).6 Women have a slightly higher probability of developing cancer before the age of 60 years.6 The median age at diagnosis for all sites is 66 years.5 In 2011, there were approximately 13.4 million men and women who were living with a history of cancer,5 the most common sites being breast, colorectal, prostate, and skin cancer.5

Table 2 SEER Average Age-Adjusted Annual Incidence Rates per 100,000 Individuals of Selected Cancer Sites in the United States, 2007–2011

Site | Race/ethnicity | Male | Female
Any | White | 532.1 | 424.4
Any | Black | 600.9 | 398.8
Any | Asian/PI | 331.0 | 293.0
Any | AI/AN | 348.1 | 301.9
Any | Hispanic | 409.1 | 325.6
Prostate | White | 139.9
Prostate | Black | 223.9
Prostate | Asian/PI | 79.3
Prostate | AI/AN | 71.5
Prostate | Hispanic | 122.6
Breast | White | | 128.0
Breast | Black | | 122.8
Breast | Asian/PI | | 93.6
Breast | AI/AN | | 79.3
Breast | Hispanic | | 93.2
Pancreas | White | 14.0 | 10.7
Pancreas | Black | 17.2 | 14.2
Pancreas | Asian/PI | 10.7 | 8.9
Pancreas | AI/AN | 12.6 | 9.1
Pancreas | Hispanic | 12.3 | 10.3
Stomach | White | 9.2 | 4.5
Stomach | Black | 15.3 | 8.5
Stomach | Asian/PI | 14.9 | 9.0
Stomach | AI/AN | 12.9 | 7.3
Stomach | Hispanic | 14.9 | 8.4
Esophagus | White | 8.0 | 1.7
Esophagus | Black | 7.9 | 2.6
Esophagus | Asian/PI | 3.7 | 1.0
Esophagus | AI/AN | 4.8 | 1.9
Esophagus | Hispanic | 5.3 | 1.1
Lung and bronchus | White | 72.4 | 53.8
Lung and bronchus | Black | 93.0 | 51.2
Lung and bronchus | Asian/PI | 49.4 | 28.1
Lung and bronchus | AI/AN | 49.5 | 34.7
Lung and bronchus | Hispanic | 40.4 | 26.1

Abbreviations: AI = American Indian; AN = Alaskan Native; PI = Pacific Islander.

Cancer is the second leading cause of death in United States5 and accounts for one in four U.S. deaths.6 In 2014, an estimated 585,720 Americans died from cancer.5 The four most common cancer types (lung, colorectal, breast, and prostate cancer) account for nearly half of cancer deaths (Table 3). As with incidence, however, death rates are declining for most cancer sites due to improvements in early detection and treatment.5

Table 3 SEER Mortality Rates^*^ From Selected Cancer Sites in the United States, 2007–2011

Site | Race/ethnicity | Male | Female
Any | White | 213.1 | 149.8
Any | Black | 276.6 | 171.2
Any | Asian/PI | 132.4 | 92.1
Any | AI/AN | 191.0 | 139.0
Any | Hispanic | 152.1 | 101.2
Prostate | White | 21.2
Prostate | Black | 50.9
Prostate | Asian/PI | 10.1
Prostate | AI/AN | 20.7
Prostate | Hispanic | 19.2
Breast | White | | 22.1
Breast | Black | | 30.8
Breast | Asian/PI | | 11.5
Breast | AI/AN | | 15.5
Breast | Hispanic | | 14.8
Pancreas | White | 12.5 | 9.4
Pancreas | Black | 15.3 | 12.5
Pancreas | Asian/PI | 8.3 | 7.1
Pancreas | AI/AN | 10.1 | 8.6
Pancreas | Hispanic | 9.6 | 7.7
Stomach | White | 4.2 | 2.2
Stomach | Black | 9.8 | 4.7
Stomach | Asian/PI | 8.7 | 5.1
Stomach | AI/AN | 8.1 | 3.8
Stomach | Hispanic | 7.6 | 4.4
Esophagus | White | 7.8 | 1.6
Esophagus | Black | 7.7 | 2.1
Esophagus | Asian/PI | 3.1 | 0.8
Esophagus | AI/AN | 6.1 | 1.6
Esophagus | Hispanic | 4.3 | 0.8
Lung and bronchus | White | 63.2 | 40.4
Lung and bronchus | Black | 78.5 | 37.2
Lung and bronchus | Asian/PI | 35.5 | 18.4
Lung and bronchus | AI/AN | 49.6 | 33.1
Lung and bronchus | Hispanic | 31.3 | 14.1

* Average age-adjusted annual rates per 100,000 individuals.

Abbreviations: AI = American Indian; AN = Alaskan Native; PI = Pacific Islander

Table 4 Progression of Cancer Stages

Stage | Definition
0 | Carcinoma in situ (limited to surface cells)
I | Localized cancer to one part of the body
II | Early locally advanced cancer to one part of the body
III | Late locally advanced cancer to one part of the body
IV | Metastasized cancer, spread to other organs or throughout the body

Both mortality and incidence rates differ by race and ethnicity (Tables 2 and 3). For cancer, African American men have higher incidence and mortality rates than white men. African American women, on the other hand, have a lower incidence rate than white women, but a higher death rate. Cancer incidence and mortality rates are lower in other racial and ethnic groups than whites and African Americans for all cancer sites combined and for the four most common types—lung, colorectal, prostate, and breast. Cancer types related to infectious agents, such as those of the stomach, are generally higher in minority populations. While survival rates among racial and ethnic groups have improved in recent decades, African Americans remain less likely to survive cancer than whites.5

The financial impact of cancer on the patient, family, and society is significant. National expenditures on cancer care have been steadily increasing in the United States, despite decreases in the incidence of some cancers. These increased costs have been attributed to population changes, including aging (i.e., cancer incidence is greatest in the elderly), the development and use of more expensive targeted treatments as standard of care, and increased survival rates. In 2010, the national cost of cancer care was estimated to be $124.6 billion. By 2020, this cost is projected to increase by 27 percent to an estimated $157.8 billion.7 The largest cost increases are predicted for the continuing phase of care for prostate and breast cancer.7

## Aspirin in Cancer Prevention

The goal of primary prevention is to prevent a cancer from developing or delaying the development of a malignancy. Primary prevention of cancers could complement the secondary prevention approach of screening to detect and treat early cancers to improve health outcomes. Primary prevention can include leading a healthy lifestyle, avoiding carcinogens, and using chemopreventive agents to reduce the risk of developing a malignancy.

Recently, several individual patient data (IPD) meta-analyses by Rothwell and colleagues (2010, 2011, 2012) have reported reductions in cancer mortality and incidence with ASA use. These analyses have generated much interest in its potential use for primary prevention of cancer.8-10 ASA, like other nonsteroidal anti-inflammatory drugs (NSAIDs), acts by inhibiting cyclooxygenase enzymes (COX-1 and COX-2), which catalyze the production of a number of tissue-specific signaling lipids called prostanoids. Unlike other NSAIDs, ASA irreversibly inactivates the enzymes through selectively acetylating critical serine residues.11 In platelets, COX-1 catalyzes the production of thromboxane A2, which is important for platelet aggregation and subsequent blood clotting. Platelets are particularly susceptible to low doses of ASA because they lack a nucleus and cannot regenerate COX enzymes. Doses of ASA in the 75 to 100 mg per day range inhibit nearly all of platelet COX-1 activity and the production of thromboxane A2. COX-1 is also highly expressed in gastric epithelial cells, where it produces prostaglandin E2 and is important for protecting the gastric mucosa.

COX-2 is expressed in a variety of tissues and is induced in others during inflammation, wound healing, and neoplasia. Multiple lines of evidence have suggested that COX-2 is the main pathway through which ASA may reduce tumorigenesis. The transcription of the COX-2 gene has been found to be upregulated in human colorectal adenomas and CRC and to be associated with increased cell adhesion, phenotypic changes, resistance to apoptosis, and tumor angiogenesis.12 Additionally, observational data indicate that ASA may selectively reduce the risk of CRC among individuals who overexpress COX-2 compared to those who do not.13 Higher doses of ASA (>2,000 mg daily), delivered through repeated dosing (i.e., three or four times per day), however, are needed to sustain inhibition of COX-2 activity in nucleated cells.11,12 Lower doses of daily ASA could potentially reduce tumor development through downstream effects on COX-1 platelet inhibition, and some lines of evidence support this mechanism. Activated platelets have induced COX-2 activity in monocytes. In addition, deletion of either COX1 or COX2 genes have reduced intestinal polyp formation in a mouse model.11 Finally, enhanced thromboxane A2 production in a murine colon adenocarcinoma cell line promoted tumor angiogenesis and the development of tumor metastases.12

ASA for the prevention of cancer has the potential to change current practice. This is particularly true when one considers ASA's effects on CVD prevention in addition to cancer prevention. Indeed, much recent interest in the impact of ASA as a cancer chemopreventive agent has been to determine whether the net benefit (CVD plus cancer disease events prevented balanced against bleeding events caused) might broaden the population in whom regular low-dose ASA use could be beneficial.14

## Harms of Aspirin Use

While ASA is widely regarded as a safe over-the-counter medication, its antiplatelet actions lead to an increased risk of bleeding. The level of bleeding risk depends on the dosage and duration of ASA, concurrent use of other medications, and patient susceptibility.15-17 The most common serious harm is upper gastrointestinal (GI) bleeding, which has been linked to even low-dose ASA use.18 Other serious bleeding events, including hemorrhagic stroke, have also been associated with ASA use.16 While short-term ASA use (for pain or fever) is associated with minor GI events (including abdominal pain, dyspepsia, or nausea and vomiting19), it is rarely associated with serious GI events. Long-term, regular use of ASA has been linked to major bleeding events, although the duration of risk associated with long-term use has not been clearly established.

Recent observational studies have suggested a possible increase in age-related macular degeneration (ARMD) with regular ASA use in older adults,20,21 and potential as well as established harms are important to consider for a chemopreventive agent.

Absolute contraindications of ASA use include individuals with active peptic ulcer, ASA allergy or intolerance, bleeding disorders or history of recent GI/intracranial bleeding, renal failure, severe liver disease, and thrombocytopenia. Relative contraindications include individuals younger than age 21 years (contraindicated in pediatric patients with viral illness) and those with concurrent use of anticoagulation therapy, concurrent use of NSAIDs, and poorly controlled hypertension, as it may increase the risk of intracranial bleeding.22-24 The risks of ASA use increases with age and, as such, ASA use is cautioned in older adults.

## Current Clinical Practice in the United States

Nearly 40 percent of the U.S. population older than age 50 years regularly uses ASA, primarily for the primary and secondary prevention of CVD.25-28 ASA is not routinely prescribed as a primary prevention strategy for cancer and many organizations recommend against its use to prevent specific noncolorectal cancers (Table 5). Many health care organizations have focused on identifying CVD primary prevention patients at sufficiently high CVD risk to outweigh bleeding harms. As such, ASA use is recommended for use in specified populations and dosing regimens to prevent CVD.29-33 More recent recommendations, however, do not recommend the use of ASA in CVD primary prevention as a population strategy. Instead, these recommendations focus more explicitly on the better articulation of individualized bleeding risks when considering ASA for primary prevention.34-36

Table 5 Recommendations of ASA Use to Prevent Cancer (Excluding Colorectal Cancer) From Other Organizations

Organization, Year | Recommendation
American College of Chest Physicians, 2007^119^ | Recommends against the use of ASA in the primary, secondary or tertiary prevention of lung cancer in individuals who are at risk for lung cancer and in patients with a history of lung cancer.
American Gastroenterological Association, 2011^120^ | Recommends against the use of ASA solely to prevent esophageal adenocarcinoma.
British Society of Gastroenterology, 2011^121^ | Unable to assert a recommendation that ASA could be chemopreventive for gastric cancer until ongoing studies completed.
European Society of Cardiology, 2012^30^ | Recommends against the use of ASA in individuals without cardiovascular or cerebrovascular disease due to risk of major bleeding; cancer risk was not considered in this recommendation.
International Conference on Cancer Prevention, 2012^122^ | Insufficient evidence on the risk-benefit profile to definitively recommend ASA use in the prevention of cancer.

Abbreviations: ASA = acetylsalicylic acid

## Previous Related USPSTF Recommendations

The USPSTF has made no previous recommendations on the use of ASA to prevent cancers other than CRC. In 2007, the USPSTF recommended against the routine use of ASA and NSAIDs to prevent CRC in individuals at average risk for CRC (D recommendation).37 The USPSTF concluded that the harms outweigh the benefits of treatment. This recommendation was based on good evidence that ASA increases GI bleeding and fair evidence that it increases the incidence of hemorrhagic strokes. Fair- to good-quality evidence showed ASA may be associated with a reduction in CRC.38 In 2009, the USPSTF recommended the use of ASA for men ages 45 to 79 years when the potential benefit due to a reduction in myocardial infarctions (MIs) outweighs the potential harms due to an increase in GI hemorrhage (A recommendation).31 The USPSTF recommended the use of ASA for women ages 55 to 79 years when the potential benefit of a reduction in ischemic strokes outweighs the potential harm of an increase in GI hemorrhage (A recommendation). The USPSTF concluded the evidence was insufficient to assess the balance of benefits and harms of ASA for CVD prevention in men and women age 80 years and older (I statement). The USPSTF recommended against the use of ASA for stroke prevention in women younger than age 55 years and for MI prevention in men younger than age 45 years (D recommendation).39

The Agency for Healthcare Research and Quality (AHRQ) commissioned three separate, but related, systematic evidence reviews on the use of ASA to prevent CVD, CRC, and cancer in adults.40-42 The USPSTF will use these reviews, also considering a separate decision model,43 to make evidence-based recommendations about the use of ASA to prevent CVD and/or cancer in adults.