# Ongoing Studies

We identified six relevant ongoing or recently completed studies through searches of clinicaltrials.gov, the Current Controlled Trials (http://www.controlled-trials.com), Australian New Zealand Clinical Trials Registry (http://www.anzctr.org.au), and the World Health Organization's International Clinical Trials Registry Platform (http://www.who.int/ictrp/en). Additional individual patient data meta-analyses by the Non-Vascular Outcomes (NOVA) Collaboration (Rothwell and colleagues) are currently underway incorporating data from the WHS and PHS as well as evaluating long-term cancer incidence and mortality.

Study | Aim | Population | Intervention | Control | Relevant Outcomes | Status
A Study of Cardiovascular Event iN Diabetes (ASCEND)145 | Determine whether ASA prevent serious vascular events | Diabetics aged ≥ 40 years | 100 mg ASA with or without 1 gram omega-3-Ethyl esters | Placebo with or without 1 gram omega-3-Ethyl esters | Cerebral hemorrhage | Anticipated completion date, December 2016
Aspirin and simvastatin Combination for Cardiovascular Events Prevent Trial in Diabetes (ACCEPT-D)118 | Study the efficacy of low-dose ASA in the prevention of CV events | Diabetics aged ≥ 50 years without clinically manifest vascular disease and treated with simvastatin (n=5,170) | 100 mg ASA | Simvastatin alone | Total and cause-specific mortality, major hemorrhagic episodes | Anticipated completion date, December 2013
ASPirin in Reducing Events in the Elderly (ASPREE)146,147 | Assess whether daily ASA extends the duration of disability- and dementia-free life | Healthy older adults aged ≥ 65 years (n=19,000) | 100 mg enteric-coated ASA for 5 years | Placebo | All-cause mortality, fatal and non-fatal cancer, clinically significant bleeding | Anticipated completion date, August 2016
Aspirin to Reduce the Risk of Initial Vascular Events (ARRIVE)148 | Assess the efficacy of ASA | Older adults with moderate risk CVD (n=12,590) | Enteric-coated ASA for 5 years | Placebo | All-cause mortality, treatment-emergent AEs | Anticipated completion date, May 2014
IMProving Adherence using Combination Therapy (IMPACT)149 | Assess whether polypill improves adherences and CVD risk factors | Patients at high-risk of CVD in primary care settings (n=600) | Polypill containing 75 mg ASA, 40 mg simvastatin, 10 mg lisinopril and either 12.5 mg hydrochlorothiazide or 50 mg atenolol for 12 months | Usual care | Serious AEs | Ongoing
Japanese Primary Prevention Project (JPPP)150 | Evaluate the primary prevention of low-dose ASA | Older adults aged 60-85 years with hypertension, dyslipidemia, or DM (n-14,466) | 100 mg enteric-coated ASA for 4 years | No ASA | All-cause mortality, extracranial hemorrhage | Recently published

Abbreviations: AE = adverse event; ASA = aceylysalycyclic acid; CV = cardiovascular; CVD = cardiovascular disease; DM = diabetes mellitus; mg = milligram(s); PAH = pulmonary arterial hypertension