# Subgroup Results

Appendix F Table 1 Cancer Mortality by Subgroup (KQ 1)

Appendix F Table 2 All-Cause Mortality by Subgroup (KQ 1)

Appendix F Table 3 Cancer Incidence by Subgroup (KQ 2)