# Evidence Tables

Appendix E Table 1 Study Design Characteristics of Included Studies

Appendix E Table 2 Baseline Demographics of Participants in Included Studies

Appendix E Table 3 Intervention Characteristics of Included Studies

Appendix E Table 4 Results of Included Studies, Total Cancer Mortality

Appendix E Table 5 Results of Included Studies, All-Cause Mortality

Appendix E Table 6 Results of Included Studies, Cancer Incidence

Appendix E Table 7 Results of Included Studies, GI Bleeding

Appendix E Table 8 Results of Included Studies, Intracranial Bleeding, Including Hemorrhagic Stroke

Appendix E Table 9 Results of Included Studies, Ulcers

Appendix E Table 10 Results of Included Studies, ARMD