# Study Details

## Description of Included Trials

Most of the 30 included RCTs51-54,57-60,62-82,85 evaluated low-dose ASA interventions (≤ 325 mg/day) in the range of 50 to 325 mg per day. Seven trials evaluated high doses of ASA (> 325 mg/day) that ranged from 500 to 1,200 mg per day51,59,64,65,71,72,75,77 and four trials evaluated more than one level of ASA dose.65,70,77,82 ASA was prescribed once per day in most of the interventions. The two largest trials—the Women's Health Study (WHS)60 and the Physicians Health Study (PHS)73—prescribed ASA every other day. A few studies also delivered ASA two62,65,75 or three51,59,71 times per day, but most of these were the high (>325 mg/day) dose interventions. While ASA was most commonly delivered in tablet form (with enteric or other coating in 10 trials), two trials evaluated soluble effervescent forms (or offered it as an option to the tablet form).72,82 Twelve trials did not describe the formulation of ASA.51,54,59,62,63,67,75-78,80,81

Eight of the 30 included trials were conducted in the United States.59,60,64,71,73,75-77 These trials included 76 to 97 percent white participants, when described.60,64,71,75-77 The remaining trials were conducted in Europe,51,54,57,61-63,66,68,69,72,74,78,80,82 Canada,79 Australia,52,53 or Japan.70,81 Two trials were conducted in multiple countries.58,67 Non-U.S. trials generally did not provide specific information about race or ethnicity of participants. Four of the included trials59,69,72,73 were conducted exclusively among male participants and one trial was conducted among women.60 The remaining trials included 11 to 72 percent females and included participants with a mean or median age at enrollment ranged from 47 to 76 years. Two trials (both conducted in Australia) restricted enrollment to patients aged 70 years or older.52,53

Many of the trials used a factorial design to evaluate at least one non-ASA intervention in addition to ASA such as vitamin E,60,61 folic acid,68,77 beta-carotene,60,73 non-ASA antithrombotic agents,62,69 or others.57,64,67 For the two trials that evaluated a non-ASA antithrombotic agent as the second intervention (TPT and the European Stroke Prevention study [ESPS-2]),62,69 we also excluded data from the ASA and no-ASA arms in which the antithrombotic agent were also prescribed.

Most of the included trials used computer-generated randomization or a random number table to assign treatments. Seven reported using block randomization.63,64,74,76,79,81,82 Three trials did not clearly describe their randomization method (including two rated good quality59,71) and three did not report their method of randomization (all fair-quality trials).52,54,75 A majority of the trials reported adequate allocation concealment through central allocation and a few57,66,68,69 reported additional measures such as sequentially-numbered drug containers of identical appearance. It was unclear if 10 of the trials had adequate allocation concealment, however, including three rated as good quality.59,76,77

In the majority of trials, participants in ASA and control groups appeared to be similar at baseline for age, gender, and smoking status. Some trials also reported that BMI was similar between groups (WHS, AFPPS, the Warfarin and Apsirn study [WARFASA], the ASPirin in Reducing Events in the Elderly [ASPREE] study, and PHS).53,57,60,69,73,77,78 Only a few trials, however, reported that groups were similar at baseline for levels of physical activity (WHS, PHS),60,73 family history of cancer (WHS, APACC, ukCAP),60,68,82 race (WHS, ETDRS, WARFASA, and AFPPS),60,64,77,78 or markers of socioeconomic status (WHS and AAA).60,66 Most included trials did not report these characteristics. Two trials (the Swedish Aspirin Low-Dose Trial [SALT] and ukCAP)68,74 did not report results of their statistical significance testing for differences in baseline characteristics between groups. One trial (ASPREE) did not report information comparing age, gender, smoking, or other important characteristics between groups at baseline, however, this study is ongoing.53

Several trials reported differences in some baseline characteristics. In Asymptomatic Cervical Bruit Study (ACBS), the ASA group appeared to have a lower rate of current smoking (33% vs. 41%) and diabetes (19% vs. 28%; p-values NR).79 In APACC, patients in the ASA group were more likely to have had advanced colon adenomas (79% vs. 68%).82 Small, but statistically significant differences, were also reported between groups for Coronary Drug Project Aspirin Study (CDPA; physical activity and cigarette smoking),59 JPAD (past smoking),70 Persantine-Aspirin Reinfarction Study (PARIS; pulse rate, antiarrhythmic medications, beta-blockers, and electrocardiogram patterns),71 and Aspirin Myocardial Infarction Study (AMIS; history of heart failure, angina, arrhythmias, CVD medications, and heart rate).75 While most of the trials adjusted results for these baseline differences, we use the actual number of persons or events reported in our meta-analyses. These numbers are not adjusted values.

As most of the included trials were designed for CVD primary prevention, methods for ascertaining relevant non-CVD were generally less clearly reported. Of our included outcomes, ascertainment of total mortality and intracranial hemorrhage were the best described across these trials. Approximately half of these trials specified total mortality as either a primary59,62,64,71,75 or secondary study outcome.54,57,58,61,63,66,70,73,76,78,80 Intracranial bleeding was often part of the set of primary CVD outcomes. Four other trials also designated bleeding in general as a primary or secondary outcome.53,58,76,78 In contrast, WHS and PHS were the only trials that specified total cancer as a primary or secondary outcome.60,73 Trials that focused on adenoma prevention may have reported total cancers,68,77 without describing how they ascertained non-colorectal cancer. In many cases, trials did not clearly report whether they continued to follow patients for any outcomes after primary endpoints were reached.

All included trials except four reported using double blinding. While many of these trials stated that ascertainment of primary outcomes were blinded, they were unclear about whether or not the assessment of non-primary outcomes was also blinded. In particular, few trials reported that blinding applied to ascertainment of nonfatal harms and only one trial60 reported that it applied non-fatal cancers. Among four trials that were open-label,61,70,72,81 only one specified that ascertainment of total mortality and adverse events were blinded.70 Another trial specified that CVD outcome ascertainment was blinded.81

While cancer incidence and non-intracranial hemorrhage harms were not the focus of most trials, the approach to ascertaining outcomes was the similar for patients in both ASA and no ASA groups across trials. Studies generally followed up with patients with either questionnaire and/or clinic visits at regularly scheduled intervals. Studies often reported that medical records were reviewed for primary outcomes (often without specify if they were reviewed for other non-fatal outcomes). Several studies stated that CT or MRI imaging or necropsy were used to diagnose stroke.58,61,65,73,74,79-81 Only two trials, however, reported that imaging was conducted for most or all cases of intracranial hemorrhage.74,81

Three of the included trials (rated as good quality for mortality or cancer incidence) used less stringent or unclear methods for ascertaining harms other than intracranial hemorrhage60,73,77 or ARMD60,73 For WHS, GI bleeding was self-reported and not confirmed by medical record review.123 We included bleeding harms from the post-trial assessment as fair-quality. We excluded long-term data at the 18-year time point due to poor quality because data on GI bleeding were collected “intermittently”, by self-report only, and without followup questionnaire as they were during the active trial period. The other two trials reported minimal information about how other harms were ascertained and we rated them as fair-quality for harms other than intracranial hemorrhage and ARMD.73,77 One trial did not report how non-colorectal cancers were ascertained and, because of this, we rated it as fair-quality for cancer incidence.77

Included trials generally followed an intention-to-treat approach in that patients were analyzed in the group to which they were assigned, regardless of compliance. Approximately half also specified that they attempted to followup and include all patients as they were originally allocated even after they discontinued treatment. Several to poor-quality trials censored patients from further analysis if they became noncompliant with treatment (Appendix B).

Completeness of followup for vital status was 99 to 100 percent in all trials that we rated as good quality and among eight trials that we rated as fair quality.54,57,61,63,65,72,75,79 For the remaining fair-quality trials, followup for vital status was higher than 90 percent, except for one trial,81 in which only 79 percent had followup for vital status. While completeness of ascertaining non-fatal outcomes was slightly lower for some trials, it was still greater than 90 percent for two trials61,71 and was 97 to 99 percent for the other three trials.59,60,73 The trials that had less than 99 percent followup dealt with missing data by carrying forward the status from the last time of contact or70 excluding patients with unknown status.51,67 Several trials did not report how they handled these missing data.53,78,80,82

The trials were generally all designed to assess differences in length of time-to-event. They enrolled participants and allocated them randomly to ASA and no ASA on an ongoing basis. The length of time that a patient was prescribed their intervention and the observation period varied depending on when the participant was enrolled. In most of the individual trial reports, the primary events are analyzed by creating survival curves and life table methods. In contrast, cancer, bleeding, and other adverse events are simply reported as the number of events out of the number randomized to the group. These trials did not necessarily report the total person-years of exposure for those in each group. Very few studies reported rates of adverse events that occurred over a constant period of time for all participants.

## Description of Included Individual Patient Data Meta-Analyses

We identified three individual patient data meta analyses8,10,87 and one study-level meta-analysis informed by individual patient data meta analysis44 provided data complementary to that from our primary studies.

In two separate fair-quality individual patient data meta analyses (published in 2011 and 2012), Rothwell and colleagues reported multiple trial- and individual-patient-level meta-analyses of trials assessing the effect of daily ASA versus no ASA on multiple outcomes including cancer mortality, all-cause mortality, and cancer incidence.8,10 Analyses in the two publications were different in terms of the studies focusing on CVD primary prevention or not, doses of ASA, minimum length of scheduled duration of treatment, and whether other antiplatelets or anticoagulant treatments could be co-administered. All of the analyses were restricted to trials of daily ASA, thus excluding WHS and PHS in which ASA was dosed every other day. The authors did not report any dual review process or assessment of methodological quality of individual trials.

In the 2011 publication, Rothwell and colleagues8 reported an individual patient data meta-analysis of cancer mortality outcomes from the seven trials (BMD, UK-TIA, ETDRS, TPT, JPAD, POPADAD, AAA) in which the mean or median scheduled duration of daily ASA treatment was at least 4 years, with the range extending beyond 5 years (all regardless of adherence), and for which relevant individual-level data for cancer mortality were available from the original trialists.57,64-66,69,70,72 This publication included trials in which the ASA intervention was administered either alone or with another antiplatelet or antithrombotic agent if the other agent was administered the same way in ASA and no ASA groups. The authors made no distinction between trials focusing on primary and secondary prevention of CVD or dose of ASA. Additionally, the authors used the designation of death due to cancer that was made by the original trial's investigators in most cases. Using the individual-level data, Rothwell and colleagues estimated the cumulative effect of ASA on time to cancer death with Kaplan-Meier curves and log-rank tests stratified by trial and calculated hazard ratios from a Cox proportional hazards model, also stratified by trial. Analyses were intention-to-treat based on how patients were allocated in the original trials. They conducted stratified analyses looking at cancer subtypes, outcomes occurring during the first five years of treatment or afterwards. Analyses are not adjusted for other baseline characteristics.

In the same 2011 publication, Rothwell and colleagues8 also reported long-term post-trial followup results on cancer mortality that were available for three of seven trials included in the main individual patient data analysis (TPT, UK-TIA, and BMD).65,69,72 Post-trial followup had occurred using data from national death certificate and cancer registration systems. Fatal cancers were defined as those for which cancer was recorded as the primary underlying cause of death as described on the death certificate. Investigators blinded to treatment allocation coded deaths using ICD 9 or 10. Rothwell and colleagues assessed trials for underlying heterogeneity and then pooled results for analyses on the effect of allocation to ASA on risk of 20-year cancer mortality, also on an intention-to-treat basis.

In a 2012 publication, Rothwell and colleagues10 conducted trial- and individual-patient-level meta-analysis of 51 trials of ASA versus no ASA, with mean or median scheduled duration of treatment of ≥ 90 days for which at least one non-vascular death was reported. They excluded trials targeting secondary cancer or individuals with colonic polyps and those in which non-ASA antiplatelet agents were administered in either group. This publication allowed trials with co-administration of anticoagulation agents. Data on vascular and non-vascular deaths during trials were abstracted from main and subsequent trial reports or from previous meta-analyses.87 For cancer deaths, the authors obtained individual patient data from trialists, if available, and otherwise used data on cancer deaths from published reports. Analyses were intention-to-treat based on how patients were allocated in the original trials. For analyses of abstracted data on non-vascular death from 51 trials, they calculated pooled OR by fixed effects meta-analyses (Mantel-Haenszel-Peto method). Using the individual patient cancer mortality data, the authors stratified analyses by years from randomization to death (less than 3, 3 to 4.9, and ≥5 years), dose of ASA (less than 300 vs. ≥ 300 mg), and site of primary cancer.

For five of the six trials assessing daily ASA less than 300 mg/day in primary prevention of vascular events,57,61,66,67,69 they also obtained individual patient data for all cancers (fatal and non-fatal) that occurred during the trials. They also assessed age, sex, and smoking status at baseline, major vascular events, major extracranial bleeds, and date and cause of all deaths during the trial. A sixth trial of low-dose ASA in primary prevention70 used fatal cancers in their analyses. The author's conducted a meta-analysis of cancer incidence stratifying results by time to diagnosis or first notification (less than 3, 3 to 4.9, and ≥ 5 years). They then pooled individual patient data and generated Kaplan-Meier curves for time to diagnosis of first notification of cancer. They assessed the effect of treatment on cancer incidence using a Cox model with time expressed as a continuous variable. To assess the time course of risks and benefits, they conducted meta-analyses evaluating incident cancer, major vascular events (including intracranial bleeds), major extracranial bleeds (fatal or requiring blood transfusion); the same analyses stratified by period of followup; pooled analyses of individual patient data (from a subset of six trials) to calculate the absolute number of events prevented per 1,000 patients per year for incident cancer, major vascular events, and major extracranial bleeds stratified by period of followup; pooled analyses on two composite outcomes including major vascular events, incident cancer, and extracranial bleeds with one analysis restricted to only the fatal extracranial bleeds.

A fair-to-good-quality individual patient data meta-analysis conducted by the Antithombotic Trialists' (ATT) Collaboration evaluated beneficial CVD and harmful bleeding outcomes in six trials of ASA in CVD primary prevention populations (n= 95,000 with 3,554 serious vascular events) and 16 trials of ASA in CVD secondary prevention (n=17,000 with 3,306 serious vascular events).87 The primary prevention trials included at least 1,000 non-diabetic participants and 2 years of scheduled treatment with ASA and no other antiplatelet drugs in either group (BDS, PHS, TPT, HOT, PPP, WHS).60,61,67,69,72,73 Dosages ranged from 100 mg every other day to 500 mg daily. Only 2 percent of the population was in a predicted 5-year CHD risk category of 10 percent or more. Secondary prevention trials represented individuals with previous stroke/TIA (10 trials) or MI (six trials). Serious vascular events were defined as MI, stroke, death from a vascular cause, and for secondary prevention trials only death from an unknown cause. Major coronary events included fatal and non-fatal events, while stroke included fatal and non-fatal hemorrhagic, ischemic, and unknown types. Extracranial bleeds were primary GI and usually required transfusion or were fatal.

A fair- quality study-level meta-analysis by Seshasai and colleagues analyzed nine placebo-controlled trials (with at least 1,000 participants and 1-year of followup) of ASA use (50 to 500 mg per day) for CVD primary prevention on CVD, nonvascular outcomes, or death.44 This MA included the same trials as our companion systematic review,41 except for one trial conducted in diabetics.64 It also included all six trials in the individual patient data meta-analysis by the ATT Collaboration87 and all six trials in individual patient data meta-analysis by Rothwell and colleagues,10 although these two analyses overlapped for three trials (HOT, TPT, PPP) only.61,67,69 Primary trial-reported data were supplemented by extracting information from another individual patient data meta-analysis on non-vascular outcomes,8 by subsequent trial reporting and contacting authors for unpublished cancer data for two trials (HOT, PHS).67,73 Thus, the data represented here are largely those already represented in previous individual patient data meta-analysis, but including additional published (or unpublished) outcomes for three trials and defining and reported on an “non-trivial bleeding” outcome that included fatal bleeding from any site, cerebrovascular or retinal bleeding, bleeding from a hollow viscus, bleeding requiring hospitalization or transfusion, or study-defined major bleeding. Event rates were approximated by dividing total numbers of events by mean (or median) followup time period and approximate control group event rates were pooled to estimate baseline risks. These estimates were used to construct number needed to harm (NNH) and number needed to treat (NNT) estimates for all statistically meaningful outcomes (only non-fatal MI, total CVD events, non-trivial bleeding and total bleeding). Study-level characteristics were explored through meta-regression examining the impact of period of publication (before or after 2000), study sample size (5,000 or above), event rates (at least 100 for nonfatal MI, at least 500 for total CVD events or non-trivial bleeds), average daily ASA dose, schedule of treatment on non-fatal MI, total CVD events, and non-trivial bleeding. The reviewers reported independent data abstraction with resolution by consensus, quality rating by at least one individual for included trials, and details of statistical analyses. The reviewers did not report on reliability of the non-trivial bleeding categorization, on study screening, or on dual quality assessment.