# Control Group Rates

Number of Events in the Control Group (per 1,000 Person-Years)

Study name | Average duration, years | N, CG | Total person-years, CG | Intracranial Hemorrhage including Hemorrhagic Stroke | Nontrivial Bleeding | GI Bleeding / Extracranial Bleeding | Cancer Incidence | Cancer Mortality | All-cause Mortality
HOT | 3.8 | 9391 | 35,685.8 | 15 (0.42) | 78 (2.19) | 37 (1.04) | 311 (8.72) | 105 (2.94) | 305 (8.55)
PPP | 3.6 | 2269 | 8,168.4 | 3 (0.37) | 9 (1.10) | NR | 89 (10.90) | 29 (3.55) | 78 (9.55)
POPADAD | 6.7 | 638 | 4,274.6 | 3 (0.70) | 34 (7.95) | NR | 60 (14.04) | 31 (7.25) | 101 (23.63)
AAA | 8.2 | 1675 | 13,735.0 | 7 (0.51) | 24 (1.75) | 8 (0.58) | 194 (14.12) | 90 (6.55) | 186 (13.54)
WHS | 10.1 | 19942 | 201,414.2 | 41 (0.20) | 3671 (18.23) | 94 (0.47) | 1427 (7.09) | 299 (1.49) | 642 (3.19)
JPAD | 4.37 | 1277 | 5,580.5 | 7 (1.25) | 7 (1.25) | 0 (0) | NR | 19 (3.41) | 38 (6.81)
BMD | 6 | 1710 | 10,260.0 | 6 (0.58) | 2 (0.19) | 3 (0.29) | 58 (5.65) | 47 (4.58) | 151 (14.72)
PHS | 5 | 11034 | 55,170.0 | 12 (0.22) | 708 (12.28) | 28 (0.51) | NR | 68 (1.23) | 227 (4.12)
TPT | 6.8 | 1272 | 8,649.6 | 2 (0.23) | 179 (20.70) | 2 (0.23) | NR | 51 (5.90) | 110 (12.72)
ETDRS | 5 | 1855 | 9,275.0 | NR | NR | NR | NR | 14 (1.51) | 366 (39.46)

Note: The minimum, median and maximum control group rates for each outcome were calculated excluding zeros and outliers

Abbreviations: CG = control group; GI = gastrointestinal; NR = not reported