# Excluded Studies

Code | Reason for Exclusion
E1 | Wrong aim or condition
E2 | Wrong population
E2a | > 20% adults aged < 40 years at BL or mean age < 40 years
E3 | Wrong intervention
E3a | Exposure to ASA < 12 months
E3b | Incorrect ASA dosage
E3c | Co-administration with chemopreventive agent
E3d | Co-administration with an anti-thrombotic agent (> 5%)
E4 | Comparative effectiveness
E5 | No relevant outcomes
E5a | Primary of secondary prevention of CRC cancer with no relevant outcomes
E5b | Primary prevention of CVD with no relevant outcomes
E6 | Wrong study design
E7 | Wrong setting
E8 | Non High-HDI country
E9 | Non-English
E10 | Poor quality
E11 | Unable to locate

1 Aspirin in coronary heart disease. The Coronary Drug Project Research Group. J Chronic Dis. Oct. 1976;29(10):625-42. KQ2E5. [pmid: 789390].
2 A randomized trial of aspirin and sulfinpyrazone in threatened stroke. The Canadian Cooperative Study Group. N Engl J Med. Jul. 13. 1978;299(2):53-9. KQ1E10, KQ2E10, KQ6E10. [pmid: 351394].
3 Persantine and aspirin in coronary heart disease. The Persantine-Aspirin Reinfarction Study Research Group. Circulation. Sep. 1980;62(3):449-61. KQ2E5b. [pmid: 7398002].
4 Persantine-aspirin reinfarction study. Design, methods and baseline results. By the persantine-aspirin reinfarction study research group. Circulation. Sep. 1980;62(3 Pt 2):II1-42. KQ2E5b. [pmid: 7408140].
5 Aspirin in coronary heart disease. The Coronary Drug Project Research Group. Circulation. Dec. 1980;62(6 Pt 2):V59-V62. KQ2E5. [pmid: 7002353].
6 Preliminary report: findings from the aspirin component of the ongoing Physicians' Health Study. N Engl J Med. 1988;318(4):262-4. KQ2E5. [pmid: 3275899].
7 Final report on the aspirin component of the ongoing Physicians' Health Study. N Engl J Med. Jul. 20. 1989;321(3):129-35. KQ2E5b. [pmid: 2664509].
8 Effect of aspirin alone and aspirin plus dipyridamole in early diabetic retinopathy. A multicenter randomized controlled clinical trial. The DAMAD Study Group. Diabetes. Apr. 1989;38(4):491-8. KQ2E5. [pmid: 2647556].
9 Risk of myocardial infarction and death during treatment with low dose aspirin and intravenous heparin in men with unstable coronary artery disease. The RISC Group. Lancet. Oct. 6. 1990;336(8719):827-30. KQ1E3a, KQ2E3a, KQ6E3a. [pmid: 1976875].
10 Preliminary report of the Stroke Prevention in Atrial Fibrillation Study. N Engl J Med. Mar. 22. 1990;322(12):863-8. KQ2E5. [pmid: 2407959].
11 Design of a multicenter randomized trial for the Stroke Prevention in Atrial Fibrillation Study. The Stroke Prevention in Atrial Fibrillation Investigators. Stroke. Apr. 1990;21(4):538-45. KQ2E5. [pmid: 2183405].
12 Stroke Prevention in Atrial Fibrillation Study. Final results. Circulation. Aug. 1991;84(2):527-39. KQ2E5. [pmid: 1860198].
13 Effects of aspirin treatment on diabetic retinopathy. Ophthalmology. 1991;98(Suppl):757-65. KQ2E5. [pmid: 2062511].
14 Early Treatment Diabetic Retinopathy Study design and baseline patient characteristics. ETDRS report number 7. Ophthalmology. May. 1991;98(5 Suppl):741-56. KQ2E5. [pmid: 2062510].
15 A comparison of two doses of aspirin (30 mg vs. 283 mg a day) in patients after a transient ischemic attack or minor ischemic stroke. The Dutch TIA Trial Study Group. N Engl J Med. Oct. 31. 1991;325(18):1261-6. KQ1E4, KQ2E4, KQ6E4. [pmid: 1922220].
16 Aspirin effects on mortality and morbidity in patients with diabetes mellitus. Early treatment Diabetic Retinopathy Study report 12. ETDRS Investigators. JAMA. 1992;268(10):1292-300. KQ2E5. [pmid: 1507375].
17 Secondary prevention in non-rheumatic atrial fibrillation after transient ischaemic attack or minor stroke. EAFT (European Atrial Fibrillation Trial) Study Group. Lancet. Nov. 20. 1993;342(8882):1255-62. KQ2E5. [pmid: 7901582].
18 Low-dose aspirin in polycythaemia vera: a pilot study. Gruppo Italiano Studio Policitemia (GISP). Br J Haematol. May. 1997;97(2):453-6. KQ1E2, KQ2E2, KQ6E2. [pmid: 9163613].
19 Thrombosis Prevention Trial: randomised trial of low-intensity oral anticoagulation with warfarin and low-dose aspirin in the primary prevention of ischaemic heart disease in men at increased risk. The Lancet. Jan. 24. 1998;351(9098):233-41. KQ2E5b. [pmid: 9457092].
20 The WASH study (Warfarin/Aspirin Study in Heart failure) rationale, design and end-points. Eur J Heart Fail. Mar. 1999;1(1):95-9. KQ1E10, KQ2E10, KQ6E10. [pmid: 10937986].
21 Summaries for patients. Occurrence of venous thromboembolism in women taking low-dose aspirin. Ann Intern Med. Oct. 16. 2007;147(8):I34. KQ1E6, KQ2E6, KQ6E6. [pmid: 17938386].
22 Daily aspirin usage associated with lower cancer mortality. J Natl Cancer Inst. 2012. Aug. 10. KQ1E6, KQ2E6, KQ6E6. [pmid: 22888141].
23 Study design of ASPirin in Reducing Events in the Elderly (ASPREE): A randomized, controlled trial. Contemp Clin Trials. Oct. 7. 2013;36(2):555-64. KQ1E5, KQ2E5, KQ6E5. [pmid: 24113028].
24 Abraham NS, Hartman C, Castillo D, et al. Effectiveness of national provider prescription of PPI gastroprotection among elderly NSAID users. American Journal of Gastroenterology. Feb. 2008;103(2):323-32. KQ1E6, KQ2E6, KQ6E3. [pmid: 18289200].
25 Abraham NS, Hartman C, Richardson P, et al. Risk of lower and upper gastrointestinal bleeding, transfusions, and hospitalizations with complex antithrombotic therapy in elderly patients. Circulation. Oct. 22. 2013;128(17):1869-77. KQ1E6, KQ2E6, KQ6E3b. [pmid: 24025594].
26 Abu DH, Eloubeidi M, Tamim H, et al. Opposing effects of aspirin and anticoagulants on morbidity and mortality in patients with upper gastrointestinal bleeding. Journal of Digestive Diseases. Jun. 2014;15(6):283-92. KQ1E8, KQ2E8, KQ6E8. [pmid: 24593260].
27 Al-Shammari AMH, Naylor I, Naylor R. Aspirin brings about its beneficial effects by modification of diastolic blood pressure of smokers. J Appl Pharmacy. 2012;3(4):651-4. PMID: None. KQ1E3a, KQ2E3a, KQ6E3a.
28 Allison M, Garland C, Chlebowski R, et al. The association between aspirin use and the incidence of colorectal cancer in women. Am J Epidemiol. Sep. 15. 2006;164(6):567-75. KQ1E6, KQ2E6, KQ6E5. [pmid: 16847042].
29 Altman R, Boullon F, Rouvier J, et al. Aspirin and prophylaxis of thromboembolic complications in patients with substitute heart valves. J Thorac Cardiovasc Surg. Jul. 1976;72(1):127-9. KQ1E4, KQ2E4, KQ6E4. [pmid: 1084448].
30 Ananthakrishnan AN, Higuchi LM, Huang ES, et al. Aspirin, nonsteroidal anti-inflammatory drug use, and risk for Crohn disease and ulcerative colitis: a cohort study. Ann Intern Med. Mar. 6. 2012;156(5):350-9. KQ1E6, KQ2E6, KQ6E3b. [pmid: 22393130].
31 Ariesen MJ, Algra A, Kappelle LJ. Antiplatelet drugs in the secondary prevention after stroke: differential efficacy in large versus small vessel disease? A subgroup analysis from ESPS-2. Stroke. Jan. 2006;37(1):134-8. KQ1E6, KQ2E6, KQ6E5. [pmid: 16306466].
32 Aronow HD, Califf RM, Harrington RA, et al. Relation between aspirin dose, all-cause mortality, and bleeding in patients with recent cerebrovascular or coronary ischemic events (from the BRAVO Trial). Am J Cardiol. Nov. 15. 2008;102(10):1285-90. KQ1E3, KQ2E3, KQ6E4. [pmid: 18993142].
33 Arvanitakis Z, Grodstein F, Bienias JL, et al. Relation of NSAIDs to incident AD, change in cognitive function, and AD pathology. Neurology. Jun. 3. 2008;70(23):2219-25. KQ1E6, KQ2E6, KQ6E5. [pmid: 18519870].
34 Azoulay L, Dell'Aniello S, Simon T, et al. The concurrent use of antithrombotic therapies and the risk of bleeding in patients with atrial fibrillation. Thromb Haemost. Mar. 5. 2013;109(3):431-9. KQ1E6, KQ2E6, KQ6E6. [pmid: 23306435].
35 Baigent C, Landray M, Leaper C, et al. First United Kingdom Heart and Renal Protection (UK-HARP-I) study: biochemical efficacy and safety of simvastatin and safety of low-dose aspirin in chronic kidney disease. Am J Kidney Dis. 2012;45(3):473-84. KQ1E2, KQ2E2, KQ6E2. [pmid: 15754269].
36 Bardia A, Ebbert JO, Vierkant RA, et al. Association of aspirin and nonaspirin nonsteroidal anti-inflammatory drugs with cancer incidence and mortality. J Natl Cancer Inst. Jun. 6. 2007;99(11):881-9. KQ1E6, KQ2E6, KQ6E3. [pmid: 17551148].
37 Bardia A, Olson JE, Vachon CM, et al. Effect of aspirin and other NSAIDs on postmenopausal breast cancer incidence by hormone receptor status: results from a prospective cohort study. Breast Cancer Res Treat. Feb. 2011;126(1):149-55. KQ1E6, KQ2E6, KQ6E5. [pmid: 20669045].
38 Barry EL, Poole EM, Baron JA, et al. CYP2C9 variants increase risk of colorectal adenoma recurrence and modify associations with smoking but not aspirin treatment. Cancer Causes Control. Jan. 2013;24(1):47-54. KQ1E6, KQ2E6, KQ6E5. [pmid: 23081681].
39 Barthelemy O, Limbourg T, Collet JP, et al. Impact of non-steroidal anti-inflammatory drugs (NSAIDs) on cardiovascular outcomes in patients with stable atherothrombosis or multiple risk factors. Int J Cardiol. Mar. 10. 2013;163(3):266-71. KQ1E6, KQ2E6, KQ6E3a. [pmid: 21719126].
40 Bauer T, Gitt A, Zahn R, et al. Impact of chronic antithrombotic therapy on hospital course of patients with acute myocardial infarction. Clin Cardiol. Dec. 2009;32(12):718-23. KQ1E6, KQ2E6, KQ6E5. [pmid: 20027657].
41 Becattini C, Agnelli G, Schenone A. Aspirin reduced recurrence of venous thromboembolism (VTE) after a first-ever, unprovoked VTE. Annals of Internal Medicine. 2012;157(8):JC4-JC3. KQ1E6, KQ2E6, KQ6E6. [pmid: 23070505].
42 Becattini C, Agnelli G, Schenone A, et al. Aspirin for preventing the recurrence of venous thromboembolism. N Engl J Med. May. 24. 2012;366(21):1959-67. KQ2E5. [pmid: 22621626].
43 Benamouzig R, Yoon H, Little J, et al. APACC, a French prospective study on aspirin efficacy in reducing colorectal adenoma recurrence: design and baseline findings. Eur J Cancer Prev. Aug. 2001;10(4):327-35. KQ1E5a, KQ2E5a. [pmid: 11535875].
44 Benamouzig R, Deyra J, Martin A, et al. Daily soluble aspirin and prevention of colorectal adenoma recurrence: one-year results of the APACC trial. Gastroenterology. Aug. 2003;125(2):328-36. KQ1E5a, KQ2E5a. [pmid: 12891533].
45 Benito-Garcia E, Michaud K, Wolfe F. The effect of low-dose aspirin on the decreased risk of development of dyspepsia and gastrointestinal ulcers associated to cyclooxygenase-2 selective inhibitors. J Rheumatol. Aug. 2007;34(8):1765-9. KQ1E6, KQ2E6, KQ6E3. [pmid: 17611980].
46 Bentham P, Gray R, Sellwood E, et al. Aspirin in Alzheimer's disease (AD2000): a randomised open-label trial. Lancet Neurol. Jan. 2008;7(1):41-9. KQ1E10, KQ2E10, KQ6E10. [pmid: 18068522].
47 Berger JS, Brown DL, Burke GL, et al. Aspirin use, dose, and clinical outcomes in postmenopausal women with stable cardiovascular disease: the Women's Health Initiative Observational Study. Circ Cardiovasc Qual Outcomes. Mar. 2009;2(2):78-87. KQ1E6, KQ2E6, KQ6E3b. [pmid: 20031819].
48 Berisha B, Gashi M, Krasniqi X, et al. Limitations of CHADS2 scoring system in predicting stroke risk--need to change the age criteria. Med Arh. 2011;65(1):27-9. KQ1E6, KQ2E6, KQ6E4. [pmid: 21534448].
49 Bermingham M, Shanahan MK, O'Connell E, et al. Aspirin use in heart failure: is low-dose therapy associated with mortality and morbidity benefits in a large community population?. Circulation. Mar. 1. 2014;7(2):243-50. KQ1E6, KQ2E6, KQ6E3d. [pmid: 24493706].
50 Bertuccio P, Bravi F, Bosetti C, et al. Aspirin and gastric cancer risk. Eur J Cancer Prev. Nov. 2010;19(6):426-7. KQ1E6, KQ2E6, KQ6E6. [pmid: 20881520].
51 Biffi A, Halpin A, Towfighi A, et al. Aspirin and recurrent intracerebral hemorrhage in cerebral amyloid angiopathy. Neurology. Aug. 24. 2010;75(8):693-8. KQ1E6, KQ2E6, KQ6E6. [pmid: 20733144].
52 Bonville DJ, Ata A, Jahraus CB, et al. Impact of preinjury warfarin and antiplatelet agents on outcomes of trauma patients. Surgery. Oct. 2011;150(4):861-8. KQ1E6, KQ2E6, KQ6E2. [pmid: 22000201].
53 Bornebroek M, de Lau LM, Haag MD, et al. Nonsteroidal anti-inflammatory drugs and the risk of Parkinson disease. Neuroepidemiology. 2007;28(4):193-6. KQ1E6, KQ2E6, KQ6E5. [pmid: 17851257].
54 Bosco JL, Palmer JR, Boggs DA, et al. Regular aspirin use and breast cancer risk in US Black women. Cancer Causes Control. Nov. 2011;22(11):1553-61. KQ1E6, KQ2E6, KQ6E5. [pmid: 21877122].
55 Bousser MG, Eschwege E, Haguenau M, et al. “AICLA” controlled trial of aspirin and dipyridamole in the secondary prevention of athero-thrombotic cerebral ischemia. Stroke. Jan. 1983;14(1):5-14. KQ1E10, KQ2E10, KQ6E10. [pmid: 6401878].
56 Boysen G, Sorensen PS, Juhler M, et al. Danish very-low-dose aspirin after carotid endarterectomy trial. Stroke. Oct. 1988;19(10):1211-5. KQ1E3b, KQ2E3b, KQ6E3b. [pmid: 3051530].
57 Brasky TM, Baik CS, Slatore CG, et al. Non-steroidal anti-inflammatory drugs and small cell lung cancer risk in the VITAL study. Lung Cancer. Aug. 2012;77(2):260-4. KQ1E6, KQ2E6, KQ6E5. [pmid: 22608142].
58 Brasky TM, Potter JD, Kristal AR, et al. Non-steroidal anti-inflammatory drugs and cancer incidence by sex in the VITamins And Lifestyle (VITAL) cohort. Cancer Causes Control. Mar. 2012;23(3):431-44. KQ1E6, KQ2E6, KQ6E5. [pmid: 22212612].
59 Breddin K, Loew D, Lechner K, et al. Secondary prevention of myocardial infarction: a comparison of acetylsalicylic acid, placebo and phenprocoumon. Haemostasis. 1980;9(6):325-44. KQ1E10, KQ2E10, KQ6E10. [pmid: 7005035].
60 Brighton TA, Eikelboom JW, Mann K. Aspirin did not reduce recurrence after a first-ever, unprovoked venous thromboembolism. Annals of Internal Medicine. 2013;158(6):JC2. KQ1E6, KQ2E6, KQ6E6. [pmid: 23552619].
61 Britton M, Helmers C, Samuelsson K. High-dose acetylsalicyclic acid after cerebral infarction: a Swedish cooperative study. Stroke. 1987;18(2):352-34. KQ1E10, KQ2E10, KQ6E10. [pmid: 3551212].
62 Burke JP, Sander S, Shah H, et al. Impact of persistence with antiplatelet therapy on recurrent ischemic stroke and predictors of nonpersistence among ischemic stroke survivors. Curr Med Res Opin. May. 2010;26(5):1023-30. KQ1E6, KQ2E6, KQ6E3. [pmid: 20199138].
63 Burton C, Isles C, Norrie J, et al. The safety and adequacy of antithrombotic therapy for atrial fibrillation: a regional cohort study. Br J Gen Pract. Sep. 2006;56(530):697-702. KQ1E6, KQ2E6, KQ6E3b. [pmid: 16954003].
64 Bytzer P, Pratt S, Elkin E, et al. Burden of upper gastrointestinal symptoms in patients receiving low-dose acetylsalicylic acid for cardiovascular risk management: a prospective observational study. Am J Cardiovasc Drugs. Feb. 2013;13(1):27-35. KQ1E6, KQ2E6, KQ6E3a. [pmid: 23315343].
65 Cadiou G, Adam M, Caussin M, et al. Antiplatelet drugs in the elderly: prescriptions often inappropriate and reduced tolerance by associated diseases and drugs. Fundam Clin Pharmacol. Apr. 2012;26(2):307-13. KQ1E6, KQ2E6, KQ6E4. [pmid: 21241362].
66 Cahoon EK, Rajaraman P, Alexander BH, et al. Use of nonsteroidal anti-inflammatory drugs and risk of basal cell carcinoma in the United States Radiologic Technologists study. Int J Cancer. Jun. 15. 2012;130(12):2939-48. KQ1E6, KQ2E6, KQ6E5. [pmid: 21780102].
67 Cao J, Liu L, Fan L, et al. The prevalence, risk factors and prognosis of aspirin resistance in elderly male patients with cardiovascular disease. Aging Male. Sep. 2012;15(3):140-7. KQ1E8, KQ2E8, KQ6E8. [pmid: 22452804].
68 Casais P, Meschengieser SS, Sanchez Luceros AG, et al. Effect of low-dose aspirin on the international normalized ratio variability in patients with mechanical heart valve prostheses. Pathophysiol Haemost Thromb. Jul. 2002;32(4):155-7. KQ1E4, KQ2E4, KQ6E4. [pmid: 12759515].
69 Catalano M, Born G, Peto R. Prevention of serious vascular events by aspirin amongst patients with peripheral arterial disease: randomized, double-blind trial. J Intern Med. Mar. 2007;261(3):276-84. KQ1E10, KQ2E10, KQ6E10. [pmid: 17305650].
70 Cea SL, Bueno H, Lanas A, et al. Cardiovascular and upper gastrointestinal bleeding consequences of low-dose acetylsalicylic acid discontinuation. Thromb Haemost. Nov. 27. 2013;110(6):1298-304. KQ1E6, KQ2E6, KQ6E6. [pmid: 24008261].
71 Chan AT, Giovannucci EL, Meyerhardt JA, et al. Long-term use of aspirin and nonsteroidal anti-inflammatory drugs and risk of colorectal cancer. JAMA. Aug. 24. 2005;294(8):914-23. KQ1E6, KQ2E6. [pmid: 16118381].
72 Chan AT, Manson JE, Feskanich D, et al. Long-term aspirin use and mortality in women. Arch Intern Med. Mar. 26. 2007;167(6):562-72. KQ1E6, KQ2E6, KQ6E6. [pmid: 17389287].
73 Chan AT, Giovannucci EL, Meyerhardt JA, et al. Aspirin dose and duration of use and risk of colorectal cancer in men. Gastroenterology. Jan. 2008;134(1):21-8. KQ1E6, KQ2E6, KQ6E5. [pmid: 18005960].
74 Chan AT, Ogino S, Fuchs CS. Aspirin use and survival after diagnosis of colorectal cancer. JAMA. Aug. 12. 2009;302(6):649-58. KQ1E6, KQ2E6, KQ6E2. [pmid: 19671906].
75 Chan KE, Lazarus JM, Thadhani R, et al. Anticoagulant and antiplatelet usage associates with mortality among hemodialysis patients. J Am Soc Nephrol. Apr. 2009;20(4):872-81. KQ1E6, KQ2E6, KQ6E2. [pmid: 19297555].
76 Chan KL, Tam J, Dumesnil JG, et al. Effect of long-term aspirin use on embolic events in infective endocarditis. Clin Infect Dis. Jan. 1. 2008;46(1):37-41. KQ1E6, KQ2E6, KQ6E3a. [pmid: 18171211].
77 Chan SS, Luben R, Bergmann MM, et al. Aspirin in the aetiology of Crohn's disease and ulcerative colitis: a European prospective cohort study. Aliment Pharmacol Ther. Sep. 2011;34(6):649-55. KQ1E6, KQ2E6, KQ6E6. [pmid: 21790683].
78 Chesebro JH, Wiebers DO, Holland AE, et al. Warfarin versus aspirin for prevention of thromboembolism in atrial fibrillation: Stroke Prevention in Atrial Fibrillation II Study. Lancet. 1994;343(8899):687-91. KQ1E4, KQ2E4, KQ6E4. [pmid: 7907677].
79 Cho E, Curhan G, Hankinson SE, et al. Prospective evaluation of analgesic use and risk of renal cell cancer. Arch Intern Med. Sep. 12. 2011;171(16):1487-93. KQ1E6, KQ2E6, KQ6E3b. [pmid: 21911634].
80 Choi CK, Kim N, Choi JW, et al. Effect of low-dose, enteric coated aspirin on gastrointestinal bleeding in patients with coronary artery disease. Gut Liver. Sep. 2008;2(2):99-104. KQ1E10, KQ2E10, KQ6E10. [pmid: 20485618].
81 Christen WG, Glynn RJ, Ajani UA, et al. Age-related maculopathy in a randomized trial of low-dose aspirin among US physicians. Arch Ophthalmol. Aug. 2001;119(8):1143-9. KQ2E5. [pmid: 11483080].
82 Cleland JG, Findlay I, Jafri S, et al. The Warfarin/Aspirin Study in Heart failure (WASH): a randomized trial comparing antithrombotic strategies for patients with heart failure. Am Heart J. Jul. 2004;148(1):157-64. KQ1E10, KQ2E10, KQ6E10. [pmid: 15215806].
83 Cole BF, Baron JA, Sandler RS, et al. Folic acid for the prevention of colorectal adenomas: a randomized clinical trial. JAMA. Jun. 6. 2007;297(21):2351-9. KQ1E3, KQ2E3, KQ6E3. [pmid: 17551129].
84 Cook NR, Cole SR, Buring JE. Aspirin in the primary prevention of cardiovascular disease in the Women's Health Study: effect of noncompliance. Eur J Epidemiol. Jun. 2012;27(6):431-8. KQ1E5, KQ2E5, KQ6E5. [pmid: 22699516].
85 Cordina SM, Vazquez G, Suri MF, et al. Does aspirin failure increase the chances of recurrent stroke and/or death among patients with ischemic stroke: a pooled analysis of two prospective trials. Stroke. 2010;41(4):e214-e215. PMID: None. KQ1E3, KQ2E3, KQ6E3.
86 Cote R, Battista RN, Abrahamowicz M, et al. Lack of effect of aspirin in asymptomatic patients with carotid bruits and substantial carotid narrowing. The Asymptomatic Cervical Bruit Study Group. Ann Intern Med. Nov. 1. 1995;123(9):649-55. KQ2E5. [pmid: 7574219].
87 Cote S, Carmichael PH, Verreault R, et al. Nonsteroidal anti-inflammatory drug use and the risk of cognitive impairment and Alzheimer's disease. Alzheimers Dement. May. 2012;8(3):219-26. KQ1E6, KQ2E6, KQ6E3. [pmid: 22546354].
88 Cruz JP, Guerrero A, Rueda E, et al. Efficacy and safety of sustained-release aspirin in patients with chronic coronary disease. Eur J Clin Pharmacol. 2010;66:S60. PMID: None. KQ1E4, KQ2E4, KQ6E4.
89 Cubbon RM, Gale CP, Rajwani A, et al. Aspirin and mortality in patients with diabetes sustaining acute coronary syndrome. Diabetes Care. Feb. 2008;31(2):363-5. KQ1E6, KQ2E6, KQ6E5. [pmid: 17959865].
90 Curhan SG, Eavey R, Shargorodsky J, et al. Analgesic use and the risk of hearing loss in men. Am J Med. Mar. 2010;123(3):231-7. KQ1E6, KQ2E6, KQ6E3b. [pmid: 20193831].
91 Dale J, Myhre E, Storstein O, et al. Prevention of arterial thromboembolism with acetylsalicylic acid. A controlled clinical study in patients with aortic ball valves. Am Heart J. Jul. 1977;94(1):101-11. KQ1E2, KQ2E2, KQ6E2. [pmid: 326013].
92 de Berardis G, Lucisano G, D'Ettorre A, et al. Association of aspirin use with major bleeding in patients with and without diabetes. JAMA. Jun. 6. 2012;307(21):2286-94. KQ1E6, KQ2E6. [pmid: 22706834].
93 Delaney JA, Lehmann N, Jockel KH, et al. Associations between aspirin and other non-steroidal anti-inflammatory drugs and aortic valve or coronary artery calcification: the Multi-Ethnic Study of Atherosclerosis and the Heinz Nixdorf Recall Study. Atherosclerosis. Aug. 2013;229(2):310-6. KQ1E6, KQ2E6, KQ6E5. [pmid: 23880181].
94 Derogar M, Sandblom G, Lundell L, et al. Discontinuation of low-dose aspirin therapy after peptic ulcer bleeding increases risk of death and acute cardiovascular events. Clin Gastroenterol Hepatol. Jan. 2013;11(1):38-42. KQ1E6, KQ2E6, KQ6E3a. [pmid: 22975385].
95 Dhillon PK, Kenfield SA, Stampfer MJ, et al. Long-term aspirin use and the risk of total, high-grade, regionally advanced and lethal prostate cancer in a prospective cohort of health professionals, 1988-2006. Int J Cancer. May. 15. 2011;128(10):2444-52. KQ1E6, KQ2E6, KQ6E5. [pmid: 21128233].
96 Diehl AK. ACP Journal Club. Individual-patient meta-analysis: daily aspirin reduces risk for incident cancer with distant metastasis. Ann Intern Med. Mar. 2. 2012;157(2):JC2-JC3. KQ1E6, KQ2E6, KQ6E6. [pmid: 22801695].
97 Dorresteijn JA, Visseren FL, Ridker PM, et al. Aspirin for primary prevention of vascular events in women: individualized prediction of treatment effects. Eur Heart J. Dec. 2011;32(23):2962-9. KQ1E5a, KQ2E5a, KQ6E5a. [pmid: 22090661].
98 Eborall HC, Stewart MC, Cunningham-Burley S, et al. Accrual and drop out in a primary prevention randomised controlled trial: qualitative study. Trials. 2011;12:7. KQ1E5, KQ2E5, KQ6E5. [pmid: 21223551].
99 Egan KM, Stampfer MJ, Giovannucci E, et al. Prospective study of regular aspirin use and the risk of breast cancer. J Natl Cancer Inst. Jul. 17. 1996;88(14):988-93. KQ1E6, KQ2E6, KQ6E3b. [pmid: 8667430].
100 Ekstrom N, Cederholm J, Zethelius B, et al. Aspirin treatment and risk of first incident cardiovascular diseases in patients with type 2 diabetes: an observational study from the Swedish National Diabetes Register. BMJ Open. 2013;3(4):2013. KQ1E6, KQ2E6. [pmid: 23604419].
101 Elwood PC, Cochrane AL, Burr ML, et al. A randomized controlled trial of acetyl salicylic acid in the secondary prevention of mortality from myocardial infarction. Br Med J. Mar. 9. 1974;1(5905):436-40. KQ1E10, KQ2E10, KQ6E10. [pmid: 4593555].
102 Elwood PC, Sweetnam PM. Aspirin and secondary mortality after myocardial infarction. Lancet. Dec. 22. 1979;2(8156-8157):1313-5. KQ1E10, KQ2E10, KQ6E10. [pmid: 92668].
103 Epplein M, Nomura AM, Wilkens LR, et al. Nonsteroidal antiinflammatory drugs and risk of gastric adenocarcinoma: the multiethnic cohort study. Am J Epidemiol. Aug. 15. 2009;170(4):507-14. KQ1E6, KQ2E6, KQ6E5. [pmid: 19584132].
104 Ethier J, Bragg-Gresham JL, Piera L, et al. Aspirin prescription and outcomes in hemodialysis patients: the Dialysis Outcomes and Practice Patterns Study (DOPPS). Am J Kidney Dis. Oct. 2007;50(4):602-11. KQ1E6, KQ2E6, KQ6E2. [pmid: 17900460].
105 Evans M, Fored CM, Bellocco R, et al. Acetaminophen, aspirin and progression of advanced chronic kidney disease. Nephrol Dial Transplant. Jun. 2009;24(6):1908-18. KQ1E6, KQ2E6, KQ6E2. [pmid: 19155536].
106 Farkouh ME, Greenberg JD, Jeger RV, et al. Cardiovascular outcomes in high risk patients with osteoarthritis treated with ibuprofen, naproxen or lumiracoxib. Ann Rheum Dis. Jun. 2007;66(6):764-70. KQ1E3, KQ2E3, KQ6E3. [pmid: 17412741].
107 Farrell B, Godwin J, Richards S, et al. The United Kingdom transient ischaemic attack (UK-TIA) aspirin trial: final results. J Neurol Neurosurg Psychiatry. Dec. 1991;54(12):1044-54. KQ2E5. [pmid: 1783914].
108 Feringa HH, van Waning VH, Bax JJ, et al. Cardioprotective medication is associated with improved survival in patients with peripheral arterial disease. J Am Coll Cardiol. Mar. 21. 2006;47(6):1182-7. KQ1E6, KQ2E6, KQ6E5. [pmid: 16545650].
109 Feskanich D, Bain C, Chan AT, et al. Aspirin and lung cancer risk in a cohort study of women: dosage, duration and latency. Br J Cancer. Nov. 5. 2007;97(9):1295-9. KQ1E6, KQ2E6, KQ6E5. [pmid: 17895894].
110 Fields WS, Lemak NA, Frankowski RF, et al. Controlled trial of aspirin in cerebral ischemia. Stroke. May. 1977;8(3):301-14. KQ1E10, KQ2E10, KQ6E10. [pmid: 324036].
111 Fields WS, Lemak NA, Frankowski RF, et al. Controlled trial of aspirin in cerebral ischemia. Part II: surgical group. Stroke. Jul. 1978;9(4):309-19. KQ1E10, KQ2E10, KQ6E10. [pmid: 354098].
112 Fonseca J, Alves CC, Neto R, et al. Nonvariceal upper gastrointestinal bleeding in Portugal: a multicentric retrospective study in twelve Portuguese hospitals. Gastroenterol Hepatol. Jun. 2012;35(6):377-85. KQ1E6, KQ2E6, KQ6E3. [pmid: 22657569].
113 Ford AC, Forman D, Bailey AG, et al. Initial poor quality of life and new onset of dyspepsia: results from a longitudinal 10-year follow-up study. Gut. Mar. 2007;56(3):321-7. KQ1E6, KQ2E6, KQ6E3. [pmid: 16908511].
114 Franceschi M, Scarcelli C, Niro V, et al. Prevalence, clinical features and avoidability of adverse drug reactions as cause of admission to a geriatric unit: a prospective study of 1756 patients. Drug Saf. 2008;31(6):545-56. KQ1E6, KQ2E6, KQ6E6. [pmid: 18484788].
115 Friedman GD, Ury HK. Initial screening for carcinogenicity of commonly used drugs. J Natl Cancer Inst. Oct. 1980;65(4):723-33. KQ1E6, KQ2E6, KQ6E5. [pmid: 6932525].
116 Friis S, Nielsen GL, Mellemkjaer L, et al. Cancer risk in persons receiving prescriptions for paracetamol: a Danish cohort study. Int J Cancer. Jan. 1. 2002;97(1):96-101. KQ1E6, KQ2E6, KQ6E3. [pmid: 11774249].
117 Friis S, Sorensen HT, McLaughlin JK, et al. A population-based cohort study of the risk of colorectal and other cancers among users of low-dose aspirin. Br J Cancer. Mar. 10. 2003;88(5):684-8. KQ1E6, KQ2E6, KQ6E5. [pmid: 12618874].
118 Friis S, Thomassen L, Sorensen HT, et al. Nonsteroidal anti-inflammatory drug use and breast cancer risk: a Danish cohort study. European Journal of Cancer Prevention. 2008;17(2):88-96. KQ1E6, KQ2E6, KQ6E4. [pmid: 18287865].
119 Friis S, Poulsen AH, Sorensen HT, et al. Aspirin and other non-steroidal anti-inflammatory drugs and risk of colorectal cancer: a Danish cohort study. Cancer Causes Control. Jul. 2009;20(5):731-40. KQ1E6, KQ2E6, KQ6E5. [pmid: 19122977].
120 Funkhouser EM, Sharp GB. Aspirin and reduced risk of esophageal carcinoma. Cancer. Oct. 1. 1995;76(7):1116-9. KQ1E6, KQ2E6, KQ6E5. [pmid: 8630885].
121 Gaede P, Lund-Andersen H, Parving HH, et al. Effect of a multifactorial intervention on mortality in type 2 diabetes. N Engl J Med. Feb. 7. 2008;358(6):580-91. KQ1E4, KQ2E4, KQ6E4. [pmid: 18256393].
122 Gallagher PJ, Castro V, Fava M, et al. Antidepressant response in patients with major depression exposed to NSAIDs: a pharmacovigilance study. Am J Psychiatry. Oct. 2012;169(10):1065-72. KQ1E6, KQ2E6, KQ6E3. [pmid: 23032386].
123 Gallicchio L, Visvanathan K, Burke A, et al. Nonsteroidal anti-inflammatory drugs and the risk of developing breast cancer in a population-based prospective cohort study in Washington County, MD. Int J Cancer. Jul. 1. 2007;121(1):211-5. KQ1E6, KQ2E6, KQ6E5. [pmid: 17330846].
124 Gann PH, Manson JE, Glynn RJ, et al. Low-dose aspirin and incidence of colorectal tumors in a randomized trial. J Natl Cancer Inst. Aug. 4. 1993;85(15):1220-4. KQ1E5a, KQ2E5a, KQ6E2. [pmid: 8331682].
125 Garcia Rodriguez LA, Lin KJ, Hernandez-Diaz S, et al. Risk of upper gastrointestinal bleeding with low-dose acetylsalicylic acid alone and in combination with clopidogrel and other medications. Circulation. Mar. 15. 2011;123(10):1108-15. KQ1E6, KQ2E6, KQ6E6. [pmid: 21357821].
126 Gatenby PA, Ramus JR, Caygill CP, et al. Aspirin is not chemoprotective for Barrett's adenocarcinoma of the oesophagus in multicentre cohort. Eur J Cancer Prev. Sep. 2009;18(5):381-4. KQ1E6, KQ2E6, KQ6E5. [pmid: 19620873].
127 Ge L, Niu G, Han X, et al. Aspirin treatment increases the risk of cerebral microbleeds. Can J Neurol Sci. Nov. 2011;38(6):863-8. KQ1E8, KQ2E8, KQ6E8. [pmid: 22030424].
128 Genkinger JM, De V I, Stampfer MJ, et al. Nonsteroidal antiinflammatory drug use and risk of bladder cancer in the health professionals follow-up study. Int J Cancer. May. 15. 2007;120(10):2221-5. KQ1E6, KQ2E6, KQ6E5. [pmid: 17290403].
129 Gent M, Barnett HJ, Sackett DL, et al. A randomized trial of aspirin and sulfinpyrazone in patients with threatened stroke. Results and methodologic issues. Circulation. Dec. 1980;62(6 Pt 2):V97-105. KQ1E10, KQ2E10, KQ6E10. [pmid: 7002357].
130 Gierach GL, Lacey JV Jr., Schatzkin A, et al. Nonsteroidal anti-inflammatory drugs and breast cancer risk in the National Institutes of Health-AARP Diet and Health Study. Breast Cancer Res. 2008;10(2):R38. KQ1E6, KQ2E6, KQ6E5. [pmid: 18447943].
131 Gill JK, Maskarinec G, Wilkens LR, et al. Nonsteroidal antiinflammatory drugs and breast cancer risk: the multiethnic cohort. Am J Epidemiol. Nov. 15. 2007;166(10):1150-8. KQ1E6, KQ2E6, KQ6E5. [pmid: 17698973].
132 Glasser SP, Hovater MK, Lackland DT, et al. Primary prophylactic aspirin use and incident stroke: reasons for geographic and racial differences in stroke study. J Stroke Cerebrovasc Dis. May. 2013;22(4):500-7. KQ1E6, KQ2E6, KQ6E3b. [pmid: 23571051].
133 Goldman S, Copeland J, Moritz T, et al. Improvement in early saphenous vein graft patency after coronary artery bypass surgery with antiplatelet therapy: results of a Veterans Administration Cooperative Study. Circulation. Jun. 1988;77(6):1324-32. KQ1E2, KQ2E2, KQ6E2. [pmid: 3286040].
134 Goren A, Liu X, Gupta S, et al. Warfarin and aspirin use for stroke prevention among patients with atrial fibrillation: the US National Health and Wellness Survey. Am J Ther. 2013. Dec. 9. KQ1E3, KQ2E3, KQ6E3. [pmid: 24326696].
135 Gottlieb S, Behar S, Hod H, et al. Trends in management, hospital and long-term outcomes of elderly patients with acute myocardial infarction. Am J Med. Jan. 2007;120(1):90-7. KQ1E1, KQ2E1, KQ6E1. [pmid: 17208084].
136 Gridley G, McLaughlin JK, Ekbom A, et al. Incidence of cancer among patients with rheumatoid arthritis. J Natl Cancer Inst. Feb. 17. 1993;85(4):307-11. KQ1E6, KQ2E6, KQ6E3. [pmid: 8426374].
137 Grodstein F, Skarupski KA, Bienias JL, et al. Anti-inflammatory agents and cognitive decline in a bi-racial population. Neuroepidemiology. 2008;30(1):45-50. KQ1E6, KQ2E6, KQ6E5. [pmid: 18259082].
138 Gullov AL, Koefoed BG, Petersen P, et al. Fixed minidose warfarin and aspirin alone and in combination vs adjusted-dose warfarin for stroke prevention in atrial fibrillation: Second Copenhagen Atrial Fibrillation, Aspirin, and Anticoagulation Study. Arch Intern Med. Jul. 27. 1998;158(14):1513-21. KQ1E4, KQ2E4, KQ6E4. [pmid: 9679792].
139 Guo X, Wang J, Wang Y, et al. Incidence and related factors of upper gastrointestinal bleeding in a Chinese population of peripheral arterial disease during a six-year follow-up. Int Angiol. Feb. 2014;33(1):65-9. KQ1E8, KQ2E8, KQ6E8. [pmid: 24452088].
140 Habel LA, Zhao W, Stanford JL. Daily aspirin use and prostate cancer risk in a large, multiracial cohort in the US. Cancer Causes Control. Jun. 2002;13(5):427-34. KQ1E6, KQ2E6, KQ6E5. [pmid: 12146847].
141 Hallevi H, Albright KC, Martin-Schild S, et al. Anticoagulation after cardioembolic stroke: to bridge or not to bridge?. Arch Neurol. Sep. 2008;65(9):1169-73. KQ1E6, KQ2E6, KQ6E3. [pmid: 18625852].
142 Hansen F, Lindblad B, Persson NH, et al. Can recurrent stenosis after carotid endarterectomy be prevented by low-dose acetylsalicylic acid? A double-blind, randomised and placebo-controlled study. Eur J Vasc Surg. Jul. 1993;7(4):380-5. KQ1E3a, KQ2E3a, KQ6E3a. [pmid: 8359292].
143 Harris RE, Kasbari S, Farrar WB. Prospective study of nonsteroidal anti-inflammatory drugs and breast cancer. Oncol Rep. Jan. 1999;6(1):71-3. KQ1E6, KQ2E6, KQ6E5. [pmid: 9864404].
144 Harris RE, Chlebowski RT, Jackson RD, et al. Breast cancer and nonsteroidal anti-inflammatory drugs: prospective results from the Women's Health Initiative. Cancer Res. Sep. 15. 2003;63(18):6096-101. KQ1E6, KQ2E6, KQ6E5. [pmid: 14522941].
145 Hasegawa T, Elder SJ, Bragg-Gresham JL, et al. Consistent aspirin use associated with improved arteriovenous fistula survival among incident hemodialysis patients in the dialysis outcomes and practice patterns study. Clin J Am Soc Nephrol. Sep. 2008;3(5):1373-8. KQ1E6, KQ2E6, KQ6E2. [pmid: 18596119].
146 Hayes JH, Anderson KE, Folsom AR. Association between nonsteroidal anti-inflammatory drug use and the incidence of lung cancer in the Iowa women's health study. Cancer Epidemiol Biomarkers Prev. Nov. 2006;15(11):2226-31. KQ1E6, KQ2E6, KQ6E5. [pmid: 17119050].
147 Hayreh SS, Podhajsky PA, Zimmerman MB. Central and hemicentral retinal vein occlusion: role of anti-platelet aggregation agents and anticoagulants. Ophthalmology. Aug. 2011;118(8):1603-11. KQ1E6, KQ2E6, KQ6E2. [pmid: 21704382].
148 Hennekens CH, Schneider WR, Hebert PR, et al. Hypothesis formulation from subgroup analyses: nonadherence or nonsteroidal anti-inflammatory drug use explains the lack of clinical benefit of aspirin on first myocardial infarction attributed to “aspirin resistance”. Am Heart J. May. 2010;159(5):744-8. KQ1E5b, KQ2E5b, KQ6E5b. [pmid: 20435181].
149 Hernan MA, Logroscino G, Garcia Rodriguez LA. Nonsteroidal anti-inflammatory drugs and the incidence of Parkinson disease. Neurology. Apr. 11. 2006;66(7):1097-9. KQ1E6, KQ2E6, KQ6E6. [pmid: 16606925].
150 Hernandez-Diaz S, Garcia Rodriguez LA. Cardioprotective aspirin users and their excess risk of upper gastrointestinal complications. BMC Med. 2006;4:22. KQ1E6, KQ2E6, KQ6E6. [pmid: 16987411].
151 Hess H, Keil-Kuri E. Theoretische grundlagen der prophylaxe obliterierender arteriopathien mit aggregationshemmern und ergebnisse einer langzeitstudie mit ASS (Colfarit). Proceedings of the Colfarit Symposium III. Germany. 1975:80-7. PMID: None. KQ1E9, KQ2E9, KQ6E9.
152 Hess H, Mietaschk A, Deichsel G. Drug-induced inhibition of platelet function delays progression of peripheral occlusive arterial disease. A prospective double-blind arteriographically controlled trial. Lancet. Feb. 23. 1985;1(8426):415-9. KQ1E10, KQ2E10, KQ6E10. [pmid: 2857803].
153 Hirata Y, Kataoka H, Shimura T, et al. Incidence of gastrointestinal bleeding in patients with cardiovascular disease: buffered aspirin versus enteric-coated aspirin. Scand J Gastroenterol. Jul. 2011;46(7-8):803-9. KQ1E10, KQ2E10, KQ6E10. [pmid: 21501103].
154 Hirvela H, Luukinen H, Laara E, et al. Risk factors of age-related maculopathy in a population 70 years of age or older. Ophthalmology. Jun. 1996;103(6):871-7. KQ1E6, KQ2E6, KQ6E3. [pmid: 8643241].
155 Holick CN, Michaud DS, Leitzmann MF, et al. Aspirin use and lung cancer in men. Br J Cancer. Nov. 3. 2003;89(9):1705-8. KQ1E6, KQ2E6, KQ6E5. [pmid: 14583773].
156 Hsu J, Pack Q, Feldstein DA. Clinical use of evidence-based medicine--clinical questions. Is low-dose aspirin a better choice in patients with coronary artery disease and bleeding risks?. WMJ. Feb. 2007;106(1):7-8. KQ1E6, KQ2E6, KQ6E6. [pmid: 17393749].
157 Huang ES, Strate LL, Ho WW, et al. A prospective study of aspirin use and the risk of gastrointestinal bleeding in men. PLoS ONE. 2010;5(12):e15721. KQ1E6, KQ2E6. [pmid: 21209949].
158 Huang ES, Strate LL, Ho WW, et al. Long-term use of aspirin and the risk of gastrointestinal bleeding. Am J Med. May. 2011;124(5):426-33. KQ1E6, KQ2E6. [pmid: 21531232].
159 Huang WK, Chiou MJ, Yu KH, et al. The association between low-dose aspirin use and the incidence of colorectal cancer: a nationwide cohort study. Aliment Pharmacol Ther. Aug. 2013;38(4):432-9. KQ1E8, KQ2E8, KQ6E5a. [pmid: 23799975].
160 Huhtakangas J, Lopponen P, Tetri S, et al. Predictors for recurrent primary intracerebral hemorrhage: a retrospective population-based study. Stroke. Mar. 2013;44(3):585-90. KQ1E6, KQ2E6, KQ6E3. [pmid: 23329207].
161 Ishikawa H, Mutoh M, Suzuki S, et al. The preventive effects of low-dose enteric-coated aspirin tablets on the development of colorectal tumours in Asian patients: a randomised trial. Gut. 2014. Jan. 31. KQ1E2, KQ2E2, KQ6E2. [pmid: 24488498].
162 Iso H, Hennekens CH, Stampfer MJ, et al. Prospective study of aspirin use and risk of stroke in women. Stroke. Sep. 1999;30(9):1764-71. KQ1E6, KQ2E6. [pmid: 10471421].
163 Jacobs EJ, Rodriguez C, Mondul AM, et al. A large cohort study of aspirin and other nonsteroidal anti-inflammatory drugs and prostate cancer incidence. J Natl Cancer Inst. Jul. 6. 2005;97(13):975-80. KQ1E6, KQ2E6, KQ6E5. [pmid: 15998950].
164 Jacobs EJ, Newton CC, Gapstur SM, et al. Daily aspirin use and cancer mortality in a large US cohort. J Natl Cancer Inst. Aug. 22. 2012;104(16):1208-17. KQ1E6, KQ2E6, KQ6E5. [pmid: 22888140].
165 Jacobs EJ, Thun MJ, Bain EB, et al. A large cohort study of long-term daily use of adult-strength aspirin and cancer incidence. J Natl Cancer Inst. Apr. 18. 2007;99(8):608-15. KQ1E6, KQ2E6, KQ6E5. [pmid: 17440162].
166 Jankowski J, Barr H, deCaestecker J, et al. Aspirin in the prevention of cancer. Lancet. 2011;377(9778):1649-50. KQ1E6, KQ2E6, KQ6E6. [pmid: 21571137].
167 Jeong CW, Lee S, Byun SS, et al. No increase in risk of microscopic hematuria with aspirin use by asymptomatic healthy people. JAMA Intern Med. Jun. 24. 2013;173(12):1145-6. KQ1E6, KQ2E6, KQ6E3. [pmid: 23609065].
168 Johansson S, Wallander MA, de Abajo FJ, et al. Prospective drug safety monitoring using the UK primary-care General Practice Research Database: theoretical framework, feasibility analysis and extrapolation to future scenarios. Drug Saf. Mar. 1. 2010;33(3):223-32. KQ1E6, KQ2E6, KQ6E5. [pmid: 20158286].
169 Johnson TW, Anderson KE, Lazovich D, et al. Association of aspirin and nonsteroidal anti-inflammatory drug use with breast cancer. Cancer Epidemiol Biomarkers Prev. Dec. 2002;11(12):1586-91. KQ1E6, KQ2E6, KQ6E5. [pmid: 12496048].
170 Kaiser J. Will an aspirin a day keep cancer away?. Science. Sep. 21. 2012;337(6101):1471-3. KQ1E6, KQ2E6, KQ6E6. [pmid: 22997320].
171 Kawut SM, Bagiella E, Shimbo D, et al. Rationale and design of a phase II clinical trial of aspirin and simvastatin for the treatment of pulmonary arterial hypertension: ASA-STAT. Contemp Clin Trials. Mar. 2011;32(2):280-7. KQ1E3a, KQ2E3a, KQ6E3a. [pmid: 21146637].
172 Kawut SM, Bagiella E, Lederer DJ, et al. Randomized clinical trial of aspirin and simvastatin for pulmonary arterial hypertension: ASA-STAT. Circulation. Jun. 28. 2011;123(25):2985-93. KQ1E3a, KQ2E3a, KQ6E3a. [pmid: 21593252].
173 Kern S, Skoog I, Ostling S, et al. Does low-dose acetylsalicylic acid prevent cognitive decline in women with high cardiovascular risk? A 5-year follow-up of a non-demented population-based cohort of Swedish elderly women. BMJ Open. 2012;2(5):2012. KQ1E6, KQ2E6, KQ6E3a. [pmid: 23035037].
174 Kim YD, Han SB, Park KH, et al. Risk factors associated with optic disc haemorrhage in patients with normal tension glaucoma. Eye. Apr. 2010;24(4):567-72. KQ1E6, KQ2E6, KQ6E6. [pmid: 19648906].
175 Klein BE, Howard KP, Gangnon RE, et al. Long-term use of aspirin and age-related macular degeneration. JAMA. Dec. 19. 2012;308(23):2469-78. KQ1E6, KQ2E6, KQ6E3. [pmid: 23288416].
176 Kor DJ, Talmor DS, Banner-Goodspeed VM, et al. injuryLung Injury Prevention with Aspirin (LIPS-A): a protocol for a multicentre randomised clinical trial in medical patients at high risk of acute lung. BMJ Open. 2012;2(5):2012. KQ1E3a, KQ2E3a, KQ6E3a. [pmid: 22952165].
177 Kozdag G, Yaymaci M, Ertas G, et al. Aspirin, clopidogrel, and warfarin use and outcomes in a cohort of 580 patients discharged after hospitalization for decompensated heart failure. Heart Vessels. Nov. 2012;27(6):568-75. KQ1E6, KQ2E6, KQ6E3. [pmid: 21909806].
178 Kretschmer G, Pratschner T, Prager M, et al. Antiplatelet treatment prolongs survival after carotid bifurcation endarterectomy. Analysis of the clinical series followed by a controlled trial. Ann Surg. Mar. 1990;211(3):317-22. KQ1E10, KQ2E10, KQ6E10. [pmid: 2178566].
179 Kronmal RA, Hart RG, Manolio TA, et al. Aspirin use and incident stroke in the cardiovascular health study. CHS Collaborative Research Group. Stroke. May. 1998;29(5):887-94. KQ1E6, KQ2E6, KQ6E3b. [pmid: 9596230].
180 Kuo HW, Tsai SS, Tiao MM, et al. Analgesic use and the risk for progression of chronic kidney disease. Pharmacoepidemiol Drug Saf. Jul. 2010;19(7):745-51. KQ1E8, KQ2E8, KQ6E8. [pmid: 20582905].
181 Kurth T. Aspirin and cancer prevention. BMJ. 2012;344:e2480. KQ1E6, KQ2E6, KQ6E6. [pmid: 22491078].
182 Kwok CS, Skinner J, Metcalf AK, et al. Prior antiplatelet or anticoagulant therapy and mortality in stroke. Heart. May. 2012;98(9):712-7. KQ1E6, KQ2E6, KQ6E3. [pmid: 22327570].
183 La VC, Bosetti C. Urological cancer: Aspirin and the risk of prostate cancer mortality. Nat Rev Clin Oncol. Nov. 2012;9(11):616-7. KQ1E6, KQ2E6, KQ6E2. [pmid: 23044777].
184 Lafrance JP, Miller DR. Selective and non-selective non-steroidal anti-inflammatory drugs and the risk of acute kidney injury. Pharmacoepidemiol Drug Saf. Oct. 2009;18(10):923-31. KQ1E6, KQ2E6, KQ6E6. [pmid: 19585463].
185 Landolfi R, Marchioli R, Kutti J, et al. Efficacy and safety of low-dose aspirin in polycythemia vera. N Engl J Med. Jan. 8. 2004;350(2):114-24. KQ1E2, KQ2E2, KQ6E2. [pmid: 14711910].
186 Larsson SC, Giovannucci E, Wolk A. Long-term aspirin use and colorectal cancer risk: a cohort study in Sweden. Br J Cancer. Nov. 6. 2006;95(9):1277-9. KQ1E6, KQ2E6, KQ6E5. [pmid: 17060932].
187 Leal AD, Thompson CA, Wang AH, et al. Anthropometric, medical history and lifestyle risk factors for myeloproliferative neoplasms in The Iowa Women's Health Study cohort. Int J Cancer. 2014;134(7):1741-50. KQ1E6, KQ2E6, KQ6E5. [pmid: 24114627].
188 Lechat P, Lardoux H, Mallet A, et al. Anticoagulant (fluindione)-aspirin combination in patients with high-risk atrial fibrillation. A randomized trial (Fluindione, Fibrillation Auriculaire, Aspirin et Contraste Spontane; FFAACS). Cerebrovasc Dis. 2001;12(3):245-52. KQ1E3, KQ2E3, KQ6E3. [pmid: 11641591].
189 Lee BH, Park JS, Park JH, et al. The effect and safety of the antithrombotic therapies in patients with atrial fibrillation and CHADS score 1. J Cardiovasc Electrophysiol. May. 2010;21(5):501-7. KQ1E6, KQ2E6, KQ6E3. [pmid: 20021521].
190 Lee I, Manson C, Hennekens C. Low-dose aspirin and risk of cancer: the Physicians Health Study. Am J Epidemiol. 1995;141:S28. PMID: None. KQ1E10, KQ2E10, KQ6E10.
191 Lee MS, Smith SD, Galor A, et al. Antiplatelet and anticoagulant therapy in patients with giant cell arteritis. Arthritis Rheum. Oct. 2006;54(10):3306-9. KQ1E6, KQ2E6, KQ6E3b. [pmid: 17009265].
192 Leitzmann MF, Stampfer MJ, Ma J, et al. Aspirin use in relation to risk of prostate cancer. Cancer Epidemiol Biomarkers Prev. Oct. 2002;11(10 Pt 1):1108-11. KQ1E6, KQ2E6, KQ6E5. [pmid: 12376516].
193 Leung WY, So WY, Stewart D, et al. Lack of benefits for prevention of cardiovascular disease with aspirin therapy in type 2 diabetic patients--a longitudinal observational study. Cardiovasc Diabetol. 2009;8:57. KQ1E6, KQ2E6, KQ6E3a. [pmid: 19878541].
194 Lewis HD, Davis JW, Archibald DG, et al. Protective effects of aspirin against acute myocardial infarction and death in men with unstable angina. N Engl J Med. Aug. 18. 1983;309(7):396-403. KQ1E3a, KQ2E5, KQ6E3a. [pmid: 6135989].
195 Liew G, Mitchell P, Wong TY, et al. The association of aspirin use with age-related macular degeneration. JAMA Intern Med. Jan. 21. 2013;173(4):258-64. KQ1E6, KQ2E6, KQ6E3b. [pmid: 23337937].
196 Liu W, Park Y, Purdue MP, et al. A large cohort study of nonsteroidal anti-inflammatory drugs and renal cell carcinoma incidence in the National Institutes of Health-AARP Diet and Health Study. Cancer Causes Control. Oct. 2013;24(10):1865-73. KQ1E6, KQ2E6, KQ6E3. [pmid: 23868221].
197 Manson JE, Stampfer MJ, Colditz GA, et al. A prospective study of aspirin use and primary prevention of cardiovascular disease in women. JAMA. Jul. 24. 1991;266(4):521-7. KQ1E6, KQ2E6. [pmid: 2061978].
198 Marra CA, Lynd LD, Colley L, et al. Risk of gastrointestinal events in patients with rheumatoid arthritis after withdrawal of rofecoxib. J Rheumatol. May. 2012;39(5):910-5. KQ1E6, KQ2E6, KQ6E3a. [pmid: 22422500].
199 Marshall SF, Bernstein L, Anton-Culver H, et al. Nonsteroidal anti-inflammatory drug use and breast cancer risk by stage and hormone receptor status. J Natl Cancer Inst. Jun. 1. 2005;97(11):805-12. KQ1E6, KQ2E6, KQ6E5. [pmid: 15928301].
200 McAlister FA, Ghali WA, Gong Y, et al. Aspirin use and outcomes in a community-based cohort of 7352 patients discharged after first hospitalization for heart failure. Circulation. Jun. 6. 2006;113(22):2572-8. KQ1E6, KQ2E6, KQ6E3. [pmid: 16735672].
201 McEwen LN, Karter AJ, Waitzfelder BE, et al. Predictors of mortality over 8 years in type 2 diabetic patients: Translating Research Into Action for Diabetes (TRIAD). Diabetes Care. Jun. 2012;35(6):1301-9. KQ1E6, KQ2E6, KQ6E5. [pmid: 22432119].
202 McNeil J, Tonkin A. The MAGIC Study and the gastrointestinal effects of low-dose aspirin : editorial to: “Prospective cohort study of gastrointestinal complications and vascular diseases in patients taking aspirin: rationale and design of the MAGIC Study” by H. Origasa et al. Cardiovasc Drug Ther. Dec. 2011;25(6):503-4. KQ1E6, KQ2E6, KQ6E6. [pmid: 22006010].
203 Meade TW, Wilkes HC, Stirling Y, et al. Randomized controlled trial of low dose warfarin in the primary prevention of ischaemic heart disease in men at high risk: design and pilot study. Eur Heart J. Aug. 1988;9(8):836-43. KQ1E3, KQ2E3, KQ6E3. [pmid: 3053176].
204 Meade TW, Roderick PJ, Brennan PJ, et al. Extra-cranial bleeding and other symptoms due to low dose aspirin and low intensity oral anticoagulation. Thromb Haemost. Jul. 6. 1992;68(1):1-6. KQ2E5. [pmid: 1514166].
205 Meade TW, Brennan PJ. Determination of who may derive most benefit from aspirin in primary prevention: subgroup results from a randomised controlled trial. BMJ. Jul. 1. 2000;321(7252):13-7. KQ1E5b, KQ2E5b, KQ6E5. [pmid: 10875825].
206 Miedema MD, Duprez DA, Misialek JR, et al. Use of coronary artery calcium testing to guide aspirin utilization for primary prevention: estimates from the multi-ethnic study of atherosclerosis. Circulation. May. 2014;7(3):453-60. KQ1E6, KQ2E6, KQ6E5. [pmid: 24803472].
207 Moon BG, Joe SG, Hwang JU, et al. Prevalence and risk factors of early-stage age-related macular degeneration in patients examined at a health promotion center in Korea. J Korean Med Sci. May. 2012;27(5):537-41. KQ1E3, KQ2E3, KQ6E3. [pmid: 22563220].
208 Mozafar M, Samsami M, Sobhiyeh MR, et al. Effectiveness of aspirin on double lumen permanent catheter efficacy in ESRD. Nephrourol Mon. 2013;5(2):762-5. KQ1E8, KQ2E8, KQ6E8. [pmid: 23841041].
209 Murphy MA, Trabert B, Yang HP, et al. Non-steroidal anti-inflammatory drug use and ovarian cancer risk: findings from the NIH-AARP Diet and Health Study and systematic review. Cancer Causes Control. Nov. 2012;23(11):1839-52. KQ1E6, KQ2E6, KQ6E5. [pmid: 22972000].
210 Nagata N, Niikura R, Aoki T, et al. Colonic diverticular hemorrhage associated with the use of NSAIDs, low-dose aspirin, antiplatelet drugs, and dual therapy. J Gastroenterol Hepatol. 2014. Apr. 10. KQ1E6, KQ2E6, KQ6E3. [pmid: 24720424].
211 Nelson M. Aspirin in the prevention of cancer. Lancet. 2011;377(9778):1650-1. KQ1E6, KQ2E6, KQ6E6. [pmid: 21571140].
212 Nelson MR, Reid CM, Ames DA, et al. Feasibility of conducting a primary prevention trial of low-dose aspirin for major adverse cardiovascular events in older people in Australia: results from the ASPirin in Reducing Events in the Elderly (ASPREE) pilot study. Med J Aust. Jul. 21. 2008;189(2):105-9. KQ2E5. [pmid: 18637782].
213 Nema H, Kato M, Katsurada T, et al. Endoscopic survey of low-dose-aspirin-induced gastroduodenal mucosal injuries in patients with ischemic heart disease. J Gastroenterol Hepatol. Dec. 2008;23(Suppl 2):S234-S236. KQ1E6, KQ2E6, KQ6E4. [pmid: 19120904].
214 Nema H, Kato M. Investigation of gastroduodenal mucosal injuries caused by low-dose aspirin therapy in patients with cerebral infarction. J Gastroenterol Hepatol. May. 2010;25. Suppl-21. KQ1E6, KQ2E6, KQ6E3. [pmid: 20586852].
215 Ng W, Wong WM, Chen WH, et al. Incidence and predictors of upper gastrointestinal bleeding in patients receiving low-dose aspirin for secondary prevention of cardiovascular events in patients with coronary artery disease. World J Gastroenterol. May. 14. 2006;12(18):2923-7. KQ1E6, KQ2E6, KQ6E3. [pmid: 16718820].
216 Njaman W, Miyauchi K, Kasai T, et al. Impact of aspirin treatment on long-term outcome (over 10 years) after percutaneous coronary intervention. Int Heart J. Jan. 2006;47(1):37-45. KQ1E6, KQ2E6, KQ6E3. [pmid: 16479039].
217 Ogawa H, Nakayama M, Morimoto T, et al. Low-dose aspirin for primary prevention of atherosclerotic events in patients with type 2 diabetes: a randomized controlled trial. JAMA. Nov. 12. 2008;300(18):2134-41. KQ2E5b. [pmid: 18997198].
218 Okada S, Morimoto T, Ogawa H, et al. Differential effect of low-dose aspirin for primary prevention of atherosclerotic events in diabetes management: a subanalysis of the JPAD trial. Diabetes Care. Jun. 2011;34(6):1277-83. KQ2E5b. [pmid: 21515838].
219 Olesen JB, Lip GY, Lindhardsen J, et al. Risks of thromboembolism and bleeding with thromboprophylaxis in patients with atrial fibrillation: A net clinical benefit analysis using a ‘real world’ nationwide cohort study. Thromb Haemost. Oct. 2011;106(4):739-49. KQ1E6, KQ2E6, KQ6E3. [pmid: 21789337].
220 Ong G, Davis TM, Davis WA. Aspirin is associated with reduced cardiovascular and all-cause mortality in type 2 diabetes in a primary prevention setting: the Fremantle Diabetes study. Diabetes Care. Feb. 2010;33(2):317-21. KQ1E6, KQ2E6, KQ6E5. [pmid: 19918016].
221 Ott MM, Eriksson E, Vanderkolk W, et al. Antiplatelet and anticoagulation therapies do not increase mortality in the absence of traumatic brain injury. J Trauma. Mar. 2010;68(3):560-3. KQ1E6, KQ2E6, KQ6E3. [pmid: 20065871].
222 Paganini-Hill A, Chao A, Ross RK, et al. Aspirin use and chronic diseases: a cohort study of the elderly. BMJ. Nov. 18. 1989;299(6710):1247-50. KQ1E6, KQ2E6, KQ6E3. [pmid: 2513898].
223 Pande RL, Perlstein TS, Beckman JA, et al. Secondary prevention and mortality in peripheral artery disease: National Health and Nutrition Examination Study, 1999 to 2004. Circulation. Jul. 5. 2011;124(1):17-23. KQ1E6, KQ2E6, KQ6E3. [pmid: 21690489].
224 Park H, Hildreth A, Thomson R, et al. Non-valvular atrial fibrillation and cognitive decline: a longitudinal cohort study. Age Ageing. Mar. 2007;36(2):157-63. KQ1E6, KQ2E6, KQ6E5. [pmid: 17259637].
225 Perahia DG, Bangs ME, Zhang Q, et al. The risk of bleeding with duloxetine treatment in patients who use nonsteroidal anti-inflammatory drugs (NSAIDs): analysis of placebo-controlled trials and post-marketing adverse event reports. Drug Healthcare & Patient Safety. 2013;5:211-9. KQ1E6, KQ2E6, KQ6E3. [pmid: 24348072].
226 Petersen P, Boysen G, Godtfredsen J, et al. Placebo-controlled, randomised trial of warfarin and aspirin for prevention of thromboembolic complications in chronic atrial fibrillation. The Copenhagen AFASAK study. Lancet. Jan. 28. 1989;1(8631):175-9. KQ2E5. [pmid: 2563096].
227 Pinheiro SP, Tworoger SS, Cramer DW, et al. Use of nonsteroidal antiinflammatory agents and incidence of ovarian cancer in 2 large prospective cohorts. Am J Epidemiol. Jun. 1. 2009;169(11):1378-87. KQ1E6, KQ2E6, KQ6E5. [pmid: 19342401].
228 Platz EA, Rohrmann S, Pearson JD, et al. Nonsteroidal anti-inflammatory drugs and risk of prostate cancer in the Baltimore Longitudinal Study of Aging. Cancer Epidemiol Biomarkers Prev. Feb. 2005;14(2):390-6. KQ1E6, KQ2E6, KQ6E5. [pmid: 15734963].
229 Posada IS, Barriales V. Alternate-day dosing of aspirin in atrial fibrillation. LASAF Pilot Study Group. Am Heart J. Jul. 1999;138(1 Pt 1):137-43. KQ1E10, KQ2E10, KQ6E10. [pmid: 10385777].
230 Pradhan AD, Cook NR, Manson JE, et al. A randomized trial of low-dose aspirin in the prevention of clinical type 2 diabetes in women. Diabetes Care. Jan. 2009;32(1):3-8. KQ1E5, KQ2E5, KQ6E5. [pmid: 18835953].
231 Rahme E, Nedjar H. Risks and benefits of COX-2 inhibitors vs non-selective NSAIDs: does their cardiovascular risk exceed their gastrointestinal benefit? A retrospective cohort study. Rheumatology. Mar. 2007;46(3):435-8. KQ1E6, KQ2E6, KQ6E3. [pmid: 17255138].
232 Rahme E, Bardou M, Dasgupta K, et al. Hospitalization for gastrointestinal bleeding associated with non-steroidal anti-inflammatory drugs among elderly patients using low-dose aspirin: a retrospective cohort study. Rheumatology. Feb. 2007;46(2):265-72. KQ1E6, KQ2E6, KQ6E4. [pmid: 16844699].
233 Rahme E, Nedjar H, Bizzi A, et al. Hospitalization for gastrointestinal adverse events attributable to the use of low-dose aspirin among patients 50 years or older also using non-steroidal anti-inflammatory drugs: a retrospective cohort study. Aliment Pharmacol Ther. Nov. 15. 2007;26(10):1387-98. KQ1E6, KQ2E6, KQ6E3. [pmid: 17892525].
234 Ratnasinghe LD, Graubard BI, KAHLE LISA, et al. Aspirin Use and Mortality from Cancer in a Prospective Cohort Study. Anticancer Res. Sep. 1. 2004;24(5B):3177-84. KQ1E6, KQ2E6, KQ6E3b. [pmid: 15510608].
235 Razzak M. Prostate cancer: Is aspirin a wonder drug in prostate cancer?. Nat Rev Urol. 2012. Sep. 18. KQ1E6, KQ2E6, KQ6E6. [pmid: 22986499].
236 Razzouk L, Mathew V, Lennon RJ, et al. Aspirin use is associated with an improved long-term survival in an unselected population presenting with unstable angina. Clin Cardiol. Sep. 2010;33(9):553-8. KQ1E6, KQ2E6, KQ6E5. [pmid: 20842739].
237 Ready A, Velicer CM, McTiernan A, et al. NSAID use and breast cancer risk in the VITAL cohort. Breast Cancer Res Treat. Jun. 2008;109(3):533-43. KQ1E6, KQ2E6, KQ6E5. [pmid: 17674199].
238 Rich JD, Cannon CP, Murphy SA, et al. Prior aspirin use and outcomes in acute coronary syndromes. J Am Coll Cardiol. Oct. 19. 2010;56(17):1376-85. KQ1E6, KQ2E6, KQ6E3a. [pmid: 20946994].
239 Richard E, Kuiper R, Dijkgraaf MG, et al. Vascular care in patients with Alzheimer's disease with cerebrovascular lesions-a randomized clinical trial. J Am Geriatr Soc. May. 2009;57(5):797-805. KQ1E3, KQ2E3, KQ6E3. [pmid: 19484836].
240 Río-Solá ML, Antonio J, Fajardo G, et al. Influence of aspirin therapy in the ulcer associated with chronic venous insufficiency. Ann Vasc Surg. 2012;26(5):620-9. KQ1E5, KQ2E5, KQ6E5. [pmid: 22437068].
241 Rosenberg L. Nonsteroidal anti-inflammatory drugs and cancer. Prev Med. Mar. 1995;24(2):107-9. KQ1E6, KQ2E6, KQ6E6. [pmid: 7597007].
242 Rothwell PM, Fowkes FG, Belch JF, et al. Effect of daily aspirin on long-term risk of death due to cancer: analysis of individual patient data from randomised trials. Lancet. 2011;377(9759):31-41. KQ2E5, KQ6E5. [pmid: 21144578].
243 Ruder EH, Laiyemo AO, Graubard BI, et al. Non-steroidal anti-inflammatory drugs and colorectal cancer risk in a large, prospective cohort. Am J Gastroenterol. 2011;106(7):1340-50. KQ1E6, KQ2E6, KQ6E5. [pmid: 21407185].
244 Sahasrabuddhe VV, Gunja MZ, Graubard BI, et al. Nonsteroidal anti-inflammatory drug use, chronic liver disease, and hepatocellular carcinoma. J Natl Cancer Inst. Dec. 5. 2012;104(23):1808-14. KQ1E6, KQ2E6, KQ6E5. [pmid: 23197492].
245 Saito Y, Morimoto T, Ogawa H, et al. Low-dose aspirin therapy in patients with type 2 diabetes and reduced glomerular filtration rate: subanalysis from the JPAD trial. Diabetes Care. Feb. 2011;34(2):280-5. KQ2E5. [pmid: 21270185].
246 Sato H, Ishikawa K, Kitabatake A, et al. Low-dose aspirin for prevention of stroke in low-risk patients with atrial fibrillation: Japan Atrial Fibrillation Stroke Trial. Stroke. Feb. 2006;37(2):447-51. KQ2E5. [pmid: 16385088].
247 Schenk JM, Calip GS, Tangen CM, et al. Indications for and use of nonsteroidal antiinflammatory drugs and the risk of incident, symptomatic benign prostatic hyperplasia: results from the prostate cancer prevention trial. Am J Epidemiol. Jul. 15. 2012;176(2):156-63. KQ1E6, KQ2E6, KQ6E5. [pmid: 22759721].
248 Schmiedl S, Rottenkolber M, Hasford J, et al. Self-medication with over-the-counter and prescribed drugs causing adverse-drug-reaction-related hospital admissions: results of a prospective, long-term multi-centre study. Drug Saf. Apr. 2014;37(4):225-35. KQ1E6, KQ2E6, KQ6E6. [pmid: 24550104].
249 Schreinemachers DM, Everson RB. Aspirin use and lung, colon, and breast cancer incidence in a prospective study. Epidemiology. Mar. 1994;5(2):138-46. KQ1E6, KQ2E6, KQ6E5. [pmid: 8172988].
250 Sciahbasi A, Rizzello V, Gonzini L, et al. Chronic aspirin and statin therapy in patients with impaired renal function and acute coronary syndromes: results from the IN-ACS Outcome Registry. Eur J Prev Cardiol. 2012. Sep. 5. KQ1E6, KQ2E6, KQ6E3. [pmid: 22952286].
251 Selak V, Elley CR, Crengle S, et al. IMProving Adherence using Combination Therapy (IMPACT): design and protocol of a randomised controlled trial in primary care. Contemp Clin Trials. Nov. 2011;32(6):909-15. KQ1E5, KQ2E5, KQ6E5. [pmid: 21777702].
252 Selak V, Elley CR, Bullen C, et al. Effect of fixed dose combination treatment on adherence and risk factor control among patients at high risk of cardiovascular disease: randomised controlled trial in primary care. BMJ. 2014;348:g3318. KQ1E4, KQ2E5, KQ6E4. [pmid: 24868083].
253 Seshasai SR, Wijesuriya S, Sivakumaran R, et al. Effect of aspirin on vascular and nonvascular outcomes: meta-analysis of randomized controlled trials. Arch Intern Med. Feb. 13. 2012;172(3):209-16. KQ1E5, KQ6E5. [pmid: 22231610].
254 Shih C, Hotaling JM, Wright JL, et al. Long-term NSAID use and incident urothelial cell carcinoma in the VITamins and Lifestyle (VITAL) study. Urol Oncol. 2012. Jul. 11. KQ1E6, KQ2E6, KQ6E5. [pmid: 22795502].
255 Silagy CA, McNeil JJ, Donnan GA, et al. Adverse effects of low-dose aspirin in a healthy elderly population. Clin Pharmacol Ther. Jul. 1993;54(1):84-9. KQ1E5, KQ2E5. [pmid: 8330469].
256 Sirois C, Moisan J, Poirier P, et al. Myocardial infarction and gastro-intestinal bleeding risks associated with aspirin use among elderly individuals with type 2 diabetes. Ann Med. 2014. May. 2. KQ1E6, KQ2E6, KQ6E6. [pmid: 24785356].
257 Sitthi-Amorn C. A randomized trial of aspirin in chronic rheumatic heart disease. Unpublished. 2013. PMID: None. KQ1E11, KQ2E11, KQ6E11.
258 Sjalander S, Sjalander A, Svensson PJ, et al. Atrial fibrillation patients do not benefit from acetylsalicylic acid. Europace. 2013. Oct. 24. KQ1E6, KQ2E6, KQ6E3. [pmid: 24158253].
259 Slatore CG, Au DH, Littman AJ, et al. Association of nonsteroidal anti-inflammatory drugs with lung cancer: results from a large cohort study. Cancer Epidemiol Biomarkers Prev. Apr. 2009;18(4):1203-7. KQ1E6, KQ2E6, KQ6E5. [pmid: 19293309].
260 Slattery J, Warlow CP, Shorrock CJ, et al. Risks of gastrointestinal bleeding during secondary prevention of vascular events with aspirin--analysis of gastrointestinal bleeding during the UK-TIA trial. Gut. Oct. 1995;37(4):509-11. KQ2E5. [pmid: 7489937].
261 Smith J, Siddiq S, Dyer C, et al. Epistaxis in patients taking oral anticoagulant and antiplatelet medication: prospective cohort study. J Laryngol Otol. Jan. 2011;125(1):38-42. KQ1E6, KQ2E6, KQ6E6. [pmid: 20843406].
262 Snygg-Martin U, Rasmussen RV, Hassager C, et al. The relationship between cerebrovascular complications and previously established use of antiplatelet therapy in left-sided infective endocarditis. Scand J Infect Dis. Dec. 2011;43(11-12):899-904. KQ1E6, KQ2E6, KQ6E3. [pmid: 21916774].
263 Soejima H, Ogawa H, Morimoto T, et al. Aspirin reduces cerebrovascular events in type 2 diabetic patients with poorly controlled blood pressure. Subanalysis from the JPAD trial. Circ J. 2012;76(6):1526-32. KQ2E5. [pmid: 22447019].
264 Sorensen HT, Mellemkjaer L, Blot WJ, et al. Risk of upper gastrointestinal bleeding associated with use of low-dose aspirin. Am J Gastroenterol. Sep. 2000;95(9):2218-24. KQ1E6, KQ2E6, KQ6E3. [pmid: 11007221].
265 Sorensen PS, Pedersen H, Marquardsen J, et al. Acetylsalicylic acid in the prevention of stroke in patients with reversible cerebral ischemic attacks. A Danish cooperative study. Stroke. Jan. 1983;14(1):15-22. KQ1E10, KQ2E10, KQ6E10. [pmid: 6337425].
266 Sreedhara R, Himmelfarb J, Lazarus JM, et al. Anti-platelet therapy in graft thrombosis: results of a prospective, randomized, double-blind study. Kidney Int. May. 1994;45(5):1477-83. KQ1E2, KQ2E2, KQ6E2. [pmid: 8072261].
267 Stampfer MJ, Buring JE, Willett W, et al. The 2 × 2 factorial design: its application to a randomized trial of aspirin and carotene in U.S. physicians. Stat Med. Apr. 1985;4(2):111-6. KQ2E5. [pmid: 4023472].
268 Strandberg TE, Pitkala K, Berglind S, et al. Multifactorial cardiovascular prevention in patients aged 75 and older: design and baseline results of a randomized controlled trial (DEBATE Study). Eur Heart J. 2001;22(Suppl):460. PMID: None. KQ1E5, KQ2E5, KQ6E5.
269 Strate LL, Liu YL, Huang ES, et al. Use of aspirin or nonsteroidal anti-inflammatory drugs increases risk for diverticulitis and diverticular bleeding. Gastroenterology. May. 2011;140(5):1427-33. KQ1E6, KQ2E6. [pmid: 21320500].
270 Sturmer T, Glynn RJ, Lee IM, et al. Aspirin use and colorectal cancer: post-trial follow-up data from the Physicians' Health Study. Ann Intern Med. May. 1. 1998;128(9):713-20. KQ2E5. [pmid: 9556464].
271 Sturmer T, Buring JE, Lee IM, et al. Colorectal cancer after start of nonsteroidal anti-inflammatory drug use. Am J Med. Jun. 2006;119(6):494-502. KQ1E6, KQ2E6, KQ6E3b. [pmid: 16750963].
272 Sutcliffe S, Grubb Iii RL, Platz EA, et al. Non-steroidal anti-inflammatory drug use and the risk of benign prostatic hyperplasia-related outcomes and nocturia in the Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial. BJU Int. Oct. 2012;110(7):1050-9. KQ1E6, KQ2E6, KQ6E5. [pmid: 22429766].
273 Teramoto T, Shimada K, Uchiyama S, et al. Rationale, design, and baseline data of the Japanese Primary Prevention Project (JPPP)-a randomized, open-label, controlled trial of aspirin versus no aspirin in patients with multiple risk factors for vascular events. Am Heart J. Mar. 2010;159(3):361-9. KQ1E4, KQ2E4, KQ6E4. [pmid: 20211296].
274 The Salt Collaborative Group. Swedish Aspirin Low-dose Trial (SALT) of 75 mg aspirin as secondary prophylaxis after cerebrovascular ischaemic events. The Lancet. Nov. 30. 1991;338(8779):1345-9. KQ2E3. [pmid: 1682734].
275 Thomsen SF, Kyvik KO, Skadhauge LR, et al. Regular use of non-steroidal anti-inflammatory drugs increases the risk of adult-onset asthma: a population-based follow-up study. Clin Respir J. Apr. 2009;3(2):82-4. KQ1E6, KQ2E6, KQ6E2. [pmid: 20298382].
276 Thun MJ, Namboodiri MM, Calle EE, et al. Aspirin use and risk of fatal cancer. Cancer Res. Mar. 15. 1993;53(6):1322-7. KQ1E6, KQ2E6, KQ6E5. [pmid: 8443812].
277 Toulouse TIA, Guiraud-Chaumeil B, Rascol A, et al. Prevention des recideives des accidents vasculairs cerebraux ischmiques par les anti-agregants plaquettaires. Rev Neurol (Paris). 1982;138:367-85. PMID: None. KQ1E9, KQ2E9, KQ6E9. [pmid: 6815756].
278 Turpie AG, Gent M, Laupacis A, et al. A comparison of aspirin with placebo in patients treated with warfarin after heart-valve replacement. N Engl J Med. Aug. 19. 1993;329(8):524-9. KQ1E3, KQ2E3, KQ6E3. [pmid: 8336751].
279 Uemura N, Sugano K, Hiraishi H, et al. Risk factor profiles, drug usage, and prevalence of aspirin-associated gastroduodenal injuries among high-risk cardiovascular Japanese patients: the results from the MAGIC study. J Gastroenterol. 2013. Jun. 12. KQ1E6, KQ2E6, KQ6E6. [pmid: 23754512].
280 Uk-Tia Study Group. United Kingdom transient ischaemic attack (UK-TIA) aspirin trial: interim results. BMJ. Jan. 30. 1988;296(6618):316-20. KQ2E5. [pmid: 2894232].
281 Vaughan TL, Dong LM, Blount PL, et al. Non-steroidal anti-inflammatory drugs and risk of neoplastic progression in Barrett's oesophagus: a prospective study. Lancet Oncol. Dec. 2005;6(12):945-52. KQ1E6, KQ2E6, KQ6E3. [pmid: 16321762].
282 Vernooij MW, Haag MD, van der Lugt A, et al. Use of antithrombotic drugs and the presence of cerebral microbleeds: the Rotterdam Scan Study. Arch Neurol. Jun. 2009;66(6):714-20. KQ1E6, KQ2E6, KQ6E3. [pmid: 19364926].
283 Vestergaard P, Hermann P, Jensen JE, et al. Effects of paracetamol, non-steroidal anti-inflammatory drugs, acetylsalicylic acid, and opioids on bone mineral density and risk of fracture: results of the Danish Osteoporosis Prevention Study (DOPS). Osteoporos Int. Apr. 2012;23(4):1255-65. KQ1E6, KQ2E6, KQ6E5. [pmid: 21710339].
284 Visser J, Ulander VM, Helmerhorst FM, et al. Thromboprophylaxis for recurrent miscarriage in women with or without thrombophilia. HABENOX: a randomised multicentre trial. Thromb Haemost. Feb. 2011;105(2):295-301. KQ1E2, KQ2E2, KQ6E2. [pmid: 21103659].
285 Vogel G, Fischer C, Huyke R. Prevention of reinfarction with acetylsalicylic acid. Prophylaxis of venous peripheral cardiac and cerebral vascular diseases with acetylsalicylic acid. Stuttgart. Schattauer. 1981:123-8. PMID: None. KQ1E9, KQ2E9, KQ6E9.
286 Wald NJ, Morris JK, Law MR. Aspirin in the prevention of cancer. Lancet. May. 14. 2011;377(9778):1649-2. KQ1E6, KQ2E6, KQ6E6. [pmid: 21571138].
287 Wallentin LC. Aspirin (75 mg/day) after an episode of unstable coronary artery disease: long-term effects on the risk for myocardial infarction, occurrence of severe angina and the need for revascularization. Research Group on Instability in Coronary Artery Disease in Southeast Sweden. J Am Coll Cardiol. Dec. 1991;18(7):1587-93. KQ1E3d, KQ2E3d, KQ6E3d. [pmid: 1960301].
288 Walter RB, Milano F, Brasky TM, et al. Long-term use of acetaminophen, aspirin, and other nonsteroidal anti-inflammatory drugs and risk of hematologic malignancies: results from the prospective Vitamins and Lifestyle (VITAL) study. J Clin Oncol. Jun. 10. 2011;29(17):2424-31. KQ1E6, KQ2E6, KQ6E5. [pmid: 21555699].
289 Wang JJ, Mitchell P, Smith W, et al. Systemic use of anti-inflammatory medications and age-related maculopathy: the Blue Mountains Eye Study. Ophthalmic Epidemiol. Feb. 2003;10(1):37-48. KQ1E3a, KQ2E3a, KQ6E3a. [pmid: 12607158].
290 Wang TY, Xiao L, Alexander KP, et al. Antiplatelet therapy use after discharge among acute myocardial infarction patients with in-hospital bleeding. Circulation. Nov. 18. 2008;118(21):2139-45. KQ1E6, KQ2E6, KQ6E5. [pmid: 18981304].
291 Wayne EJ, Brier ME, Dwyer AC. Association of maturation period blood pressure with dialysis access patency. Semin Dial. Jan. 2013;26(1):90-6. KQ1E6, KQ2E6, KQ6E2. [pmid: 22452617].
292 Wei L, Fahey T, MacDonald TM. Adherence to statin or aspirin or both in patients with established cardiovascular disease: exploring healthy behaviour vs. drug effects and 10-year follow-up of outcome. Br J Clin Pharmacol. Jul. 2008;66(1):110-6. KQ1E6, KQ2E6, KQ6E4. [pmid: 18492127].
293 Welin L, Wilhelmsen L, Bjornberg A, et al. Aspirin increases mortality in diabetic patients without cardiovascular disease: a Swedish record linkage study. Pharmacoepidemiol Drug Saf. Dec. 2009;18(12):1143-9. KQ1E6, KQ2E6, KQ6E3. [pmid: 19672841].
294 White E, Patterson RE, Kristal AR, et al. VITamins And Lifestyle cohort study: study design and characteristics of supplement users. Am J Epidemiol. Jan. 1. 2004;159(1):83-93. KQ1E6, KQ2E6, KQ6E5. [pmid: 14693663].
295 Winning J, Neumann J, Kohl M, et al. Antiplatelet drugs and outcome in mixed admissions to an intensive care unit. Crit Care Med. Jan. 2010;38(1):32-7. KQ1E6, KQ2E6, KQ6E3. [pmid: 19770746].
296 Yamamoto T, Mishina Y, Ebato T, et al. Prevalence of erosive esophagitis among Japanese patients taking low-dose aspirin. J Gastroenterol Hepatol. Apr. 2010;25(4):792-4. KQ1E3a, KQ2E3a, KQ6E3a. [pmid: 20074160].
297 Yamane K, Ikeda T, Taniguchi R, et al. Impact of platelet reactivity on long-term clinical outcomes and bleeding events in Japanese patients receiving antiplatelet therapy with aspirin. J Atheroscler Thromb. 2012;19(12):1142-53. KQ1E6, KQ2E6, KQ6E3. [pmid: 22878699].
298 Yuan Z, Weinstein R, Zhang J, et al. Antithrombotic therapies in patients with heart failure: hypothesis formulation from a research database. Pharmacoepidemiol Drug Saf. Sep. 2010;19(9):911-20. KQ1E6, KQ2E6, KQ6E3. [pmid: 20602345].
299 Yusuf SW, Daraban N, Abbasi N, et al. Treatment and outcomes of acute coronary syndrome in the cancer population. Clin Cardiol. 2012;35(7):443-50. KQ1E6, KQ2E6, KQ6E2. [pmid: 22588943].
300 Zell JA, Ziogas A, Bernstein L, et al. Meat consumption, nonsteroidal anti-inflammatory drug use, and mortality among colorectal cancer patients in the California Teachers Study. Cancer Prev Res (Phila). Jul. 2010;3(7):865-75. KQ1E6, KQ2E6, KQ6E2. [pmid: 20551290].
301 Zhang X, Smith-Warner SA, Collins LC, et al. Use of aspirin, other nonsteroidal anti-inflammatory drugs, and acetaminophen and postmenopausal breast cancer incidence. J Clin Oncol. Oct. 1. 2012;30(28):3468-77. KQ1E6, KQ2E6, KQ6E5. [pmid: 22927520].