# Detailed Methods

## Literature Search Strategies – Systematic Reviews (benefits)

### Cochrane Database of Systematic Reviews

#1 Gastrointestinal next Neoplasm*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#2 Gastrointestinal next cancer*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#3 Gastrointestinal next tumor*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#4 Gastrointestinal next tumour*:ti,ab,kw from 2008 to 2013
#5 gastric next neoplasm*:ti,ab,kw from 2008 to 2013
#6 gastric next cancer*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#7 gastric next tumor*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#8 gastric next tumour*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#9 gastric next carcinoma*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#10 gastric next adenocarcinoma*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#11 Esophageal next Neoplasm*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#12 Esophageal next cancer*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#13 Esophageal next tumor*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#14 Esophageal next tumour*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#15 Esophageal next carcinoma*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#16 oesophageal next cancer*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#17 oesophageal next neoplasm*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#18 oesophageal next tumor*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#19 oesophageal next tumour*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#20 oesophageal next carcinoma*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#21 Intestinal next Neoplasm*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#22 Intestinal next cancer*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#23 Intestinal next tumor*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#24 Intestinal next tumour*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#25 Duodenal next Neoplasm*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#26 Duodenal nex cancer*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#27 Duodenal next tumor*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#28 Duodenal next tumour*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#29 Ileal next Neoplasm*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#30 Ileal next cancer*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#31 Ileal next tumor*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#32 Ileal next tumour*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#33 Jejunal next Neoplasm*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#34 Jejunal next cancer*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#35 Jejunal next tumor*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#36 Jejunal next tumour*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#37 Stomach next Neoplasm*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#38 Stomach next cancer*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#39 Stomach next tumor*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#40 Stomach next tumour*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#41 breast next Neoplasm*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#42 breast next cancer*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#43 breast next tumor*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#44 breast next tumour*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#45 breast next carcinoma*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#46 lung next Neoplasm*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#47 lung next cancer*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#48 lung next tumor*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#49 lung next tumour*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#50 lung next carcinoma*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#51 lung next adenocarcinoma*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#52 Bronchial next Neoplasm*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#53 Bronchial next cancer*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#54 Bronchial next tumor*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#55 Bronchial next tumour*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#56 prostat* next neoplasm*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#57 prostat* next cancer*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#58 prostat* next tumor*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#59 prostat* next tumour*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#60 prostat* next carcinoma*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#61 Pancreatic next neoplasm*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#62 Pancreatic next cancer*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#63 Pancreatic next tumor*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#64 Pancreatic next tumour*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#65 Pancreatic next carcinoma*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#66 Pancreatic next adenocarcinoma*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#67 or #1-#66 from 2008 to 2013, in Cochrane Reviews
#68 Aspirin:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#69 “acetylsalicylic acid”:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#70 Salicylate*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews
#71 #68 or #69 or #70 from 2008 to 2013, in Cochrane Reviews
#72 #67 and #71 from 2008 to 2013, in Cochrane Reviews

### DARE

1. (neoplasm*) OR (cancer*) OR (tumor*) OR (tumour*) OR (carcinoma*)
2. (adenocarcinoma*)
3. #1 OR #2
4. (Gastrointestinal ) OR (gastric ) OR (Esophageal ) OR (oesophageal ) OR (Intestinal ) FROM 2008 TO 2013
5. (Duodenal ) OR (Ileal) OR (Jejunal) OR (Stomach) OR (breast) FROM 2008 TO 2013
6. (lung) OR (Bronchial) OR (prostat*) OR (Pancreatic ) FROM 2008 TO 2013
7. #4 OR #5 OR #6
8. #3 AND #7
9. (prevent*) IN DARE FROM 2008 TO 2013
10. #8 AND #9

### HTA

1. (neoplasm*) OR (cancer*) OR (tumor*) OR (tumour*) OR (carcinoma*)
2. (adenocarcinoma*)
3. #1 OR #2
4. (Gastrointestinal ) OR (gastric ) OR (Esophageal ) OR (oesophageal ) OR (Intestinal ) FROM 2008 TO 2013
5. (Duodenal ) OR (Ileal) OR (Jejunal) OR (Stomach) OR (breast) FROM 2008 TO 2013
6. (lung) OR (Bronchial) OR (prostat*) OR (Pancreatic ) FROM 2008 TO 2013
7. #4 OR #5 OR #6
8. #3 AND #7
9. (prevent*) IN HTA FROM 2008 TO 2013
10. #8 AND #9

### PubMed

#20 #9 OR #16 OR #17 OR #18 Filters: Publication date from 2008/01/01; English
#19 #9 OR #16 OR #17 OR #18
#18 aspirin[ti] AND cancer[ti] AND (gastrointestinal[ti] OR breast[ti] OR lung[ti] OR prostat*[ti] OR pancreatic[ti] OR gastric[ti]) AND systematic[sb]
#17 #6 AND aspirin[tiab] AND #8 AND systematic[sb]
#16 #12 AND #13 AND #14 AND systematic[sb] AND (publisher[sb] OR in process[sb] OR pubmednotmedline[sb])
#15 #12 AND #13 AND #14 AND systematic[sb]
#14 prevent*[tiab]
#13 Aspirin[tiab] OR “acetylsalicylic acid”[tiab] OR Salicylate*[tiab]
#12 #10 OR #11
#11 (breast[tiab] OR lung[tiab] OR Bronchial[tiab] OR prostat*[tiab] OR Pancreatic[tiab]) AND (Neoplasm*[tiab] OR cancer*[tiab] OR tumor[tiab] OR tumors[tiab] OR tumour*[tiab] OR carcinoma*[tiab] OR adenocarcinoma*[tiab])
#10 (Gastrointestinal[tiab] OR gastric[tiab] OR Esophageal[tiab] OR oesophageal[tiab] OR Intestinal[tiab] OR Duodenal[tiab] OR Ileal[tiab] OR Jejunal[tiab] OR Stomach[tiab]) AND (Neoplasm*[tiab] OR cancer*[tiab] OR tumor[tiab] OR tumors[tiab] OR tumour*[tiab] OR carcinoma*[tiab] OR adenocarcinoma*[tiab])
#9 #6 AND #7 AND #8 AND systematic[sb]
#8 “prevention and control” [Subheading] OR prevent*[tiab]
#7 “Aspirin”[Mesh] OR “Salicylates”[Mesh:NoExp]
#6 #1 OR #2 OR #3 OR #4 OR #5
#5 “Prostatic Neoplasms”[Mesh] OR “Pancreatic Neoplasms”[Mesh:NoExp]
#4 “Lung Neoplasms”[Mesh:NoExp] OR “Bronchial Neoplasms”[Mesh:NoExp] OR “Carcinoma, Bronchogenic”[Mesh:NoExp] OR “Carcinoma, Non-Small-Cell Lung”[Mesh] OR “Small Cell Lung Carcinoma”[Mesh]
#3 “Breast Neoplasms”[Mesh:NoExp] OR “Breast Neoplasms, Male”[Mesh] OR “Carcinoma, Ductal, Breast”[Mesh] OR “Inflammatory Breast Neoplasms”[Mesh]
#2 “Duodenal Neoplasms”[Mesh] OR “Ileal Neoplasms”[Mesh] OR “Jejunal Neoplasms”[Mesh] OR “Stomach Neoplasms”[Mesh]
#1 “Gastrointestinal Neoplasms”[Mesh:NoExp] OR “Esophageal Neoplasms”[Mesh:NoExp] OR “Gastrointestinal Stromal Tumors”[Mesh] OR “Intestinal Neoplasms”[Mesh:NoExp]

## Literature Search Strategies – Systematic Reviews (harms)

### PubMed

#1 “Aspirin/adverse effects”[Mesh] AND systematic[sb] Filters: Publication date from 2008/01/01; English
#2 “Platelet Aggregation Inhibitors/adverse effects”[Majr] AND (aspirin[tiab] OR “acetylsalicylic acid”[tiab]) AND systematic[sb] Filters: Publication date from 2008/01/01; English
#3 “Aspirin”[Majr] AND (safety[tiab] OR harm*[tiab] OR adverse[tiab] OR gastrointestinal[tiab] OR bleed*[tiab] or hemorrhag*[tiab] OR haemorrhag*[tiab]) AND systematic[sb] Filters: Publication date from 2008/01/01; English
#4 ((aspirin[tiab] OR “acetylsalicylic acid”[tiab]) AND (safety[tiab] OR harm*[tiab] OR adverse[tiab] OR gastrointestinal[tiab] OR bleed*[tiab] or hemorrhag*[tiab] OR haemorrhag*[tiab]) AND (in process[sb] OR publisher[sb] OR pubmednotmedline[sb]) AND systematic[sb]) NOT “Clin Evid (Online)”[jour] Filters: Publication date from 2008/01/01; English
#5 #1 OR #2 OR #3 OR #4 = 187

### Cochrane Database of Systematic Reviews

#1 aspirin:ti from 2008 to 2013, in Cochrane Reviews (Reviews only)
#2 “acetylsalicylic acid”:ti from 2008 to 2013, in Cochrane Reviews (Reviews only)
#3 Platelet next Aggregation next Inhibit*:ti from 2008 to 2013, in Cochrane Reviews (Reviews only)
#4 #1 or #2 or #3 from 2008 to 2013, in Cochrane Reviews (Reviews only)
#5 safety:ti,ab,kw from 2008 to 2013, in Cochrane Reviews (Reviews only)
#6 adverse:ti,ab,kw from 2008 to 2013, in Cochrane Reviews (Reviews only)
#7 harm*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews (Reviews only)
#8 gastrointestinal:ti,ab,kw from 2008 to 2013, in Cochrane Reviews (Reviews only)
#9 bleed*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews (Reviews only)
#10 hemorrhag*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews (Reviews only)
#11 haemorrhag*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews (Reviews only)
#12 #5 or #6 or #7 or #8 or #9 or #10 or #11 from 2008 to 2013, in Cochrane Reviews (Reviews only)
#13 #4 and #12 from 2008 to 2013, in Cochrane Reviews (Reviews only) = 12

### DARE

1. (aspirin):TI OR (acetylsalicylic acid):TI IN DARE FROM 2008 TO 2013
2. (safety) OR (adverse) OR (harm*) OR (gastrointestinal) IN DARE FROM 2008 TO 2013
3. (bleed*) OR (hemorrhag*) OR (haemorrhag*) IN DARE FROM 2008 TO 2013
4. #2 OR #3
5. #1 AND #4 = 46 total (only 4 non-duplicates from PubMed or CDSR)

## Literature Search Strategies – Primary Literature (benefits)

### MEDLINE

1. Gastrointestinal Neoplasms/ ()
2. Esophageal Neoplasms/ ()
3. Gastrointestinal Stromal Tumors/ ()
4. Intestinal Neoplasms/ ()
5. Duodenal Neoplasms/ ()
6. Ileal Neoplasms/ ()
7. Jejunal Neoplasms/ ()
8. Stomach Neoplasms/ ()
9. Breast Neoplasms/ ()
10. Breast Neoplasms, Male/ ()
11. Carcinoma, Ductal, Breast/ ()
12. Inflammatory Breast Neoplasms/ ()
13. Lung Neoplasms/ ()
14. Bronchial Neoplasms/ ()
15. Carcinoma, Bronchogenic/ ()
16. Carcinoma, Non-Small-Cell Lung/ ()
17. Small Cell Lung Carcinoma/ ()
18. Prostatic Neoplasms/ ()
19. Pancreatic Neoplasms/ ()
20. gastrointestinal.ti,ab. ()
21. gastric.ti,ab. ()
22. esophageal.ti,ab. ()
23. esophagus.ti,ab. ()
24. oesophageal.ti,ab. ()
25. intestinal.ti,ab. ()
26. duodenal.ti,ab. ()
27. ileal.ti,ab. ()
28. jejunal.ti,ab. ()
29. stomach.ti,ab. ()
30. breast.ti,ab. ()
31. lung.ti,ab. ()
32. bronchia$.ti,ab. ()
33. prostat$.ti,ab. ()
34. (pancreas or pancreatic).ti,ab. ()
35. 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 ()
36. (neoplasm$ or cancer$ or tumor$ or tumour$ or carcinoma$ or adenocarcinoma$).ti,ab. ()
37. 35 and 36 ()
38. (neoplasm$ or cancer$ or tumor$ or tumour$ or carcinoma$ or adenocarcinoma$).ti. ()
39. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 37 or 38 ()
40. Aspirin/ ()
41. Salicylates/ ()
42. (Aspirin or acetylsalicylic acid or Salicylate$).ti,ab. ()
43. 40 or 41 or 42 ()
44. 39 and 43 ()
45. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ ()
46. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt. ()
47. Random$.ti,ab. ()
48. control groups/ or double-blind method/ or single-blind method/ ()
49. clinical trial$.ti,ab. ()
50. controlled trial$.ti,ab. ()
51. meta analy$.ti,ab. ()
52. 45 or 46 or 47 or 48 or 49 or 50 or 51 ()
53. 44 and 52 ()
54. limit 53 to (english language and yr=“2011 -Current”) ()
55. remove duplicates from 54 ()

### Cochrane Central Register of Controlled Clinical Trials (http://www.thecochranelibrary.com/) (CENTRAL)

#1 Gastrointestinal next neoplasm*:ti,ab,kw from 2011 to 2014, in Trials
#2 Gastrointestinal next cancer*:ti,ab,kw from 2011 to 2014, in Trials
#3 Gastrointestinal next tumor*:ti,ab,kw from 2011 to 2014, in Trials
#4 Gastrointestinal next tumour*:ti,ab,kw from 2011 to 2014, in Trials
#5 Gastrointestinal next carcinoma*:ti,ab,kw from 2011 to 2014, in Trials
#6 Gastrointestinal next adenocarcinoma*:ti,ab,kw from 2011 to 2014, in Trials
#7 gastric next neoplasm*:ti,ab,kw from 2011 to 2014, in Trials
#8 gastric next cancer*:ti,ab,kw from 2011 to 2014, in Trials
#9 gastric next tumor*:ti,ab,kw from 2011 to 2014, in Trials
#10 gastric next tumour*:ti,ab,kw from 2011 to 2014, in Trials
#11 gastric next carcinoma*:ti,ab,kw from 2011 to 2014, in Trials
#12 gastric next adenocarcinoma*:ti,ab,kw from 2011 to 2014, in Trials
#13 Esophageal next neoplasm*:ti,ab,kw from 2011 to 2014, in Trials
#14 Esophageal next cancer*:ti,ab,kw from 2011 to 2014, in Trials
#15 Esophageal next tumor*:ti,ab,kw from 2011 to 2014, in Trials
#16 Esophageal next tumour*:ti,ab,kw from 2011 to 2014, in Trials
#17 Esophageal next carcinoma*:ti,ab,kw from 2011 to 2014, in Trials
#18 Esophageal next adenocarcinoma*:ti,ab,kw from 2011 to 2014, in Trials
#19 esophagus next neoplasm*:ti,ab,kw from 2011 to 2014, in Trials
#20 esophagus next cancer*:ti,ab,kw from 2011 to 2014, in Trials
#21 esophagus next tumor*:ti,ab,kw from 2011 to 2014, in Trials
#22 esophagus next tumour*:ti,ab,kw from 2011 to 2014, in Trials
#23 esophagus next carcinoma*:ti,ab,kw from 2011 to 2014, in Trials
#24 esophagus next adenocarcinoma*:ti,ab,kw from 2011 to 2014, in Trials
#25 oesophageal next cancer*:ti,ab,kw from 2011 to 2014, in Trials
#26 oesophageal next neoplasm*:ti,ab,kw from 2011 to 2014, in Trials
#27 oesophageal next tumor*:ti,ab,kw from 2011 to 2014, in Trials
#28 oesophageal next tumour*:ti,ab,kw from 2011 to 2014, in Trials
#29 oesophageal next carcinoma*:ti,ab,kw from 2011 to 2014, in Trials
#30 oesophageal next adenocarcinoma*:ti,ab,kw from 2011 to 2014, in Trials
#31 Intestinal next Neoplasm*:ti,ab,kw from 2011 to 2014, in Trials
#32 Intestinal next cancer*:ti,ab,kw from 2011 to 2014, in Trials
#33 Intestinal next tumor*:ti,ab,kw from 2011 to 2014, in Trials
#34 Intestinal next tumour*:ti,ab,kw from 2011 to 2014, in Trials
#35 Intestinal next carcinoma*:ti,ab,kw from 2011 to 2014, in Trials
#36 Intestinal next adenocarcinoma*:ti,ab,kw from 2011 to 2014, in Trials
#37 Duodenal next Neoplasm*:ti,ab,kw from 2011 to 2014, in Trials
#38 Duodenal nex cancer*:ti,ab,kw from 2011 to 2014, in Trials
#39 Duodenal next tumor*:ti,ab,kw from 2011 to 2014, in Trials
#40 Duodenal next tumour*:ti,ab,kw from 2011 to 2014, in Trials
#41 Duodenal next carcinoma*:ti,ab,kw from 2011 to 2014, in Trials
#42 Duodenal next adenocarcinoma*:ti,ab,kw from 2011 to 2014, in Trials
#43 Ileal next Neoplasm*:ti,ab,kw from 2011 to 2014, in Trials
#44 Ileal next cancer*:ti,ab,kw from 2011 to 2014, in Trials
#45 Ileal next tumor*:ti,ab,kw from 2011 to 2014, in Trials
#46 Ileal next tumour*:ti,ab,kw from 2011 to 2014, in Trials
#47 Ileal next carcinoma*:ti,ab,kw from 2011 to 2014, in Trials
#48 Ileal next adenocarcinoma*:ti,ab,kw from 2011 to 2014, in Trials
#49 Jejunal next Neoplasm*:ti,ab,kw from 2011 to 2014, in Trials
#50 Jejunal next cancer*:ti,ab,kw from 2011 to 2014, in Trials
#51 Jejunal next tumor*:ti,ab,kw from 2011 to 2014, in Trials
#52 Jejunal next tumour*:ti,ab,kw from 2011 to 2014, in Trials
#53 Jejunal next carcinoma*:ti,ab,kw from 2011 to 2014, in Trials
#54 Jejunal next adenocarcinoma*:ti,ab,kw from 2011 to 2014, in Trials
#55 Stomach next Neoplasm*:ti,ab,kw from 2011 to 2014, in Trials
#56 Stomach next cancer*:ti,ab,kw from 2011 to 2014, in Trials
#57 Stomach next tumor*:ti,ab,kw from 2011 to 2014, in Trials
#58 Stomach next tumour*:ti,ab,kw from 2011 to 2014, in Trials
#59 Stomach next carcinoma*:ti,ab,kw from 2011 to 2014, in Trials
#60 Stomach next adenocarcinoma*:ti,ab,kw from 2011 to 2014, in Trials
#61 breast next Neoplasm*:ti,ab,kw from 2011 to 2014, in Trials
#62 breast next cancer*:ti,ab,kw from 2011 to 2014, in Trials
#63 breast next tumor*:ti,ab,kw from 2011 to 2014, in Trials
#64 breast next tumour*:ti,ab,kw from 2011 to 2014, in Trials
#65 breast next carcinoma*:ti,ab,kw from 2011 to 2014, in Trials
#66 breast next adenocarcinoma*:ti,ab,kw from 2011 to 2014, in Trials
#67 lung next Neoplasm*:ti,ab,kw from 2011 to 2014, in Trials
#68 lung next cancer*:ti,ab,kw from 2011 to 2014, in Trials
#69 lung next tumor*:ti,ab,kw from 2011 to 2014, in Trials
#70 lung next tumour*:ti,ab,kw from 2011 to 2014, in Trials
#71 lung next carcinoma*:ti,ab,kw from 2011 to 2014, in Trials
#72 lung next adenocarcinoma*:ti,ab,kw from 2011 to 2014, in Trials
#73 Bronchial next Neoplasm*:ti,ab,kw from 2011 to 2014, in Trials
#74 Bronchial next cancer*:ti,ab,kw from 2011 to 2014, in Trials
#75 Bronchial next tumor*:ti,ab,kw from 2011 to 2014, in Trials
#76 Bronchial next tumour*:ti,ab,kw from 2011 to 2014, in Trials
#77 Bronchial next carcinoma*:ti,ab,kw from 2011 to 2014, in Trials
#78 Bronchial next adenocarcinoma*:ti,ab,kw from 2011 to 2014, in Trials
#79 prostat* next neoplasm*:ti,ab,kw from 2011 to 2014, in Trials
#80 prostat* next cancer*:ti,ab,kw from 2011 to 2014, in Trials
#81 prostat* next tumor*:ti,ab,kw from 2011 to 2014, in Trials
#82 prostat* next tumour*:ti,ab,kw from 2011 to 2014, in Trials
#83 prostat* next carcinoma*:ti,ab,kw from 2011 to 2014, in Trials
#84 prostat* next adenocarcinoma*:ti,ab,kw from 2011 to 2014, in Trials
#85 Pancrea* next neoplasm*:ti,ab,kw from 2011 to 2014, in Trials
#86 Pancrea* next cancer*:ti,ab,kw from 2011 to 2014, in Trials
#87 Pancrea* next tumor*:ti,ab,kw from 2011 to 2014, in Trials
#88 Pancrea* next tumour*:ti,ab,kw from 2011 to 2014, in Trials
#89 Pancrea* next carcinoma*:ti,ab,kw from 2011 to 2014, in Trials
#90 Pancrea* next adenocarcinoma*:ti,ab,kw from 2011 to 2014, in Trials
#91 (neoplasm*:ti or cancer*:ti or tumor*:ti or tumour*:ti or carcinoma*:ti or adenocarcinoma*:ti) from 2011 to 2014, in Trials
#92 or #1-#91 from 2011 to 2014, in Trials
#93 Aspirin:ti,ab,kw from 2011 to 2014, in Trials
#94 “acetylsalicylic acid”:ti,ab,kw from 2011 to 2014, in Trials
#95 Salicylate*:ti,ab,kw from 2011 to 2014, in Trials
#96 #93 or #94 or #95 from 2011 to 2014, in Trials
#97 #92 and #96 from 2011 to 2014, in Trials

### PubMed

#6 Search #4 AND #5 AND publisher[sb] Filters: Publication date from 2011/01/01 to 2013/06/03; English
#5 Search Aspirin[tiab] OR “acetylsalicylic acid”[tiab] OR Salicylate*[tiab]
#4 Search #1 OR #2 OR #3
#3 Search (neoplasm*[ti] OR cancer*[ti] OR tumor[ti] OR tumors[ti] OR tumour*[ti] OR carcinoma*[ti] OR adenocarcinoma*[ti])
#2 Search (breast[tiab] OR lung[tiab] OR bronchial[tiab] OR prostat*[tiab] OR pancreatic[tiab] OR pancreas[tiab]) AND (neoplasm*[tiab] OR cancer*[tiab] OR tumor[tiab] OR tumors[tiab] OR tumour*[tiab] OR carcinoma*[tiab] OR adenocarcinoma*[tiab])
#1 Search (gastrointestinal[tiab] OR gastric[tiab] OR esophageal[tiab] OR esophagus[tiab] OR oesophageal[tiab] OR intestinal[tiab] OR duodenal[tiab] OR ileal[tiab] OR jejunal[tiab] OR stomach[tiab]) AND (neoplasm*[tiab] OR cancer*[tiab] OR tumor[tiab] OR tumors[tiab] OR tumour*[tiab] OR carcinoma*[tiab] OR adenocarcinoma*[tiab])

## Literature Search Strategies – Primary Literature (harms)

### MEDLINE

Database: Ovid MEDLINE(R) without Revisions <1996 to June 3, 2014>, Ovid MEDLINE(R) Daily Update < June 3, 2014>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <June 3, 2014>

Search Strategy:

--------------------------------------------------------------------------------

1. Aspirin/ ()
2. aspirin.ti,ab. ()
3. acetylsalicylic acid.ti,ab. ()
4. salicylate$.ti,ab. ()
5. 1 or 2 or 3 or 4 ()
6. Mortality/ ()
7. Morbidity/ ()
8. Death/ ()
9. Hemorrhage/ ()
10. Gastrointestinal Hemorrhage/ ()
11. Stroke/ ()
12. Intracranial Hemorrhages/ ()
13. Cerebral Hemorrhage/ ()
14. safety.ti,ab. ()
15. harm$.ti,ab. ()
16. mortality.ti,ab. ()
17. toxicity.ti,ab. ()
18. (adverse adj2 (interaction$ or response$ or effect$ or event$ or reaction$ or outcome$)).ti,ab. ()
19. gastrointestinal.ti,ab. ()
20. bleed$.ti,ab. ()
21. hemorrhag$.ti,ab. (
22. haemorrhag$.ti,ab. ()
23. stroke$.ti,ab. ()
24. adverse effects.fs. ()
25. toxicity.fs. ()
26. 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 ()
27. 5 and 26 ()
28. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ ()
29. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt. ()
30. Random$.ti,ab. ()
31. control groups/ or double-blind method/ or single-blind method/ ()
32. clinical trial$.ti,ab. ()
33. controlled trial$.ti,ab. ()
34. meta analy$.ti,ab. ()
35. 28 or 29 or 30 or 31 or 32 or 33 or 34 ()
36. 27 and 35 ()
37. Animals/ not (Humans/ and Animals/) ()
38. 36 not 37 ()
39. limit 38 to (english language and yr=“2010 -Current”) ()
40. remove duplicates from 39 ()

--------------------------------------------------------------------------------

1. Aspirin/ ()
2. aspirin.ti,ab. ()
3. acetylsalicylic acid.ti,ab. ()
4. salicylate$.ti,ab. ()
5. 1 or 2 or 3 or 4 ()
6. Mortality/ ()
7. Morbidity/ ()
8. Death/ ()
9. Hemorrhage/ ()
10. Gastrointestinal Hemorrhage/ ()
11. Stroke/ ()
12. Intracranial Hemorrhages/ ()
13. Cerebral Hemorrhage/ ()
14. safety.ti,ab. ()
15. harm$.ti,ab. ()
16. mortality.ti,ab. ()
17. toxicity.ti,ab. ()
18. (adverse adj2 (interaction$ or response$ or effect$ or event$ or reaction$ or outcome$)).ti,ab. ()
19. gastrointestinal.ti,ab. ()
20. bleed$.ti,ab. ()
21. hemorrhag$.ti,ab. ()
22. haemorrhag$.ti,ab. ()
23. stroke$.ti,ab. ()
24. adverse effects.fs. ()
25. toxicity.fs. ()
26. 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 ()
27. 5 and 26 ()
28. limit 27 to (english language and yr=“2006 -Current”) ()
29. Cohort studies/ ()
30. Longitudinal studies/ ()
31. Prospective studies/ ()
32. Follow-up studies/ ()
33. cohort.ti,ab. ()
34. longitudinal.ti,ab. ()
35. prospective$.ti,ab. ()
36. (follow-up or followup).ti,ab. ()
37. 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 ()
38. 28 and 37 ()
39. remove duplicates from 38 ()

### PubMed

#4 Search #1 AND #2 AND #3 AND English[Language] AND publisher[sb] Filters: Publication date from 2010/01/01 to 2014/06/03
#3 Search random*[tiab] OR trial*[tiab] OR meta analy*[tiab]
#2 Search (safety[tiab] OR harm*[tiab] OR adverse[tiab] OR toxicity[tiab] OR mortality[tiab] OR morbidity[tiab] OR gastrointestinal[tiab] OR bleed*[tiab] OR hemorrhag*[tiab] OR haemorrhag*[tiab] OR stroke*[tiab])
#1 Search Aspirin[tiab] OR “acetylsalicylic acid”[tiab] OR Salicylate*[tiab]
#7 Search #4 AND publisher[sb] Filters: Publication date from 2006/01/01 to 2014/06/03; English
#6 Search #4 AND publisher[sb] Filters: English
#4 Search #1 AND #2 AND #3
#3 Search cohort*[tiab] OR prospective*[tiab] OR longitudinal[tiab] OR followup[tiab] OR follow up[tiab]
#2 Search (safety[tiab] OR harm*[tiab] OR adverse[tiab] OR toxicity[tiab] OR mortality[tiab] OR morbidity[tiab] OR gastrointestinal[tiab] OR bleed*[tiab] OR hemorrhag*[tiab] OR haemorrhag*[tiab] OR stroke*[tiab])
#1 Search Aspirin[tiab] OR “acetylsalicylic acid”[tiab] OR Salicylate*[tiab]

### Cochrane Central Register of Controlled Clinical Trials (http://www.thecochranelibrary.com/) (CENTRAL)

#1 aspirin:ti,ab,kw from 2010 to 2014, in Trials
#2 “acetylsalicylic acid”:ti,ab,kw from 2010 to 2014, in Trials
#3 salicylate*:ti,ab,kw from 2010 to 2014, in Trials
#4 platelet next aggregation next inhibit*:ti,ab,kw from 2010 to 2014, in Trials
#5 #1 or #2 or #3 or #4 from 2010 to 2014, in Trials
#6 safety:ti,ab,kw from 2010 to 2014, in Trials
#7 adverse:ti,ab,kw from 2010 to 2014, in Trials
#8 harm*:ti,ab,kw from 2010 to 2014, in Trials
#9 toxicity:ti,ab,kw from 2010 to 2014, in Trials
#10 mortality:ti,ab,kw from 2010 to 2014, in Trials
#11 morbidity:ti,ab,kw from 2010 to 2014, in Trials
#12 death*:ti,ab,kw from 2010 to 2014, in Trials
#13 gastrointestinal:ti,ab,kw from 2010 to 2014, in Trials
#14 bleed*:ti,ab,kw from 2010 to 2014, in Trials
#15 hemorrhag*:ti,ab,kw from 2010 to 2014, in Trials
#16 haemorrhag*:ti,ab,kw from 2010 to 2014, in Trials
#17 stroke*:ti,ab,kw from 2010 to 2014, in Trials
#18 #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17 from 2010 to 2014, in Trials
#19 #5 and #18 from 2010 to 2014, in Trials
#20 #1 or #2 or #3 from 2010 to 2014, in Trials
#21 #20 and #18

Appendix A Figure 1 Literature Flow Diagram

Abbreviations: CE = comparative effectiveness; KQ = Key Question

This figure is a flow chart that summarizes the search and selection of articles. There were 4,937 citations identified through literature databases. An additional 275 citations were identified from outside sources such as reference lists and suggestions from peer reviewers. After duplicates were removed, 4,393 unique citations were screened at the title/abstract stage. The full-text of 336 citations were examined for inclusion for one or more of the Key Questions. The included 68 articles (28 studies) for Key Question 1, 36 articles (12 studies) for Key Question 2, and 78 articles (34 studies) for Key Question 6. Reasons for excluding the other articles are available in the Appendix.

Appendix A Table 1 Inclusion and Exclusion Criteria

Category | Inclusion criteria | Exclusion criteria
Aim/Condition | All KQs: Any indication; cancer incidence and deaths reported as an outcome:; - Primary prevention of cancer; - Primary prevention of CVD (secondary prevention of CVD for sensitivity analyses) | All KQs: Secondary or tertiary prevention of cancer; treatment of cancer; cancer remission; cancer recurrence; cancer metastases
Population | All KQs: Adults aged 40 years and older | All KQs:; - Non-human populations; - Children and adolescents (aged < 18 years); - Studies where the majority of participants are aged < 40 years; - Pregnant women; - Institutionalized individuals (e.g., psychiatric inpatients); - Individuals in long-term care; - Post-surgical patients; - Contraindicated or not eligible for ASA chemoprevention; - Symptomatic patients (e.g., those undergoing a diagnostic colonoscopy); Cancer-specific:; - Personal history of cancers for which we are evaluating chemoprevention outcomes; - High-incidence familial cancer syndromes (e.g., Lynch syndrome) for cancers for which we are evaluating chemoprevention outcomes
Intervention | All KQs: Aspirin; - Oral; - Minimum 75 mg every day or every other day; - No maximum limit; - Exposure of at least 12 months; - Formulations include: tablet, enteric coated tablets, chewable tablets, effervescent tablets; Both intervention and control (or exposed and unexposed) groups may be taking other medications or supplements | All KQs:; - Irregular or occasional ASA use; - Other non-ASA NSAID; - Delivered via non-oral routes; - Dosage information not reported; - Non-tablet oral formulations (e.g., gum); - Co-administration with other chemopreventive (e.g., tamoxifen) or potentially chemopreventive agents (e.g., vitamin E) or lifestyle interventions (e.g., diet, exercise); - Co-administration with other non-ASA anti-thrombotic medications (e.g., warfarin, other anti-platelet agents)
Comparator | All KQs:; - Placebo; - No intervention | All KQs: Comparative effectiveness (i.e., any active agent or intervention – e.g., pharmacological, lifestyle intervention)
Outcomes | KQs 1, 2 (health and cancer outcomes):; - Incidence of cancer; - Cancer-related mortality; - All-cause mortality; KQ 6:; - GI bleeding; - Hemorrhagic stroke; - Other serious harms (e.g., age-related macular degeneration) | All KQs: Cancer-specific:; - Biomarkers; - Biologic or physiologic markers of cancer (e.g., serum PSA, breast density); - Pre-cancerous markers; - Progression or metastasis; - Recurrence; KQ 6: Post-operative or minor bleeding
Study design | KQs 1, 2:; - RCTs; - CCTs; - Systematic reviews and meta-analyses of RCTs for evidence on benefits; KQ 6:; - RCTs; - CCTs; - Systematic reviews and meta-analyses analyses for evidence of harms; - Large prospective cohort studies; - Patient registries | KQs 1, 2:; - Factorial designed studies where the aspirin versus placebo arm is not reported separately; - Observational studies; - Narrative reviews; - Commentaries; - Editorials; - Narrative reviews; KQ 6:; - Case reports,; - Case-control studies; - Small or retrospective cohort studies; - Case series; - Commentaries; - Editorials; - Narrative reviews
Setting | All KQs: Outpatient | All KQs: Exclusively inpatient
Timing of outcome assessment | All KQs: 12 months or longer | All KQs: Less than 12 months
Country | All KQs: Any country with a 2013 Human Development Index of “Very High” | All KQs: Any country with less than a Human Development Index of “Very High”
Language | All KQs: English | All KQs: Other languages besides English
Study Quality | All KQs: Good and fair quality, according to USPSTF criteria | All KQs: Poor quality as defined by design-specific USPSTF criteria

Abbreviations: ASA = acetylsalicylic acid; CCT = clinical controlled trial; CVD = cardiovascular disease; KQ = Key Question; mg = milligram(s); NSAID = non-steroidal anti-inflammatory drug; PSA = prostate serum antigen; RCT = randomized controlled trial; USPSTF = U.S. Preventive Services Task Force

Appendix A Table 2 Quality Assessment Criteria

Study Design | Adapted Quality Criteria
Randomized controlled trials, adapted from the USPSTF methods48 | - Valid random assignment?; - Was allocation concealed?; - Was eligibility criteria specified?; - Were groups similar at baseline?; - Were outcome assessors blinded?; - Were measurements equal, valid and reliable?; - Was there adequate adherence to the intervention?; - Were the statistical methods acceptable?; - Was the handling of missing data appropriate?; - Was there acceptable followup?; - Was there evidence of selective reporting of outcomes?; - What was the funding source?
Observational studies, adapted from the Newcastle-Ottawa Scales49 | - Was the exposed cohort representative?; - Was the selection of the nonexposed cohort systematic?; - Was eligibility criteria specified?; - Were baseline characteristics well described?; - Were groups similar at baseline?; - Was the ascertainment of exposure reported?; - Was the outcome of interest not present at baseline?; - Were measurements equal, valid and reliable?; - Were outcome assessors blinded?; - Was there adequate followup time for an event to occur?; - Was there acceptable followup?; - Were the statistical methods acceptable?; - Was the handling of missing data appropriate?; - Was there adjustment for confounders?; - What was the funding source?
Assessment of Multiple Systematic Reviews (AMSTAR)50 | - Was an a priori design provided?; - Was there duplicate study selection and data extraction?; - Was a comprehensive literature search performed?; - Was the status of publication used as an inclusion criteria?; - Was a list of studies provided?; - Was the scientific quality of the included studies assessed and documented?; - Was the scientific quality of the included studies used appropriately in formulating conclusions?; - Were the methods used to combine the findings of studies appropriate?; - Was the likelihood of publication bias assessed?; - Was the conflict of interest included?

Abbreviations: USPSTF = U.S. Preventive Services Task Force