# References

1 Heron M. Deaths: Leading causes for 2010. National vital statistics reports. Hyattsville, MD. National Center for Health Statistics. 2013;62(6).
2 Go AS, Mozaffarian D, Roger VL, et al. Heart disease and stroke statistics--2014 update: a report from the American Heart Association. Circulation. Jan. 21. 2014;129(3):e28-e292. [pmid: 24352519].
3 George MG, Tong X, Sonnenfeld N, et al. Recommended use of aspirin and other antiplatelet medications among adults--National Ambulatory Medical Care Survey and National Hospital Ambulatory Medical Care Survey, United States, 2005-2008. MMWR Morb Mortal Wkly Rep. Jun. 15. Suppl. 2012;61:11-8. [pmid: 22695458].
4 Wilkins JT, Ning H, Berry J, et al. Lifetime risk and years lived free of total cardiovascular disease. JAMA. Nov. 7. 2012;308(17):1795-801. [pmid: 23117780].
5 Fang J, Shaw Kate M, Keenan NL. Prevalence of coronary heart disease--United States, 2006-2010. MMWR Morb Mortal Wkly Rep. Oct. 14. 2011;60(40):1377-81. [pmid: 21993341].
6 D'Agostino RB Sr., Vasan RS, Pencina MJ, et al. General cardiovascular risk profile for use in primary care: the Framingham Heart Study. Circulation. Feb. 12. 2008;117(6):743-53. [pmid: 18212285].
7 Yusuf S, Hawken S, Ounpuu S, et al. Effect of potentially modifiable risk factors associated with myocardial infarction in 52 countries (the INTERHEART study): case-control study. Lancet. Sep. 11. 2004;364(9438):937-52. [pmid: 15364185].
8 Wilson PW, D'Agostino RB, Levy D, et al. Prediction of coronary heart disease using risk factor categories. Circulation. May. 12. 1998;97(18):1837-47. [pmid: 9603539].
9 Berry JD, Dyer A, Cai X, et al. Lifetime Risks of Cardiovascular Disease. N Engl J Med. Jan. 26. 2012;366(4):321-9. [pmid: 22276822].
10 Executive Summary of The Third Report of The National Cholesterol Education Program (NCEP) Expert Panel on Detection, Evaluation, And Treatment of High Blood Cholesterol In Adults (Adult Treatment Panel III). JAMA. May. 16. 2001;285(19):2486-97. [pmid: 11368702].
11 Centers for Disease Control and Prevention. National Diabetes Fact Sheet: National Estimates and General Information on Diabetes and Prediabetes in the United States, 2011. Atlanta, GA. US Department of Health and Human Services, Centers for Disease Control and Prevention. 2011.
12 Fox CS, Coady S, Sorlie PD, et al. Trends in cardiovascular complications of diabetes. JAMA. Nov. 24. 2004;292(20):2495-9. [pmid: 15562129].
13 Fox CS, Coady S, Sorlie PD, et al. Increasing cardiovascular disease burden due to diabetes mellitus: the Framingham Heart Study. Circulation. Mar. 27. 2007;115(12):1544-50. [pmid: 17353438].
14 Goff DC Jr., Lloyd-Jones DM, Bennett G, et al. 2013 ACC/AHA Guideline on the Assessment of Cardiovascular Risk: A Report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines. J Am Coll Cardiol. 2013. Nov. 12. [pmid: 24239921].
15 National Cholesterol Education Program. Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel III). Final Report. NIH Publication No. 02-5215. National Heart, Lung, and Blood Institute. 2002. [pmid: 12485966].
16 Anderson KM, Odell PM, Wilson PW, et al. Cardiovascular disease risk profiles. Am Heart J. Jan. 1991;121(1 Pt 2):293-8. [pmid: 1985385].
17 Chambless LE, Folsom AR, Sharrett AR, et al. Coronary heart disease risk prediction in the Atherosclerosis Risk in Communities (ARIC) study. J Clin Epidemiol. Sep. 2003;56(9):880-90. [pmid: 14505774].
18 Conroy RM, Pyorala K, Fitzgerald AP, et al. Estimation of ten-year risk of fatal cardiovascular disease in Europe: the SCORE project. Eur Heart J. Jun. 2003;24(11):987-1003. [pmid: 12788299].
19 Ridker PM, Buring JE, Rifai N, et al. Development and validation of improved algorithms for the assessment of global cardiovascular risk in women: the Reynolds Risk Score. JAMA. Feb. 14. 2007;297(6):611-9. [pmid: 17299196].
20 Ridker PM, Paynter NP, Rifai N, et al. C-reactive protein and parental history improve global cardiovascular risk prediction: the Reynolds Risk Score for men. Circulation. Nov. 25. 2008;118(22):2243-51. 4p. [pmid: 18997194].
21 Hippisley-Cox J, Coupland C, Vinogradova Y, et al. Predicting cardiovascular risk in England and Wales: prospective derivation and validation of QRISK2. BMJ. Jun. 28. 2008;336(7659):1475-82. [pmid: 18573856].
22 Assmann G, Cullen P, Schulte H. Simple scoring scheme for calculating the risk of acute coronary events based on the 10-year follow-up of the prospective cardiovascular Munster (PROCAM) study. Circulation. Jan. 22. 2002;105(3):310-5. [pmid: 11804985].
23 Matheny M, McPheeters ML, Glasser A, et al. Systematic Review of Cardiovascular Disease Risk Assessment Tools. AHRQ Publication No. 11-05155-EF-1. 2011. [pmid: 21796824].
24 Berger JS, Jordan CO, Lloyd-Jones D, et al. Screening for cardiovascular risk in asymptomatic patients. J Am Coll Cardiol. Mar. 23. 2010;55(12):1169-77. [pmid: 20298922].
25 Anderson KM, Wilson PW, Odell PM, et al. An updated coronary risk profile. A statement for health professionals. Circulation. Jan. 1991;83(1):356-62. [pmid: 1984895].
26 Larson MK, Ashmore JH, Harris KA, et al. Effects of omega-3 acid ethyl esters and aspirin, alone and in combination, on platelet function in healthy subjects. Thrombosis & Haemostasis. Oct. 2008;100(4):634-41. [pmid: 18841286].
27 Bayer AG. History of Bayer HealthCare. 2013.
28 American Heart Association. What is Cardiovascular Disase (Heart Disease)?. 2013. May 9, 2014.
29 Nemerovski CW, Salinitri FD, Morbitzer KA, et al. Aspirin for primary prevention of cardiovascular disease events. Pharmacotherapy. Nov. 2012;32(11):1020-35. [pmid: 23019080].
30 Abramson S, Howard R. Aspirin: mechanism of action, major toxicities, and use in rheumatic diseases. 2014.
31 Golden BD, Abramson SB. Selective cyclooxygenase-2 inhibitors. Rheum Dis Clin North Am. May. 1999;25(2):359-78. [pmid: 10356423].
32 Wallace JL. Prostaglandins, NSAIDs, and gastric mucosal protection: why doesn't the stomach digest itself?. Physiol Rev. Oct. 2008;88(4):1547-65. [pmid: 18923189].
33 Baigent C, Blackwell L, Collins R, et al. Aspirin in the primary and secondary prevention of vascular disease: collaborative meta-analysis of individual participant data from randomised trials. Lancet. May. 30. 2009;373(9678):1849-60. [pmid: 19482214].
34 Parekh AK, Galloway JM, Hong Y, et al. Aspirin in the secondary prevention of cardiovascular disease. N Engl J Med. Jan. 17. 2013;368(3):204-5. [pmid: 23323896].
35 Aspirin for the prevention of cardiovascular disease: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. Mar. 17. 2009;150(6):396-404. [pmid: 19293072].
36 Goldstein LB, Bushnell CD, Adams RJ, et al. Guidelines for the primary prevention of stroke: a guideline for healthcare professionals from the American Heart Association/American Stroke Association. Stroke. Feb. 2011;42(2):517-84. [pmid: 21127304].
37 Pignone M, Alberts MJ, Colwell JA, et al. Aspirin for primary prevention of cardiovascular events in people with diabetes: a position statement of the American Diabetes Association, a scientific statement of the American Heart Association, and an expert consensus document of the American College of Cardiology Foundation. Diabetes Care. Jun. 2010;33(6):1395-402. [pmid: 20508233].
38 National Institute for Health and Clinical Excellence. Clinical Knowledge Summaries. Antiplatelet treatment. When to prescribe antiplatelet treatment (primary prevention). 2013. http://cks.nice.org.uk/antiplatelet-treatment#!scenariorecommendation. April 15, 2014.
39 Joint British Societies' consensus recommendations for the prevention of cardiovascular disease (JBS3). Heart. Apr. 2014;100(Suppl 2):ii1-ii67. [pmid: 24667225].
40 Scottish Intercollegiate Guidelines Network (SIGN). Antithrombotics: indications and management. SIGN Publication No. 129. Edinburgh. SIGN. 2013.
41 Perk J, De BG, Gohlke H, et al. European Guidelines on cardiovascular disease prevention in clinical practice (version 2012). The Fifth Joint Task Force of the European Society of Cardiology and Other Societies on Cardiovascular Disease Prevention in Clinical Practice (constituted by representatives of nine societies and by invited experts). Eur Heart J. Jul. 2012;33(13):1635-701. [pmid: 22555213].
42 U.S.Preventive Services Task Force. Aspirin for the Primary Prevention of Cardiovascular Events: Recommendation and Rationale. Annals of Internal Medicine. 2002;136(2):157-60. [pmid: 11790071].
43 Ogawa H, Nakayama M, Morimoto T, et al. Low-dose aspirin for primary prevention of atherosclerotic events in patients with type 2 diabetes: a randomized controlled trial. [Erratum appears in JAMA. 2009 May 13;301(18):1882]. JAMA. Nov. 12. 2008;300(18):2134-41. [pmid: 18997198].
44 Belch J, MacCuish A, Campbell I, et al. The prevention of progression of arterial disease and diabetes (POPADAD) trial: factorial randomised placebo controlled trial of aspirin and antioxidants in patients with diabetes and asymptomatic peripheral arterial disease. BMJ. 2008;337:a1840. [pmid: 18927173].
45 Fowkes FG, Price JF, Stewart MC, et al. Aspirin for prevention of cardiovascular events in a general population screened for a low ankle brachial index: a randomized controlled trial. JAMA. Mar. 3. 2010;303(9):841-8. [pmid: 20197530].
46 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20:21-35. [pmid: 11306229].
47 U.S.Preventive Services Task Force. U.S. Preventive Services Task Force procedure manual. AHRQ Publication No. 08-05118-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2008.
48 National Institute for Health and Clinical Excellence. The Guidelines Manual. London. National Institute for Health and Clinical Excellence. 2006.
49 Fortmann SP, Burda BU, Senger CA, et al. Vitamin and mineral supplements in the primary prevention of cardiovascular disease and cancer: An updated systematic evidence review for the U.S. Preventive Services Task Force. Ann Intern Med. Dec. 17. 2013;159(12):824-34. [pmid: 24217421].
50 Whitlock E, Williams S, Burda B, et al. Aspirin use in adults: total cancer, all-cause mortality, and harms. Rockville, MD. 2014.
51 Fu R, Gartlehner G, Grant M, et al. Conducting quantitative synthesis when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. Nov. 2011;64(11):1187-97. [pmid: 21477993].
52 Yusuf S, Peto R, Lewis J, et al. Beta blockade during and after myocardial infarction: an overview of the randomized trials. Prog Cardiovasc Dis. Mar. 1985;27(5):335-71. [pmid: 2858114].
53 Final report on the aspirin component of the ongoing Physicians' Health Study. Steering Committee of the Physicians' Health Study Research Group. N Engl J Med. Jul. 20. 1989;321(3):129-35. [pmid: 2664509].
54 Thrombosis prevention trial: randomised trial of low-intensity oral anticoagulation with warfarin and low-dose aspirin in the primary prevention of ischaemic heart disease in men at increased risk. The Medical Research Council's General Practice Research Framework. Lancet. Jan. 24. 1998;351(9098):233-41. [pmid: 9457092].
55 ETDRS Investigators. Aspirin effects on mortality and morbidity in patients with diabetes mellitus. Early Treatment Diabetic Retinopathy Study report 14. ETDRS Investigators. JAMA. Sep. 9. 1992;268(10):1292-300. [pmid: 1507375].
56 Hansson L, Zanchetti A, Carruthers SG, et al. Effects of intensive blood-pressure lowering and low-dose aspirin in patients with hypertension: principal results of the Hypertension Optimal Treatment (HOT) randomised trial. HOT Study Group. Lancet. Jun. 13. 1998;351(9118):1755-62. [pmid: 9635947].
57 Peto R, Gray R, Collins R, et al. Randomised trial of prophylactic daily aspirin in British male doctors. Br Med J (Clin Res Ed). Jan. 30. 1988;296(6618):313-6. [pmid: 3125882].
58 Ridker PM, Cook NR, Lee IM, et al. A randomized trial of low-dose aspirin in the primary prevention of cardiovascular disease in women. N Engl J Med. Mar. 31. 2005;352(13):1293-304. [pmid: 15753114].
59 de Gaetano G. Collaborative Group of the Primary Prevention Project. Low-dose aspirin and vitamin E in people at cardiovascular risk: a randomised trial in general Practice. The Lancet. Jan. 13. 2001;357(9250):89-95. [pmid: 11197445].
60 Kjeldsen SE, Kolloch RE, Leonetti G, et al. Influence of gender and age on preventing cardiovascular disease by antihypertensive treatment and acetylsalicylic acid. The HOT study. Hypertension Optimal Treatment. J Hypertens. May. 2000;18(5):629-42. [pmid: 10826567].
61 Berger JS, Roncaglioni MC, Avanzini F, et al. Aspirin for the primary prevention of cardiovascular events in women and men: a sex-specific meta-analysis of randomized controlled trials. JAMA. Jan. 18. 2006;295(3):306-13. [pmid: 16418466].
62 Zanchetti A. Aspirin and Antiplatet Drugs in the Prevention of Cardiovascular Complications of Diabetes. Pharmacotherapy of diabetes: new developments: improving life and prognosis for diabetic patients. New York, New York. Springer Science and Business Media. 2007:211-8.
63 Sacco M, Pellegrini F, Roncaglioni MC, et al. Low-dose aspirin and vitamin E in people at cardiovascular risk: a randomised trial in general Practice. Diabetes Care. Dec. 1. 2003;26(12):3264-72. [pmid: 14633812].
64 Zanchetti A, Hansson L, Dahlof B, et al. Benefit and harm of low-dose aspirin in well-treated hypertensives at different baseline cardiovascular risk. J Hypertens. Nov. 2002;20(11):2301-7. [pmid: 12409970].
65 Soejima H, Ogawa H, Morimoto T, et al. Aspirin reduces cerebrovascular events in type 2 diabetic patients with poorly controlled blood pressure. Subanalysis from the JPAD trial. Circ J. 2012;76(6):1526-32. [pmid: 22447019].
66 Meade TW, BRENNAN PJ. Determination of who may derive most benefit from aspirin in primary prevention: subgroup results from a randomised controlled trial. BMJ. Jul. 1. 2000;321(7252):13-7. [pmid: 10875825].
67 Dorresteijn JA, Visseren FL, Ridker PM, et al. Aspirin for primary prevention of vascular events in women: individualized prediction of treatment effects. European Heart Journal. Dec. 2011;32(23):2962-9. [pmid: 22090661].
68 Cook NR, Lee IM, Zhang SM, et al. Alternate-day, low-dose aspirin and cancer risk: long-term observational follow-up of a randomized trial. Ann Intern Med. Jul. 16. 2013;159(2):77-85. [pmid: 23856681].
69 Rexrode KM, Lee IM, Cook NR, et al. Baseline characteristics of participants in the Women's Health Study. J Womens Health Gend Based Med. Jan. 2000;9(1):19-27. [pmid: 10718501].
70 Christen WG, Glynn RJ, Ajani UA, et al. Age-related maculopathy in a randomized trial of low-dose aspirin among US physicians. Arch Ophthalmol. Aug. 2001;119(8):1143-9. [pmid: 11483080].
71 Okada S, Morimoto T, Ogawa H, et al. Effect of low-dose aspirin on primary prevention of cardiovascular events in Japanese diabetic patients at high risk. Circulation Journal. 2013;77(12):3023-8. [pmid: 24042256].
72 Seshasai SR, Wijesuriya S, Sivakumaran R, et al. Effect of aspirin on vascular and nonvascular outcomes: meta-analysis of randomized controlled trials. Arch Intern Med. Feb. 13. 2012;172(3):209-16. [pmid: 22231610].
73 Raju N, Sobieraj-Teague M, Hirsh J, et al. Effect of Aspirin on Mortality in the Primary Prevention of Cardiovascular Disease. Am J Med. Jul. 2011;124(7):621-9. [pmid: 21592450].
74 Bartolucci AA, Tendera M, Howard G. Meta-analysis of multiple primary prevention trials of cardiovascular events using aspirin. Am J Cardiol. Jun. 15. 2011;107(12):1796-801. [pmid: 21481826].
75 Berger JS, Lala A, Krantz MJ, et al. Aspirin for the prevention of cardiovascular events in patients without clinical cardiovascular disease: a meta-analysis of randomized trials. Am Heart J. Jul. 2011;162(1):115-24. [pmid: 21742097].
76 DerSimonian R, Kacker R. Random-effects model for meta-analysis of clinical trials: an update. Contemp Clin Trials. Feb. 2007;28(2):105-14. [pmid: 16807131].
77 Higgins JP, Whitehead A. Borrowing strength from external trials in a meta-analysis. Stat Med. Dec. 30. 1996;15(24):2733-49. [pmid: 8981683].
78 Kontopantelis E, Springate DA, Reeves D. A re-analysis of the Cochrane Library data: the dangers of unobserved heterogeneity in meta-analyses. PLoS One. 2013;8(7):e69930. [pmid: 23922860].
79 Guolo A. Higher-order likelihood inference in meta-analysis and meta-regression. Stat Med. Feb. 20. 2012;31(4):313-27. [pmid: 22173666].
80 Zhang C, Sun A, Zhang P, et al. Aspirin for primary prevention of cardiovascular events in patients with diabetes: A meta-analysis. Diabetes Res Clin Pract. Feb. 2010;87(2):211-8. [pmid: 19853947].
81 Younis N, Williams S, Ammori B, et al. Role of aspirin in the primary prevention of cardiovascular disease in diabetes mellitus: a meta-analysis. Expert Opin Pharmacother. Jun. 2010;11(9):1459-66. [pmid: 20429671].
82 Stavrakis S, Stoner JA, Azar M, et al. Low-dose aspirin for primary prevention of cardiovascular events in patients with diabetes: a meta-analysis. Am J Med Sci. Jan. 2011;341(1):1-9. [pmid: 21191260].
83 De Berardis G, Sacco M, Strippoli GF, et al. Aspirin for primary prevention of cardiovascular events in people with diabetes: meta-analysis of randomised controlled trials. BMJ. 2009;339:b4531. [pmid: 19897665].
84 Butalia S, Leung AA, Ghali WA, et al. Aspirin effect on the incidence of major adverse cardiovascular events in patients with diabetes mellitus: a systematic review and meta-analysis. [Review]. Cardiovascular Diabetology. 2011;10:25. [pmid: 21453547].
85 Ekstrom N, Cederholm J, Zethelius B, et al. Aspirin treatment and risk of first incident cardiovascular diseases in patients with type 2 diabetes: an observational study from the Swedish National Diabetes Register. BMJ Open. 2013;3(4). [pmid: 23604419].
86 Coccheri S. Antiplatelet therapy: controversial aspects. Thromb Res. Mar. 2012;129(3):225-9. [pmid: 22119155].
87 Pulcinelli FM, Biasucci LM, Riondino S, et al. COX-1 sensitivity and thromboxane A2 production in type 1 and type 2 diabetic patients under chronic aspirin treatment. Eur Heart J. May. 2009;30(10):1279-86. [pmid: 19346231].
88 Bulugahapitiya U, Siyambalapitiya S, Sithole J, et al. Is diabetes a coronary risk equivalent? Systematic review and meta-analysis. Diabet Med. Feb. 2009;26(2):142-8. [pmid: 19236616].
89 De Berardis G, Lucisano G, D'Ettorre A, et al. Association of aspirin use with major bleeding in patients with and without diabetes. JAMA. Jun. 6. 2012;307(21):2286-94. [pmid: 22706834].
90 Welin L, Wilhelmsen L, Bjornberg A, et al. Aspirin increases mortality in diabetic patients without cardiovascular disease: a Swedish record linkage study. Pharmacoepidemiology & Drug Safety. Dec. 2009;18(12):1143-9. [pmid: 19672841].
91 Bowman L. ASCEND: A Study of Cardiovascular Events iN Diabetes. http://clinicaltrialsgov/ct2/show/NCT00135226?term=cardiovascular+events+prevention+trial+in+diabetes&rank=4. 2011.
92 De Berardis G, Sacco M, Evangelista V, et al. Aspirin and Simvastatin Combination for Cardiovascular Events Prevention Trial in Diabetes (ACCEPT-D): design of a randomized study of the efficacy of low-dose aspirin in the prevention of cardiovascular events in subjects with diabetes mellitus treated with statins. Trials. 2007;8:21. [pmid: 17725825].
93 Lanas A, Garcia-Rodriguez LA, Polo-Tomas M, et al. Time trends and impact of upper and lower gastrointestinal bleeding and perforation in clinical practice. Am J Gastroenterol. Jul. 2009;104(7):1633-41. [pmid: 19574968].
94 Nelson M, Reid C, Beilin L, et al. Rationale for a trial of low-dose aspirin for the primary prevention of major adverse cardiovascular events and vascular dementia in the elderly: Aspirin in Reducing Events in the Elderly (ASPREE). Drugs Aging. 2003;20(12):897-903. [pmid: 14565783].
95 Matthys F, De BT, De BG, et al. Review of guidelines on primary prevention of cardiovascular disease with aspirin: how much evidence is needed to turn a tanker?. Eur J Prev Cardiol. 2014;21(3):354-65. [pmid: 23610452].
96 Food and Drug Administration. Citizen Petition Denial Response from FDA to Bayer Healthcare, LLC. Department of Health and Human Services. 2014.
97 Mosca L, Benjamin EJ, Berra K, et al. Effectiveness-based guidelines for the prevention of cardiovascular disease in women--2011 update: a guideline from the american heart association. Circulation. Mar. 22. 2011;123(11):1243-62. [pmid: 21325087].
98 Ridker PM, Cook NR. Statins: new American guidelines for prevention of cardiovascular disease. Lancet. Nov. 30. 2013;382(9907):1762-5. [pmid: 24268611].
99 Muntner P, Colantonio LD, Cushman M, et al. Validation of the Atherosclerotic Cardiovascular Disease Pooled Cohort Risk Equations. JAMA. 2014. Mar. 29. [pmid: 24682252].
100 Kavousi M, Leening MJ, Nanchen D, et al. Comparison of Application of the ACC/AHA Guidelines, Adult Treatment Panel III Guidelines, and European Society of Cardiology Guidelines for Cardiovascular Disease Prevention in a European Cohort. JAMA. 2014. Mar. 29. [pmid: 24681960].
101 Brindle P, Beswick A, Fahey T, et al. Accuracy and impact of risk assessment in the primary prevention of cardiovascular disease: a systematic review. Heart. Dec. 2006;92(12):1752-9. [pmid: 16621883].
102 Beswick AD, Brindle P, Fahey T, et al. A Systematic Review of Risk Scoring Methods and Clinical Decision Aids Used in the Primary Prevention of Coronary Heart Disease. 2008. [pmid: 21834196].
103 Siontis GC, Tzoulaki I, Siontis KC, et al. Comparisons of established risk prediction models for cardiovascular disease: systematic review. BMJ. 2012;344:e3318. [pmid: 22628003].
104 Ridker PM, Cook NR. Refining the American guidelines for prevention of cardiovascular disease - Authors' reply. Lancet. Feb. 15. 2014;383(9917):600. [pmid: 24529467].
105 Maciosek M, Dehmer S, Flottemesch T. Aspirin use to prevent cardiovascular disease and cancer: a decision analysis. Rockville, MD. Agency for Healthcare Research and Quality. 2014.
106 Liew G, Mitchell P, Wong TY, et al. The Association of Aspirin Use With Age-Related Macular Degeneration. JAMA Intern Med. Jan. 2013;21:1-7. [pmid: 23337937].
107 de Jong PT, Chakravarthy U, Rahu M, et al. Associations between aspirin use and aging macula disorder: the European Eye Study. Ophthalmology. Jan. 2012;119(1):112-8. [pmid: 21920607].
108 Baigent C, Keech A, Kearney PM, et al. Efficacy and safety of cholesterol-lowering treatment: prospective meta-analysis of data from 90,056 participants in 14 randomised trials of statins. Lancet. Oct. 8. 2005;366(9493):1267-78. [pmid: 16214597].
109 Ferreira-Gonzalez I, Busse JW, Heels-Ansdell D, et al. Problems with use of composite end points in cardiovascular trials: systematic review of randomised controlled trials. BMJ. Apr. 14. 2007;334(7597):786. [pmid: 17403713].
110 Rothwell PM. Treating individuals 2. Subgroup analysis in randomised controlled trials: importance, indications, and interpretation. Lancet. Jan. 8. 2005;365(9454):176-86. [pmid: 15639301].
111 Sun X, Briel M, Busse JW, et al. Credibility of claims of subgroup effects in randomised controlled trials: systematic review. BMJ. 2012;344:e1553. [pmid: 22422832].
112 Pitrou I, Boutron I, Ahmad N, et al. Reporting of safety results in published reports of randomized controlled trials. Arch Intern Med. Oct. 26. 2009;169(19):1756-61. [pmid: 19858432].
113 Chuback J, Kamineni A, Buist D, et al. Aspirin use for the prevention of colorectal cancer: an evidence update for the US Preventive Services Task Force. Rockville, MD. Agency for Healthcare Research and Quality. 2014.
114 The Atherosclerosis Risk in Communities (ARIC) Study: design and objectives. The ARIC investigators. Am J Epidemiol. Apr. 1989;129(4):687-702. [pmid: 2646917].
115 Friedman GD, Cutter GR, Donahue RP, et al. CARDIA: study design, recruitment, and some characteristics of the examined subjects. J Clin Epidemiol. 1988;41(11):1105-16. [pmid: 3204420].
116 Fried LP, Borhani NO, Enright P, et al. The Cardiovascular Health Study: design and rationale. Ann Epidemiol. Feb. 1991;1(3):263-76. [pmid: 1669507].
117 D'Agostino RB Sr., Grundy S, Sullivan LM, et al. Validation of the Framingham coronary heart disease prediction scores: results of a multiple ethnic groups investigation. JAMA. Jul. 11. 2001;286(2):180-7. [pmid: 11448281].
118 Bastuji-Garin S, Deverly A, Moyse D, et al. The Framingham prediction rule is not valid in a European population of treated hypertensive patients. J Hypertens. Oct. 2002;20(10):1973-80. [pmid: 12359975].
119 Folsom AR, Chambless LE, Duncan BB, et al. Prediction of coronary heart disease in middle-aged adults with diabetes. Diabetes Care. Oct. 2003;26(10):2777-84. [pmid: 14514579].
120 Bhopal R, Fischbacher C, Vartiainen E, et al. Predicted and observed cardiovascular disease in South Asians: application of FINRISK, Framingham and SCORE models to Newcastle Heart Project data. J Public Health (Oxf). Mar. 2005;27(1):93-100. [pmid: 15749725].
121 Stephens JW, Ambler G, Vallance P, et al. Cardiovascular risk and diabetes. Are the methods of risk prediction satisfactory?. Eur J Cardiovasc Prev Rehabil. Dec. 2004;11(6):521-8. [pmid: 15580065].
122 Empana JP, Ducimetiere P, Arveiler D, et al. Are the Framingham and PROCAM coronary heart disease risk functions applicable to different European populations? The PRIME Study. Eur Heart J. Nov. 2003;24(21):1903-11. [pmid: 14585248].
123 Cooper JA, Miller GJ, Humphries SE. A comparison of the PROCAM and Framingham point-scoring systems for estimation of individual risk of coronary heart disease in the Second Northwick Park Heart Study. Atherosclerosis. Jul. 2005;181(1):93-100. [pmid: 15939059].
124 Woodward M, Brindle P, Tunstall-Pedoe H. Adding social deprivation and family history to cardiovascular risk assessment: the ASSIGN score from the Scottish Heart Health Extended Cohort (SHHEC). Heart. Feb. 2007;93(2):172-6. [pmid: 17090561].
125 Hippisley-Cox J, Coupland C, Vinogradova Y, et al. Derivation and validation of QRISK, a new cardiovascular disease risk score for the United Kingdom: prospective open cohort study. BMJ. Jul. 21. 2007;335(7611):136. [pmid: 17615182].
126 Wolf PA, D'Agostino RB, Belanger AJ, et al. Probability of stroke: a risk profile from the Framingham Study. Stroke. Mar. 1991;22(3):312-8. [pmid: 2003301].
127 D'Agostino RB, Wolf PA, Belanger AJ, et al. Stroke risk profile: adjustment for antihypertensive medication. The Framingham Study. Stroke. Jan. 1994;25(1):40-3. [pmid: 8266381].
128 Truelsen T, Lindenstrom E, Boysen G. Comparison of probability of stroke between the Copenhagen City Heart Study and the Framingham Study. Stroke. Apr. 1994;25(4):802-7. [pmid: 8160224].
129 Teramoto T, Shimada K, Uchiyama S, et al. Rationale, design, and baseline data of the Japanese Primary Prevention Project (JPPP)-a randomized, open-label, controlled trial of aspirin versus no aspirin in patients with multiple risk factors for vascular events. Am Heart J. Mar. 2010;159(3):361-9. [pmid: 20211296].
130 Bayer. ARRIVE: A Study to Assess the Efficacy and Safety of Enteric-Coated Acetylsalicylic Acid in Patients at Moderate Risk of Cardiovascular Disease (ARRIVE). http://clinicaltrials gov/ct2/show/record/NCT00501059?term=ARRIVE&rank=2 2013.
131 Guidelines and Protocols Advisory Committee. Cardiovascular disease - primary prevention. Victoria. BC Ministry of Health. 2008.
132 Guidelines and Protocols Advisory Committee. Diabetes Care. Victoria. BC Ministry of Health. 2010.
133 World Health Organization. Pocket Guidelines for Assessment and Management of Cardiovascular Risk. Geneva. 2007.
134 Hayden M, Pignone M, Phillips C, et al. Aspirin for the primary prevention of cardiovascular events: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. Jan. 15. 2002;136(2):161-72. [pmid: 11790072].
135 Wolff T, Miller T, Ko S. Aspirin for the primary prevention of cardiovascular events: an update of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. Mar. 17. 2009;150(6):405-10. [pmid: 19293073].
136 Calonge N, Lefevre M. USPSTF Response to the ATT Collaboration Meta-Analysis. U.S. Preventive Services Task Force. 2009.