# Abbreviations

AAA: Aspirin for Asymptomatic Atherosclerosis
ABI: ankle brachial index
ACC/AHA: American College of Cardiology/American Heart Association
ACCEPT-D: Aspirin and Simvastatin Combination for Cardiovascular Events Prevention Trial in Diabetes
ACE: angiotensin converting enzyme
adj: adjusted
AHRQ: Agency for Healthcare Research and Quality
ALLHAT: Antihypertensive and Lipid Lowering Treatment to Prevent Heart Attack
ARB: angiotensin receptor blocker
ARIC: Atherosclerosis Risk in Communities
ARMD: age-related macular degeneration
ASA: acetylsalicylic acid
ASCEND: A Study of Cardiovascular Events in Diabetes
ATP: Adult Treatment Panel
ATT: Antithrombotic Trialists
BMD: British Doctor's Trial
BMI: body mass index
CAD: coronary artery disease
CARDIA: Coronary Artery Risk Development in Young Adults
CCT: controlled clinical trial
CG: control group
CHD: coronary heart disease
CHF: congestive heart failure
CHS: Cardiovascular Health Study
CI: confidence interval
COX: cyclooxygenase
CVD: cardiovascular disease
DBP: diastolic blood pressure
dL: deciliter
DM: diabetes mellitus
ETDRS: Early Treatment Diabetic Retinopathy
FDA: Food and Drug Administration
FPG: fasting plasma glucose
GI: gastrointestinal
HbA1c: glycated hemoglobin
HDL: high-density lipoprotein
HOT: Hypertension Optimal Treatment
HR: hazard ratio
HTN: hypertension
ICD: International classification of disease
IG: intervention group
IHD: ischemic heart disease
IPD: individual patient data
ITT: intent-to-treat
JPAD: Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes
k: number of studies
kg: kilogram
KQ: key question
L: liter
LDL: low-density lipoprotein
m^2^: square meter
MA: meta-analysis
MESA: Multiethnic Study of Atherosclerosis
mg: milligram(s)
MI: myocardial infarction
mm: millimeters mercury
mmol: millimole
N: number
NICE: National Institute for Health and Care Excellence
NIH: National Institutes of Health
NR: not reported
NS: not significant
NSAIDs: nonsteroidal anti-inflammatory drugs
OR: odds ratio
PAD: peripheral arterial disease
PHS: Physician's Health Study
POPADAD: Prevention of Progression of Arterial Disease and Diabetes
PPI: proton pump inhibitor
PPP: Primary Prevention Project
py: person-years
QOD: every other day
RCT: randomized controlled trial
RR: relative risk
SSRI: selective serotonin reuptake inhibitor
SBP: systolic blood pressure
TC: total cholesterol
TIA: transient ischemic attack
TPT: Thrombosis Prevention Trial
UK: United Kingdom
US: United States
USPSTF: United States Preventive Services Task Force
WHO: World Health Organization
WHS: Women's Health Study