# Discussion

## Summary

Table 22 presents a summary of evidence for each KQ, which we discuss briefly next. Our meta-analysis of 10 primary prevention trials confirmed the conclusions from several other published meta-analyses, showing that aspirin reduces the risk of major CVD events (total MI, total stroke, or CVD death) by about 11 percent, which appears to be largely driven by a 20 percent reduction in nonfatal MI (Appendix E Table 3).33,72-75 This effect on nonfatal MI/coronary events persisted when pooling only trials using aspirin with average daily doses of 100 mg or less. When pooling trials with doses of 100 mg or less, a nonfatal stroke benefit emerged as statistically significant. Our meta-analysis showed a modest, statistically significant reduction in all-cause mortality, which was not persistent in sensitivity analyses of lower-dose aspirin (≤100 mg/day). This finding was not reported in other meta-analyses.33,72-75 A concurrent review concluded that modest reductions in all-cause mortality cannot completely be explained through CVD and/or cancer mortality reduction.50 It appears that the nonfatal MI/coronary event benefit begins sometime within the first 5 years of use. While we did not pool major GI bleeding events because of study heterogeneity and rarity of events, we qualitatively found that most trials supported an increased risk similar to those reported in four prior meta-analyses that showed an increase in major bleeding events, with statistically significant measures of association ranging from 1.54 to 1.70.^33,72,73,75^ Thus, in a primary prevention population, the net impacts on CVD prevention are modest and closely matched by increases in major bleeding risks.

Table 22 Summary of Evidence

Population | No. of Studies, No. of Observations (n), Design | Summary of Findings | Consistency/Precision | Reporting Bias | Overall Study Quality | Body of Evidence Limitations | EPC Assessment of Overall Strength of Evidence | Applicability
Key Question 1 (Health Outcomes)
Adults without known CVD | K=10 n=103,787 10 RCTs | Aspirin 50-650 mg/day does not have an effect on: total stroke (k=10), nonfatal stroke (k=9), CVD death (k=10), fatal MI + fatal stroke (k=9), or all-cause mortality (k=10). Aspirin 50-650 mg/day reduces the risk of major CVD events (total MI, total stroke, CVD death) by 11% (k=10; RR, 0.89 [95% CI, 0.84 to 0.95]; I^2^=0%), which appears to be largely driven by a 20% reduction in nonfatal MI (k=9; RR, 0.80 [0.72 to 0.88]; I^2^=62.8%). | By outcome: Major CVD events: Consistent. Reasonably precise. Nonfatal MI: Reasonably consistent. Imprecise. Nonfatal stroke: Inconsistent. Imprecise. Fatal MI: Inconsistent. Imprecise. Fatal stroke: Inconsistent. Imprecise. All-cause mortality: Consistent. Imprecise. | Undetected. | Fair | Substantial heterogeneity in populations, trial designs, aspirin dosing, and trial durations. Trials were mostly 4-6 years with 1 trial as long as 10 years. Trials powered for composite CVD outcomes of varying severity (fatal and nonfatal outcomes with some trials, including angina, revascularization in composite CVD outcome). The few studies that adjusted for any confounders did so inadequately. | MODERATE for reduction in CVD events. MODERATE for reduction in nonfatal MI. LOW for benefit vs. harm for nonfatal stroke. LOW for no effect in CVD death. LOW for individual outcomes of fatal MI and fatal stroke due to imprecision and inconsistency. MODERATE for no statistically different effect in all-cause mortality at 5-10 years. | Primary prevention populations including those with co-morbidities.
Key Question 1a (Subpopulations)
A priori subpopulations of adults without known CVD | Age: k=7; n=90,442, 7 RCTs Sex: k=10; n=103,787, 10 RCTs Diabetes: k=8; n=96,108, 8 RCTs HTN: k=5; n=85,816, 5 RCTs CVD risk: k=3; n=61,206, 3 RCTs Lipid levels: k=4; n=67,026, 4 RCTs ABI: k=2; n=4,626, 2 RCTs Smoking: k=3; n=64,486, 3 RCTs Race/ethnicity: k=0 | Aspirin consistently achieves a greater RR reduction in total MI in older age groups (age ≥65 years). The RR reduction for various CVD outcomes appears to be the same for men and women. Aspirin's effect on CVD outcomes is not modified in patients with diabetes selected for disease status only. There is insufficient evidence to make any conclusions about treatment modification for aspirin in any of the following subpopulations: CVD risk, lipid level, blood pressure level, ABI, smoking status, and race/ethnicity. | By subpopulation for specified CVD outcomes: Age: Reasonably consistent for total MI in trials, but not confirmed in IPD MA. Inconsistent for stroke, composite CVD outcome^*^. Insufficient for all-cause mortality (1 trial). Imprecise for MI, stroke, all-cause mortality, and composite CVD outcome^*^. Sex: Consistent, with major limitations and lack of adjustment for confounders for MI, thereby limiting credibility; inconsistent for stroke outcomes, all-cause mortality, and CVD composite outcome^*^. Imprecise for MI, stroke, all-cause mortality, and CVD composite outcomes^*^. Diabetes: Inconsistent and imprecise for all-cause mortality and stroke. Reasonably consistent and imprecise for MI. Consistent and imprecise for composite CVD^*^. ABI/lipids/smoking/CVD risk/HTN: Inconsistent. Imprecise for all CVD related outcomes. Race/ethnicity: N/A | Undetected, but possible due to limited reporting (i.e., unclear if a priori vs. posthoc subgroup analyses for many trials). | Age, sex, DM: Fair ABI/lipids/smoking/CVD risk/HTN/race/ethnicity: Poor | Trials were not powered for subgroup analyses. Subgroup analyses rarely reported interaction testing, never adequately controlled for confounders, and commonly did not specify timing of subgroup specification, lending it to potential bias. Moreover, few studies had direct evidence from within-study comparisons. | LOW to MODERATE for greater RR reduction for total MI in older adults (age ≥65 vs. <65 years). MODERATE that aspirin's effect on CVD-related outcomes is the same by sex. MODERATE that aspirin's effect on CVD composite outcomes^*^ and total MI is not modified based on diabetes disease status only. LOW that aspirin's effect on stroke and all-cause mortality is not modified based on diabetes disease status. INSUFFICIENT for any treatment modification in other subpopulations: CVD risk, lipid level, blood pressure levels, ABI, smoking status, race/ethnicity. | Subpopulation specific applicability
Key Question 1b (Dose, Formulation Duration)
Adults without known CVD | Dose: ≤100 mg: k=7; n=72,866; 7 RCTs; >100 mg: k=3; n=30,921; 3 RCTs Formulation: k=10; n=103,787; 10 RCTs Duration: k=10; n=103,787; 10 RCTS, specifically k=8 for time-to-event reporting; n=76,577; 8 RCTs | Aspirin at doses ≤100 mg/day reduces total stroke by 15% (k=7; RR, 0.85 [95% CI, 0.76 to 0.96]; I^2^=0%), driven by a reduction in nonfatal stroke (k=6; RR, 0.82 [95% CI, 0.71 to 0.95]; I^2^=0%). Aspirin at doses ≤100 mg/day reduces nonfatal MI by 15% (k=7; RR, 0.85 [95% CI, 0.75 to 0.97]; I^2^=52.1%), with some between-study variability. Aspirin doses of <325 mg/day reduces nonfatal MI by 22% (k=8; RR, 0.78 [95% CI, 0.70 to 0.87]; I^2^=65.5), with between-study variability, but doesn't affect nonfatal stroke (k=7; RR, 0.89 [95% CI, 0.78 to 1.01]; I^2^=23.2%) or total stroke (k=8; RR, 0.90 [95% CI, 0.81 to 1.01]; I^2^=18.3%). No conclusions can be made regarding benefit modification based on aspirin formulation. CVD benefit (largely from nonfatal MI) begins within the first 5 years of use (likely the first 1-2 years) and available evidence suggests there is no diminishing benefit through the first 4 to 5 years, with limited data for longer durations. | Dose: ≤100 and <325 mg/day for MI and stroke outcomes: Reasonably consistent. Imprecise. Formulation: Inconsistent. Imprecise. Duration: Consistent. Imprecise. | Undetected. | Fair | Heterogeneous dosing schedules and formulations. Time-to-event data reported in 8 trials for various outcomes. Trial durations mostly 4-6 years, with 1 trial of 10 years; no trial with aspirin administration longer than 10 years. | MODERATE that lower dose of aspirin (≤100 mg/day) reduces nonfatal MI and nonfatal stroke. MODERATE that aspirin's CVD-related treatment benefit (largely from nonfatal MI) begins within the first 5 years (likely years 1-2). INSUFFICIENT for any treatment modification by formulation. | Primary prevention populations, including those with co-morbidities.
Key Question 2 (Health Outcomes)
Adults without known CVD | k=9 n=100,076 9 RCTs Major GI bleeding: k=7; n=94,305; 7 RCTs Total hemorrhagic stroke: k=7; n=93,661; 7 RCTs ARMD: k=2; n=61,947; 2 RCTs | Qualitative synthesis shows that major GI bleeding and hemorrhagic stroke are more common in aspirin group; however, precise estimates of this increased risk are not possible. Major GI bleeding: 7 trials report this rare event (≤0.8%) and RRs were >1 in all but 1 trial, ranging from 1.13 to 8.10 in those 6 trials. An IPD MA showed a 50% increase in major GI and other extracranial bleeding (RR, 1.54 [95% CI, 1.30 to 1.82]). Total hemorrhagic stroke: 7 trials report this rare outcome (event rates, 0% to 0.5%) and showed nonstatistically significant mixed results, with RRs ranging from 0.68 to 4.01. 3 out of 7 trials had RRs <1 and 4 remaining trials show RRs of 1.24 to 2.14. PHS and WHS were the largest RCTs with consistent, nonsignificant trend toward harm, with adjRRs of 1.24 and 2.14. An IPD MA reported a nonstatistically significant trend of a higher incidence of hemorrhagic stroke in the aspirin group compared to the control group (RR, 1.32 [95% CI, 0.91 to 1.91]). ARMD: 2 large RCTs report no difference in ARMD with vision loss in the aspirin group compared to the control group (PHS adjRR, 0.78 [95% CI, 0.46 to 1.32]; WHS adjRR, 0.82 [95% CI, 0.64 to 1.06]). | By outcome Major GI bleeding: Consistent. Imprecise. Hemorrhagic stroke: Inconsistent. Imprecise. ARMD: Reasonably consistent. Imprecise. | Undetected. | Fair | Trial design, dose, duration, population heterogeneity and rare events limit ability to pool data. No trial reported ascertainment methods for GI bleeding. Major GI bleeding rare (≤0.8%). Total hemorrhagic stroke rare (≤0.5%). | MODERATE that there is an increase in major GI bleeding with aspirin, but estimates are imprecise. Based on 2 RCTs with >10 events in the control group in the general population (WHS, PHS), the RR estimate likely lies between 1.37 and 1.75. LOW for aspirin's effect on hemorrhagic stroke due to rare events. MODERATE that there is no difference in ARMD with vision loss with aspirin use. | Primary prevention populations including those with co-morbidities.
Key Question 2a (Subpopulations)
A priori subpopulations of adults without known CVD | Major GI bleeding: Age: k=1; n=18,790; 1 RCT Sex: k=6; n=92,911; 6 RCTs DM: k=1; n=2,539; 1 RCT HTN: k=1; n=18,790; 1 RCT 10-yr CVD risk: k=1; n=18,790; 1 RCT Lipids, ABI, smoking, race/ethnicity: k=0 Hemorrhagic stroke: Age: k=0 Sex: k=5; n=74,121; 5 RCTs DM: k=2; n=3,815; 2 RCTs HTN, lipids, ABI, CVD risk, smoking: k=0 DM: k=2; n=61,947 ARMD: Age, sex, smoking, alcohol, HTN, lipids, ABI, CVD risk, race/ethnicity: k=0 | Few trials report GI bleeding or hemorrhagic stroke by subgroup. Due to the rare occurrence of harm events in the entire populations studied, it is not possible to make conclusions regarding possible differential harms profile among subpopulations. Sex: Only 2 RCTs allow within trial comparisons showing major GI bleeding is more common in men vs. women, but no interaction testing done. Interaction testing in 2 RCTs reporting ARMD with or without vision loss by subgroup (unclear if analysis a priori) found no effect modifications for any subgroup, except 1 RCT showed HTN status altered the treatment effect, with hypertensive men having a statistically significant 65% reduction in ARMD (RR, 0.35 [95% CI, 0.15 to 0.83]; p =0.04 for interaction; no correction for multiple testing). | By outcome: Major GI bleeding: Age, DM, HTN, CVD risk, lipids, ABI, smoking, race/ethnicity: N/A (0-1 trial) Sex: Inconsistent. Imprecise. Hemorrhagic stroke: Age, DM, HTN, lipids, ABI, CVD risk, smoking, race/ethnicity: N/A (0 trials) Sex: Inconsistent. Imprecise. ARMD: Sex, age, smoking, alcohol, HTN, lipids, DM: Reasonably consistent (2 trials). Imprecise. | Undetected. | Poor | The most subgroup evidence for aspirin's bleeding risks exists for sex-specific subgroups, but rare events make numbers too unstable for conclusions. Zero to one trial for bleeding harms (major GI bleeding or hemorrhagic stroke) in any given subgroup (except sex). | INSUFFICIENT evidence that there is any modification in harm risk by subpopulation. | Primary prevention populations including those with co-morbidities.
Key Question 2b (Dose, Formulation Duration)
Adults without known CVD | Major GI bleeding: Dose: k=7; n=94,305; 7 RCTs Duration: k=7; n=94,305; 7 RCTs Formulation: k=7; n=94,305; 7 RCTs Hemorrhagic stroke: Dose: k=7; n=93,661; 7 RCTs Duration: k=7; n=93,661; 7 RCTs Formulation: k=7; n=93,661; 7 RCTs ARMD: k=2; n=61,947; 2 RCTs | In all RCTs, the bleeding events were rare, making it difficult to make generalizable conclusions regarding the relationship between aspirin dose, duration, formulation, and bleeding events. | By outcome: Major GI bleeding: Dose, duration, formulation: Inconsistent. Imprecise. Hemorrhagic stroke: Dose, duration, formulation: Inconsistent. Imprecise. ARMD: Dose, duration, formulation: Inconsistent. Imprecise. | Undetected. | Poor | Given the lack of precision in estimating major GI bleeding and hemorrhagic stroke harms when examining all trials, little can be said about how dose, duration, and formulation alter these harms. Given that only 2 RCTs examined ARMD, it is not possible to make conclusions regarding the impact of dose, duration, or formulation. | INSUFFICIENT that dose, duration, or formulation alters relative risks for bleeding harms. | Primary prevention populations including those with co-morbidities.

* Composite CVD outcome=Total MI + total stroke + CVD mortality.

Abbreviations: ABI = ankle brachial index; ARMD = age-related macular degeneration; CI = confidence interval; CVD = cardiovascular disease; DM = diabetes mellitus; GI = gastrointestinal; HTN = hypertension; IPD MA = individual participant data meta-analysis; MI = myocardial infarction; NA = not applicable; PHS = Physicians' Health Study; RCT = randomized, controlled trial; RR = relative risk; WHS = Women's Health Study.

## Risk-Based Approach

In any given population, the benefits of aspirin for primary prevention are directly related to the RR reduction realized from aspirin and the baseline risk of CVD events balanced by the serious harms of GI bleeding and hemorrhagic strokes. To maximize the effectiveness side of the equation, we must identify a subpopulation for whom either: 1) the RR reduction realized from aspirin is higher than the average population, or 2) the baseline risk of CVD events is higher than the average population and high enough to outweigh the serious bleeding risks. Our systematic review aimed to critically appraise the subpopulation literature to answer these questions and found that very few a priori subgroup analyses were available, even fewer performed interaction testing, and none adequately controlled for important confounders. There are four specific subpopulations of greatest interest: age, sex, diabetes, and baseline CVD risk. Given the few available subgroup analyses, we focused on within-study comparisons and did not pool data for any individual population subgroups because of few contributing studies, small numbers of events, trial design, and population heterogeneity.76-79

### Sex

For sex, our qualitative analysis of the 10 RCTs showed no pattern for sex- and outcome-specific trends in composite CVD events, MI/coronary events, or stroke outcomes, except in WHS, which was the largest primary prevention population of women studied to date (90% of whom were younger than age 65 years). WHS showed that while aspirin reduced ischemic stroke, it did not reduce total MI/coronary events, except in the oldest age group of women ( 65 years or older), where MI/coronary events were reduced by 34 percent in the aspirin group compared with the control group (RR, 0.66 [95% CI, 0.44 to 0.97]).58 Sex-specific meta-analyses of six of the 10 trials showed conflicting results: while one meta-analysis showed a sex-specific difference, with women realizing benefit for total and ischemic stroke and men realizing benefit for reduction in total MI, interaction testing and multivariate adjustment for other risk factors were not performed. Additionally, these findings were predominantly driven by the WHS results.61 It is possible that the relatively young age of the WHS population, together with lack of adjustment for confounders, including age, led to a sex- and outcome-specific conclusion in this meta-analysis.61 The ATT IPD meta-analysis of the same six trials showed that after controlling for multiple comparisons, the apparent sex-specific differences in MI/coronary events and ischemic stroke events were no longer statistically significant.33 Subsequent to the ATT publication, other meta-analyses have confirmed the findings of no sex-specific, outcome-specific differences in major CVD events.75 Furthermore, the lack of heterogeneity of treatment effect in the secondary aspirin prevention literature puts such sex-specific findings in question.33 Appendix E Table 4 provides a timeline of publications to illustrate the changing findings for sex-specific conclusions about aspirin for CVD prevention.

### Diabetes

From six trials with evidence on patients with diabetes, our qualitative synthesis found no effect modification based on diabetes status for any of our CVD-related outcomes. This confirms the findings from five prior systematic reviews that pooled three to six trials in populations or subpopulations with diabetes and showed no statistically significant reduction in CVD events, total MI, or total stroke,80-84 as well as a large Swedish observational study showing no CVD event, CVD mortality, or all-cause mortality benefit among diabetes patients.85 The suggested biologic plausibility of a lack of effect of aspirin in patients with diabetes could be based on aspirin resistance and possibly increased platelet turnover.86,87 Patients with diabetes are at a two- to four-fold risk for CVD events compared to those without diabetes;11-13 however, evidence suggests that is not a CHD risk equivalent, since diabetes patients have a 43 percent lower risk of CHD events compared with those with a known history of CHD events.88 Some have suggested that the use of aspirin in diabetes, therefore, lies somewhere between primary and secondary prevention. Results from two European cohorts further complicate the discussion of aspirin's net benefit for diabetes patients. One of these studies, an Italian population-based cohort using administrative data from more than 4 million individuals, showed that diabetes patients have an increased risk of major bleeding compared to those without diabetes regardless of aspirin use. This study did show, however, that aspirin use only marginally increases major bleeding rates in patients with diabetes compared to nonaspirin users with diabetes.89 The other study, a Swedish patient registry of 58,465 individuals, showed that aspirin use was associated with increased all-cause mortality in diabetes patients without CVD, particularly among older patients, after controlling for confounders.90 Both of these cohort studies have the major limitations of being administrative database analyses, which are particularly prone to erroneous conclusions of causality. Two large in progress RCTs enrolling more than 20,000 patients with diabetes may definitively answer this question regarding whether or not aspirin is effective for primary prevention in this population (A Study of Cardiovascular Events in Diabetes [ASCEND]91 and Aspirin and Simvastatin Combination for Cardiovascular Events Prevention Trial in Diabetes [ACCEPT-D]).92

### Age

Older adults were the only subpopulation for which there appears to be a differential benefit from aspirin. Studies consistently showed a greater RR reduction in total MI/coronary events among older age groups based on three trials,53,58,60 with WHS and HOT showing a statistically significant one-third reduction in total MI/coronary events for those age 65 years or older. Likewise, PHS showed similar reductions at age 50 years and older. Both PHS and WHS reported statistically significant p-values for heterogeneity of treatment effect for age for total MI/coronary events, and this statistic was not reported for HOT. This trend was not seen in the ATT IPD meta-analysis, however, as this trial did not find any heterogeneity of composite CVD events or coronary events based on age (<65 years compared to ≥65 years).33 Concerns about a greater absolute bleeding risk with increasing age, regardless of aspirin use,93 makes it important to quantify the RR reduction and balance it with higher bleeding risk. This is especially important for this subpopulation, as it appears that each decade of age confers a 50 percent increase in hemorrhagic stroke risk and doubles the risk of major extracranial bleeding.33 The ongoing Aspirin in Reducing Events in the Elderly (ASPREE) trial has recruited 19,000 men and women age 70 years or older and randomized them to aspirin (100 mg daily) versus placebo, with a primary outcome of all-cause mortality, dementia incidence, or physical disability and will hopefully provide more precise estimates of harms and benefits in the older adult population.94

### CVD Risk Approach

Given the lack of apparent treatment effectiveness modification based on individual risk characteristics, many international guideline panels have proposed a multiple risk factor-based approach. This approach uses a 10-year CVD risk calculator to identify a group with high risk for CVD events, thereby maximizing the absolute net benefits from aspirin.95 Comparisons of international guidelines reveal that there is wide variation in the risk threshold for aspirin primary prevention recommendations, ranging from 4 to 30 percent 10-year CHD or CVD risk, with several panels recommending against aspirin use for primary prevention, regardless of CVD risk category (Appendix E Table 1). The previous USPSTF recommendation recommended aspirin (75 mg/day) for various 10-year CHD or stroke risk thresholds based on age and sex.

The U.S. Food and Drug Administration (FDA) recently denied primary prevention of MI as an indication for aspirin in any risk group. This decision was based on a review of six primary prevention trials, study-level and IPD meta-analyses, and newer trials in special populations, from which the FDA concluded there was insufficient evidence to support this indication.96 In the rationale for its decision, the FDA stated that pooled results are generally not a basis for reaching effectiveness conclusions and furthermore that primary endpoints are given the greatest weight in interpreting evidence; in the case of aspirin for primary prevention, no study achieved statistically significant results for its planned primary endpoint as interpreted by FDA statistical reviewers.96

Clinical guideline implementation requires selection of a specific risk prediction tool. Available risk prediction tools vary widely across a number of domains, including the definition of CHD or CVD outcomes predicted, risk factors included, and variation in the baseline risk and other characteristics of model derivation cohorts (Appendix A, Appendix E Table 5). Limitations of risk equations include: nonrepresentative or historically dated populations, limited ethnic diversity in derivation populations, narrowly defined endpoints, endpoints influenced by provider preferences, endpoints with poor reliability, and inclusion or exclusion of novel risk factors.14,19,97

In November 2013, the ACC/AHA Guideline on the Assessment of Cardiovascular Risk was released. This guideline included a new “pooled cohort equation” for predicting 10-year risk of a first hard atherosclerotic CVD event, defined as nonfatal MI, CHD death, and fatal or nonfatal stroke.14 The derivation population included participants from four National Heart, Lung, and Blood Institute-sponsored community-based cohort studies (Atherosclerosis Risk in Communities [ARIC], Cardiovascular Health Study [CHS], Coronary Artery Risk Development in Young Adults [CARDIA], and Framingham/Framingham-Offspring), and this tool represented a departure from the previous narrower outcome focus of risk assessment for CHD.15 Additionally, while the inclusion of multiethnic populations in the derivation cohorts enabled race- and sex-specific equations for blacks and whites, this was not the case for Hispanics, Asians, and other ethnic subpopulations.14

Critics have voiced several concerns about the model's calibration, citing overprediction that was most notable in the highest risk group of greater than or equal to 10 percent 10-year risk. They also point out the model's discrimination has been summarized as moderate, at best, using c-statistics.14,98-100 In an unpublished in-process analysis, external validations of the ACC/AHA pooled cohort equation were performed for Hispanic men and women in the Multiethnic Study of Atherosclerosis (MESA) cohort and the Antihypertensive and Lipid Lowering Treatment to Prevent Heart Attack (ALLHAT) trial. Preliminary results of this analysis appear to be consistent with other studies that have suggested overprediction in populations other than non-Hispanic Caucasians (K. Shum, personal communication, 2014).14

Other externally validated U.S.-based models include CHD calculators based on Framingham data by Anderson, Wilson, and ATP III.8,15,16,25 Systematic reviews show that external validations of the Anderson and Wilson models have generally found that they overestimate risk in groups with low observed risk and underpredict risk in groups with higher risk.101,102 Evidence from direct comparisons of risk assessment tools suggests potentially small differences in performance across models,100,103 while others have argued that it is not appropriate to compare models head-to-head because of wide variation in outcome definitions, years of followup, and absolute risk categories.104

Despite the aforementioned shortcomings, the ACC/AHA pooled cohort calculator is, to date, the only U.S.-based CVD calculator that has published its external validations in other U.S.-based populations. Ideally, one could develop a model to apply the risk prediction equation for clinical care that would guide shared decisionmaking with patients regarding the risks and benefits of aspirin. Currently, a contemporaneous AHRQ-commissioned model hoping to address these needs is under development.105

## Harms

Our qualitative analysis, which was limited to major GI bleeding as defined by transfusion, hospitalization, or death, showed an increase in bleeding risk, although given trial heterogeneity, we were unable to estimate the effect with any precision; trials reported RRs between 0.50 and 8.10. Other published meta-analyses showed major bleeding ORs/RRs in the primary prevention trials ranging from 1.54 to 1.70.^33,72,73,75^ Given the rarity of hemorrhagic strokes, we were unable to precisely estimate this harm in aspirin users. Based on the emergence of a total stroke benefit with lower doses of aspirin, however, it is plausible that some of the hemorrhagic strokes caused by aspirin can be mitigated by lowering the dose.

An association with aspirin use and ARMD has been reported in one large U.S.-based cohort study106 and one cross-sectional European study107 of nonprimary prevention populations. This association, however, was not reported by our two included trials reporting this outcome.53,58

## Cotreatment With Statins or PPIs

Experts have suggested that additional considerations should inform aspirin treatment in patients taking other medications, such as statins and PPIs. While none of our 10 trials reported outcomes in statin users compared with nonusers, authoritative evidence shows that statins provide a 25 percent reduction in major vascular events in primary prevention populations.108 It is not clear whether the modest absolute benefit of aspirin seen in the primary prevention population would be further enhanced by concomitant use of statins, but there is an in progress trial assessing this issue in populations with diabetes.92 Until these results are published, it remains unclear how statins may modify aspirin-associated benefits or bleeding events.89

Our systematic review did not identify any eligible RCTs to address whether PPIs modify CVD effects with aspirin or bleeding risk in primary prevention populations. Co-administration of PPIs with low-dose aspirin to mitigate associated bleeding risks is being primarily pursued in those with indications for aspirin treatment (i.e., postCVD procedure or secondary prevention). For primary prevention populations without disease, trials of PPI/low-dose aspirin would be needed to determine the net effect, including whether the primary prevention aims are affected by this additional medication.

## Limitations of the Literature

There are several limitations of the literature. The 10 primary prevention studies are heterogeneous in terms of aspirin dose, duration of therapy, baseline population characteristics, comorbid conditions, and, most importantly, baseline CVD risk at trial entry. Additionally, trials were powered for composite outcomes combining fatal and nonfatal events of varying severity,109 where individual outcomes of MI and stroke were rare enough in this primary prevention population to make any findings of nonstatistical significance potentially due to lack of power. We were unable to draw any conclusions regarding formulation—specifically whether or not enteric coated aspirin has diminished GI bleeding risks. Because of the relatively short trial durations and lack of comparable time-to-event data reporting in the trials, we could not precisely determine the minimum time-to-benefit other than to conclude that the CVD-related benefits (i.e., nonfatal MI) occur during the first 5 years of therapy. As such, it remains unclear whether the nonfatal MI benefit continues to accrue at a constant rate beyond 5 to 10 years of use. Followup in most studies was 4 to 6 years, although only one trial provided extended observational followup at 18 years.67 As a result, we cannot exclude larger benefits conferred over a longer time period in a primary prevention population. While we found that ideal dosing for primary prevention is likely 100 mg per day or less, it is unclear if every other day dosing versus daily dosing makes a difference for CVD benefits. Additionally, some literature suggests that every other day dosing may not be sufficient for other types of aspirin benefit (i.e., cancer benefits).110 At this point, there is scant data to support any effect modification in any population. Subgroup analyses rarely reported interaction testing, never adequately controlled for confounders, and commonly did not specify timing of subgroup analyses, lending it to bias.110,111 Bleeding outcomes were variably reported, and given the general underreporting of harms112 and the restrictive inclusion criteria in RCTs, these trials likely underestimate bleeding risks in real practice.

## Limitations of Our Review

We limited our review to English-language, primary prevention literature for both effectiveness and harms; therefore, we only examined a subset of the harms literature. Moreover, we limited our review of bleeding to major GI bleeding, defined as requiring transfusion or hospitalization or leading to death; bleeding of lesser severity and trials that did not specify bleeding severity were not addressed. We did not examine other potential nonCVD benefits from aspirin (i.e., cancer benefits). Two contemporaneous AHRQ-commissioned systematic reviews, however, are addressing all of these issues.50,113

## Conclusions and Future Research Needs

Nearly half of the primary prevention trials recruited patients in the 1980s, and most trials reflect usual clinical care administered more than 20 years ago. Aspirin's potential role in primary prevention will continue to evolve based on the magnitude of a modest relative benefit balanced with bleeding risks in the context of declining smoking rates, increasing statin use, and more aggressive hypertension management. Recent trials44,45 ,43 published since the last review for the USPSTF35 focus on special populations for whom absolute risk reduction could outweigh bleeding harms; however, these trials failed to show any CVD benefit, even for the composite outcomes they were powered to detect. Nonetheless, we identified this question about aspirin's benefit in subpopulations as the area with the greatest evidence gaps. There remains a role for future research to identify subpopulations who may realize a clinically important net benefit from aspirin.

We identified the following research gaps:

- Concomitant therapy with statins or PPIs: RCT-level data are needed that examine the absolute benefit of aspirin with concurrent statin use in those deemed at elevated CVD risk. These data could further elucidate the nature of the effect of aspirin and statins combined in primary prevention populations, but it is crucial that these trials are sufficiently powered to assess hard CVD outcomes with long-term followup (>10 years). This research could also determine whether there are populations at high enough risk to realize a moderate benefit from aspirin use in primary prevention. Similarly, the impact of co-therapy with PPIs on the net effect of low-dose aspirin in primary prevention populations would inform this potential approach.
- Subpopulations with diabetes: Diabetes patients are an important subpopulation that needs further study. The pending ASCEND and ACCEPT-D trials could provide evidence for a role for aspirin in primary prevention for any subpopulations with diabetes.
- Racial/ethnic subpopulations: To date, there is no data available or in process RCTs addressing the role of aspirin used for primary prevention in racial/ethnic subpopulations; trials are needed to inform current practice.
- IPD meta-analyses: IPD meta-analyses provide important data that complement existing trial data. An updated IPD meta-analysis that includes the three new trials published since the ATT IPD meta-analysis33 and adjusts for confounders is needed to fully evaluate aspirin's effect in important subpopulations.