# Results

## Literature Search

Our literature search yielded 2,853 unique citations. From these, we provisionally accepted 61 articles for review based on titles and abstracts (Appendix B Figure 1). After screening the full-text articles, 10 trials (27 articles) were judged to have met the inclusion criteria for KQ 1 and nine trials (26 articles) met inclusion for KQ 2 (Appendix B Figure 1); the remaining articles were excluded (Appendix C).

## Overview of Included Studies

Ten major RCTs (two good-quality and eight fair-quality) investigated the benefits of aspirin for the primary prevention of cardiovascular morbidity and mortality.43-45,53-59 Nine of these studies examined the harms associated with aspirin use for primary prevention.43-45,53,54,56-59 Details on study design and baseline participant characteristics are included in Tables 1 and 2.

Table 1 Baseline Participant Characteristics of Included Trials for Aspirin for Primary Prevention of Cardiovascular Events

| BMD, 1988^57^ | PHS I, 1989^53^ | ETDRS, 1992^55^ | HOT, 1998^56^ | TPT, 1998^54^ | PPP, 2001^59^ | WHS, 2005^58^ | JPAD, 2008^43^ | POPADAD, 2008^44^ | AAA, 2010^45^
Quality | Fair | Good | Fair | Fair | Fair | Fair | Good | Fair | Fair | Fair
Country | UK | US | US | 26 countries^¶^ | UK | Italy | US | Japan | Scotland | UK
N Randomized | 5,139 | 22,071 | 3,711 | 18,790 | 2,540 | 4,495 | 39,876 | 2,539 | 1,276 | 3,350
Age, years (mean) | <60: 46.8% 60-69: 39.0% 70-79: 14.1% | 40-49: 41.0%^*^ 50-59: 33.8%^*^ 60-69: 18.5%^*^ 70-84: 6.7%^*^ | <30: 16.9^*^ 30-49: 31.5^*^ ≥50: 51.7^*^ | 61.5^*^ | 57.5^*^ | 64.4 | 54.6 | 64.5 | 60.3 | 62.0
% Female | 0 | 0 | 43.5^*^ | 47.0^*^ | 0 | 58.0 | 100.0 | 45.4 | 55.9 | 72
Hypertension
% HTN | 9.9 | NR | 44.4^*,†^ | 100 | NR | 68.0 | 25.9 | 58.0 | NR | NR
SBP/DBP, mm Hg (mean) | 135.8/NR | SBP: <109: 3.2^*^ 110-129: 52.6^*^ 130-149: 39.7^*^ ≥150: 4.5^*^ DBP: ≤69: 5.9^*^ 70-79: 31.4^*^ 80-89: 52.4^*^ ≥90: 10.4^*^ | SBP ≥130.0: 66.0%^*^ DBP ≥85.0: 39.1%^*^ | 170.0/105.0 | 139.0/NR^*^ | 145.2/85.4 | <120/<75: 32.6% 120-29/75-84: 32.0% 130-39/85-89: 19.4% ≥140/≥90: 16.0% | 135.0/76.5 | 145/79.0^*^ | 147.5/84.0
% Treated for HTN | NR | NR | NR | 100.0 | 1,421 participants treated during part or all of the trial | 66.0 | NR | Ca channel blocker: 34.5 ARB: 21.0 ACE: 14.7 β blocker: 6.4 α blocker: 3.6 | NR | Diuretic: 15.2 Nitrate/Ca channel blocker: 6.4 ACE/ARB: 6.2 β blocker: 9.8
Cholesterol
TC, mg/dL (mean) | NR | <159: 10.0^*^ 160-209: 39.1^*^ 210-259: 36.4^*^ ≥260: 14.6^*^ | NR | 235.5^*^ | 247.1^*^ | 235.5^*^ | NR | 201.0 | 212.4^*,#^ | 238.5
LDL, mg/dL (mean) | NR | NR | NR | NR | NR | 150.6^*^ | NR | NR | 119.7^*,#^ | NR
HDL, mg/dL (mean) | NR | NR | NR | NR | NR | 54.1^*^ | NR | 55 | 46.3^*,#^ | NR
% Treated for Cholesterol | NR | NR | NR | NR | NR | 16.0 | NR | 25.6 | NR | 4.0
Diabetes
% with Diabetes | 2.0 | 2.4^*^ | 100.0 | 8.0^*^ | NR | 17.0 | 2.6 | 100.0 | 100.0 | 3.0
FPG, mg/dL | NR | NR | NR | NR | NR | 109.9^*^ | NR | 147.0 | NR | NR
HbA1c, % | NR | NR | ≥10: 42.0%^*^ | NR | NR | NR | NR | 7.05 | 8.0 | NR
PAD
% with Abnormal ABI (≤0.99) | NR | NR | 9.4^*,‡^ | NR | NR | NR | NR | NR | 100.0 | 100.0
ABI (mean) | NR | NR | NR | NR | NR | NR | NR | NR | 0.9^*,#^ | 0.86
% Current Smokers | ≥21 cigarettes per day: 6.1 | 11.0^*^ | ≥6 cigarettes per day: 44.2^*^ | 15.9^*^ | 41.3^*^ | 15.0 | 13.1 | 21.2 | 31.1 | 33.0
Mean BMI (kg/m^2^) | NR | ≤23.0: 25.7^*^ 23.0-24.4: 24.1^*^ 24.4-26.3: 25.1^*^ ≥26.4: 25.0^*^ | ≥120% of desirable weight: 41.5^*^ | 28.4^*^ | 27.4^*^ | 27.6 | 26.0 | 24.0 | 29.2^*,#^ | NR
CVD Risk | NR | NR | NR | NR | All participants 20% or 25% of risk score^§^ | ≥3 CVD risk factors: 29% | Framingham 10-year CHD risk, %: <5.0%: 84.5 5.0-9.9%: 11.5 ≥10.0%: 4.0 | NR | NR | NR
% Prior CVD | Heart disease (excluding MI): 6.2 Other vascular disease: 3.6 TIA: 2.6 | 0 | MI: 5.6^*^ TIA: 1.5^*^ CAD: 7.7^*^ CHF: 2.8^*^ Stroke: 1.8^*^ | MI: 1.5^*^ Other CHD: 5.9^*^ Stroke: 1.2^*^ | 0 | 0 | 0 | 0 | 0 | 0
Annual Risk of Cardiovascular Events (%) ║ | 1.54 | 0.67 | 4.08 | 1.19 | 1.53 | 0.76 | 0.26 | 0.82 | 2.53 | 0.99

* Data calculated.

† Elevated BP (SBP ≥160 mm Hg or DBP ≥95 mm Hg) or on HTN medications.

‡ Intermittent claudication.

§ According to risk assessment tool derived from Northwick Park Heart Study variables.

║ Data are from Berger 2011 meta-analysis; calculated as percent with cardiovascular events in control group/years followup.

¶ 26 countries in Europe, North and South America, and Asia.

# Median.

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ABI = ankle brachial index; ACE = angiotensin-converting enzyme; ARB = angiotensin receptor blocker; BMD = British Doctor's Trial; BMI = body mass index; CAD = coronary artery disease; CHF = congestive heart failure; CVD = cardiovascular disease; DBP = diastolic blood pressure; ETDRS = Early Treatment Diabetic Retinopathy; FPG = fasting plasma glucose; HbA1c = glycated hemoglobin; HDL = high-density lipoprotein; HOT = Hypertension Optimal Treatment; HTN = hypertension; JPAD = Japanese Primary Prevention of Atherosclerosis With Aspirin for Diabetes; LDL = low-density lipoprotein; MI = myocardial infarction; N = number; NR = not reported; PAD = peripheral arterial disease; PHS = Physician's Health Study; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; PPP = Primary Prevention Project; SBP = systolic blood pressure; TC = total cholesterol; TIA = transient ischemic attack; TPT = Thrombosis Prevention Trial; UK = United Kingdom; US = United States; WHS = Women's Health Study.

Table 2 Methodological and Intervention Characteristics of Included Trials for Aspirin for Primary Prevention of Cardiovascular Events

| BMD, 1988^57^ | PHS I, 1989^53^ | ETDRS, 1992^55^ | HOT, 1998^56^ | TPT, 1998^54^ | PPP, 2001^59^ | WHS, 2005^58^ | JPAD, 2008^43^ | POPADAD, 2008^44^ | AAA, 2010^45^
Quality | Fair | Good | Fair | Fair | Fair | Fair | Good | Fair | Fair | Fair
Country | UK | US | US | 26 countries^§^ | UK | Italy | US | Japan | UK | UK
N Randomized | 5,139 | 22,071 | 3,711 | 18,790 | 2,540 | 4,495 | 39,876 | 2,539 | 1,276 | 3,350
Study Design | RCT | 2×2 RCT, Beta-carotene | 2×2 RCT, Early or delayed photocoagulation | 3×2 RCT, HTN treatment goals | 2×2 RCT, Warfarin | 2×2 RCT, Vitamin E | 2×2 RCT, Vitamin E | RCT | 2×2 RCT, Antioxidant | RCT
Inclusion | Male physicians | Male physicians ages 40-84 years | Men & women ages 18-70 years with diabetes & diabetic retinopathy | Men & women ages 50-80 years with HTN | Men ages 45-69 years at the top 20% or 25% of CVD risk score | Men & women age ≥50 years with at least 1 CVD risk factor | Female health professionals age ≥45 years | Men & women ages 30-85 years with diabetes | Men & women age ≥40 years with diabetes & asymptomatic PAD (ABI ≤0.99) | Men & women ages 50-75 years with ABI of ≤0.95
ASA Dose & Formulation | 500 mg daily, unspecified^*^ | 325 mg QOD, tablet, not enteric coated^†^ | 650 mg daily, tablet, not enteric coated | 75 mg daily, unspecified | 75 mg daily, controlled release capsule | 100 mg daily, enteric coated tablet | 100 mg QOD, tablet, not enteric coated | 100 mg daily, tablet, not enteric coated^‡^ | 100 mg daily, tablet, not enteric coated | 100 mg daily, tablet, enteric coated
ASA Duration & Mean Followup | 6 years | 5 years | 5 years | 3.8 years | 6.8 years║ | 3.6 years | 10.1 years | 4.37 years║ | 6.7 years║ | 8.2 years
Primary Endpoint | Mortality from stroke, MI, or other vascular conditions | CVD mortality | All-cause mortality | Composite of major CV events: fatal and nonfatal MI, fatal and nonfatal stroke, and death due to CVD | All IHD: coronary death and fatal and nonfatal MI Fatal IHD: coronary death and fatal MI | Composite outcome: cumulative rate of CV death, nonfatal MI, and nonfatal stroke | Composite outcome: major CV event, defined as a nonfatal MI, nonfatal stroke, or CVD death | Composite of any atherosclerotic event: sudden death; death from coronary, cerebrovascular, or aortic causes; nonfatal acute MI; unstable angina; newly developed exertional angina; nonfatal ischemic and hemorrhagic stroke; TIA; or nonfatal aortic and peripheral vascular disease | 2 composite end points: 1) death from CHD or stroke, nonfatal MI or stroke, above ankle amputation for critical limb ischemia; 2) death from CHD or stroke | Composite outcome: initial (earliest) fatal or nonfatal coronary event or stroke or revascularization
Secondary Endpoints | Nonfatal vascular and nonvascular events: MI, CVA, TIA, bleeding, other vascular conditions and nonfatal malignant neoplasms, respiratory events, cataracts, migraines, musculoskeletal disorders | MI events (fatal and nonfatal), strokes (fatal and nonfatal), all-cause mortality | Cause-specific mortality, CV events (fatal and nonfatal MI, stroke), amputations, kidney disease or failure | Fatal and nonfatal MI or stroke, CVD mortality, total mortality, death from kidney failure, change in eGFR, major and minor hemorrhage | Stroke (thrombotic and hemorrhagic) | CV death, total death, nonfatal MI, total CV events: CV deaths, total deaths, total CV events (defined as nonfatal MI, nonfatal stroke, angina, TIA, PAD, revascularization procedures) | MI, stroke, CVD mortality, all-cause mortality | Each primary end point and combinations of primary end points and death from any cause; adverse events: reported GI events, any hemorrhagic events other than CVA | All-cause mortality, nonfatal MI, and occurrence of other vascular events | 1) All initial vascular events, defined as a composite outcome: primary end point event or angina, intermittent claudication, or TIA; 2) all-cause mortality
Adherence & Crossover | At 1 year, 19.5% of IG stopped ASA, and at 5 years, 24.8% stopped ASA | At 5 years, 85.7% in IG was still taking ASA or platelet- active drug; 14.2% of CG reported taking ASA or other antiplatelets | At 1 year, 8.2% of IG was not taking drug; at 5 years, 89% of IG was taking ASA (70%) or other platelet-affecting drug (19%). In CG, 71% was taking only placebo and 18% was taking known platelet-affecting drug. | NR | According to tablet counts, about 2% of tablets were missed at followup visits; serum salicylate was measured in a subsample, with 6.8% in IG indicating no recent ASA use | At 1 year, 19.2% of IG was no longer taking ASA; at the end of surveillance, 19.3% was no longer taking ASA | Compliance was defined as use on at least 120 days per year: Year 1: 88% Year 5: 76% Year 10: 67% Trial average: 73% | At trial end, 90.3% of participants were taking ASA | At 1 year, 14% of participants stopped taking trial drugs; at 5 years, 50% (cumulative) of patients withdrew from trial therapy^¶^ | At 5 years, those taking ASA did so for 88% of person-years throughout trial

* Patients had the option to select either 500 or 300 mg per day of either effervescent aspirin or an enteric coated tablet.

† General tablet formulation unspecified; however, 624 participants in IG requested enteric-coated preparation and 16 requested Ecotrin.

‡ Patients could take either 81 or 100 mg daily.

§ 26 countries in Europe, North and South America, and Asia.

║ Median.

¶ Unclear how adherence information was ascertained.

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ABI = ankle brachial index; ASA = aspirin; BMD = British Doctor's Trial; CHD = coronary heart disease; CG = control group; CV = cardiovascular; CVA = cerebrovascular accident; CVD = cardiovascular disease; eGFR = epidermal growth factor receptor; ETDRS = Early Treatment Diabetic Retinopathy Study; HOT = Hypertension Optimal Treatment; HTN = hypertension; IHD = ischemic heart disease; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis With Aspirin for Diabetes; MI = myocardial infarction; N = number; NR = not reported; PAD = peripheral arterial disease; PHS = Physician's Health Study; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; PPP = Primary Prevention Project; QOD = every other day; RCT = randomized, controlled trial; TIA = transient ischemic attack; TPT = Thrombosis Prevention Trial; UK = United Kingdom; US = United States; WHS = Women's Health Study.

## KQ 1 Does Regular Aspirin Use in Patients Without Known CVD Reduce MI, Stroke, Death From MI or Stroke, or All-Cause Mortality?

### Summary of Results

Based on a meta-analysis of the 10 primary prevention aspirin RCTs, aspirin appears to have a statistically significant, although modest, benefit on nonfatal MI/coronary events. It also showed a benefit for the composite outcomes of nonfatal stroke combined with nonfatal MI/coronary events and total stroke combined with total MI/coronary events (including CVD death). These composite findings were again largely driven by the reduction in nonfatal MI/coronary events. All-cause mortality may be unchanged or slightly reduced with aspirin; the statistically significant modest reduction was not persistent with sensitivity analyses in lower doses, nor was it seen in an IPD meta-analysis. A pooled analysis that only included low-dose aspirin trials (≤100 mg/day) showed a modest reduction in total stroke while still retaining much of the nonfatal MI benefit. All 10 trials were powered for composite outcomes, making it difficult to determine if the nonstatistically significant findings with some individual outcomes were due to lack of power. Each of the trials recruited participants from unique patient subpopulations, thereby making pooling potentially less useful for clinical application.

### Trial Characteristics

Ten major RCTs (N=103,787), two good-quality and eight fair-quality, investigated the benefits of aspirin for the primary prevention of cardiovascular morbidity and mortality.43-45,53-59 These trials were conducted in the United Kingdom,44,45,54,57 the United States, 53,55,58 Japan,43 Italy,59 or were multinational.56 Six were conducted in the 1980s or 1990s,53-57,59 with four trials starting recruitment in the mid-1990s or later.43-45,58 Recent trials44,45 ,43 published since the last review for the USPSTF35 focus on special populations with diabetes, abnormal ABI, or both. While all 10 included studies were RCTs, the Japanese Primary Prevention of Atherosclerosis With Aspirin for Diabetes (JPAD) trial 43 and the Primary Prevention Project (PPP)59 were open-label trials.

Six of the 10 trials included 2×2 factorial designs with cotreatments of vitamins/antioxidants,44,53,58,59 photocoagulation,55 or warfarin.54 One trial, the Hypertension Optimal Treatment (HOT) trial, was a 3×2 factorial design wherein patients were initially randomized to one of three diastolic blood pressure targets, then each of the target blood pressure groups were randomized to aspirin or placebo.56

The 10 primary prevention RCTs randomized a total of 103,787 participants with individual trial sizes ranging from 1,276 to 39,876 participants. The largest two trials were substantially larger than any other trials and both funded by the National Institutes of Health; the Women's Health Study (WHS) included more than 39,000 participants and its male counterpart, the Physicians' Health Study (PHS), included more than 22,000 participants.53,58 Overall, followup times in the trials ranged from 3.6 to 10.1 years. PPP had the shortest followup time of less than 4 years.59 The Aspirin for Asymptomatic Atherosclerosis (AAA) trial and WHS had the longest followup times of 8 and 10 years, respectively.45,58

Seven of the trials administered aspirin at a dosage of 100 mg or less daily or every other day;43-45,54,56,58,59 one trial used 325 mg every other day,53 one used 500 mg daily,57 and one used 650 mg daily.55 Half of the studies specified tablet formulation; two used enteric coated45,59 and three trials used other or unspecified formulations.43,44,56 Control groups received placebo,44,45,53-56,58 nothing,43,59 or were advised to avoid aspirin products.57 Cotreatments included betacarotene,53 antioxidant combination (alpha-tocopherol, ascorbic acid, pyridoxine hydrochloride, zinc sulphate, nicotinamide, lecithin, and sodium selenite),44 vitamin E,58,59 or warfarin.54 Almost all of the trials were government sponsored, with the exception of HOT and the British Medical Doctor's (BMD) trial, which were industry sponsored.56,57

Primary outcomes for seven trials were cardiovascular event composites, which involved combining cardiovascular mortality events and nonfatal events defined variably;43-45,54,56,58,59 two trials' primary outcomes were cardiovascular mortality event composites,53,57 and one trial's primary outcome was all-cause mortality.55 Secondary outcomes generally included several of the following: event rates for individual outcomes of fatal stroke, nonfatal stroke, fatal MI, nonfatal MI, cardiovascular mortality, or all-cause mortality. Eight studies specified stroke etiology as hemorrhagic versus ischemic.43-45,53,54,57-59 It is important to note that all of the trials were only powered to detect differences in the composite outcomes. Harms outcomes were reported quite variably and included, for some (but not all) trials, one or more of the following: GI bleeding,43-45,54,56-59 fatal GI bleeding,53,56,58 subarachnoid/subdural hemorrhage,43,45,56 major bleeding composites,45,56 44-54 hemorrhagic/peptic ulcers,43,45,57,58 bleeding requiring transfusion,43,53,58 and/or minor bleeding.43,45,53-56,58,59 Bleeding events were variably defined and ascertainment unreported for most trials.

MI and stroke were clearly defined using World Health Organization (WHO) or modified AHA criteria in all except two trials—BMD and the Early Treatment Diabetic Retinopathy Study (ETDRS).55,57 Cardiovascular deaths were variably defined and often included events outside of fatal MI/coronary events or fatal stroke, such as deaths due to rheumatic fever, pulmonary embolism, abdominal aortic aneurysm, or hypertensive disease. Events were ascertained using a combination of death certificates, national registries, hospital and outpatient records, autopsies (when available), and physician and patient questionnaires. Independent blinded endpoint committees confirmed events in all trials.

PHS and WHS had run-in periods of 12 to 18 weeks.53,58 Compliance with aspirin therapy in the intervention group was variably reported and ascertained from participant questionnaires in the eight studies reporting compliance. The Thrombosis Prevention Trial (TPT) was the only trial that used pill counts or salicylate levels to measure compliance/crossover. At 5 years, PHS, BMD, and ETDRS reported 70 to 89 percent of participants taking aspirin or other platelet affecting drugs.53,55,57 Despite TPT's nearly 50 percent withdrawal rate, those continuing in both groups missed only 2 percent of tablets based on pill counts and only 6.8 percent in the intervention group had salicylate levels indicating no recent aspirin use. At the end of the trial (median, 4.37 years), JPAD reported 90 percent compliance in the aspirin group.43 At 5 years, the Prevention of Progression of Arterial Disease and Diabetes (POPADAD) trial reported that 50 percent of the total participants were not taking their assigned tablets (placebo or aspirin).44 Followup data on mortality events was available for 97 to 100 percent of participants in all RCTs except JPAD, which had 92.4 percent followup completion. Three trials reported less than 1 percent withdrawal rates.43-45 TPT had a high withdrawal rate of 42 percent at 5 years.54 Six trials did not report withdrawals.53,55-59

All trials used ITT analyses. All but one trial55 clearly reported valid random assignment procedures. Proper allocation concealment was reported in seven trials.43-45,53-56 Seven of the RCTs reported adequate blinding of providers, patients, and outcome assessors. One trial57 did not clearly report blinding and two trials were open-label.43,59 Trials reported outcome associations predominantly as RRs, with a few as hazard ratios (HRs), and only four trials adjusted their primary outcome for confounders.45,53,55,58

### Participant Characteristics

Three trials were conducted in healthy male or female health care professionals.53,57,58 Seven trials included participants who would be considered at higher than average cardiovascular risk: patients with diabetes;43 patients with diabetic retinopathy;55 patients with diabetes and ABI less than or equal to 0.99;^44^ patients with hypertension;56 individuals with abnormal ABI less than or equal to 0.95;^45^ individuals with at least one CVD risk factor;59 or those at high risk for ischemic disease based on the Northwick Park Heart Study algorithm.54 The lower age limit of inclusion in ETDRS was 18 years, but it ranged from 30 to 40 years in other trials. HOT and JPAD specified age 80 and 85 years as upper limits, while POPADAD specified no upper age limit. All studies were intended to target primary prevention candidates and excluded participants with a history of stroke or MI, except HOT and TPT, which only excluded those with an MI/coronary event or stroke in the recent past or occurring in the 12 months prior to recruitment. All studies excluded those taking current or regular aspirin therapy, as well as those with aspirin contraindications or allergies. Seven of the trials excluded those with a history of peptic ulcer disease,43,44,53,54,57 GI hemorrhage,55 or severe indigestion.45 Four trials excluded those with poor survival prognosis.44,55,56,59

In the seven studies that reported mean ages, the mean age was relatively young and ranged from 54.6 to 64.5 years.43-45,54,56,58,59 Ninety percent of WHS participants were younger than 65 years; 75 percent of PHS participants were younger than 60 years. Three trials recruited only men,53,54,57 one trial recruited only women,58 and six trials included both sexes, with 43.5 to 71.5 percent being women.43-45,55,56,59 Only WHS and ETDRS, both U.S.-based RCTs, reported information on race. WHS reported 5.2 percent of participants were nonwhite and ETDRS reported 23.6 percent of participants were nonwhite.55,58 Other than the JPAD trial that was conducted in Japan,43 most of the trials, especially the European trials, probably recruited predominantly Caucasian participants.

Participants' baseline cardiovascular event risks varied widely, as evidenced by the incidence of a composite of CVD events (all MI/coronary events combined with all stroke and CVD death) in the control groups ranging from 2.6 percent over 10.1 years (annualized 0.2% per year, assuming a constant event rate) in WHS (a population of female health professionals) to 20.4 percent over 5 years (annualized 4.1% per year) in ETDRS, a population with diabetic retinopathy. All 10 RCTs reported the percent of current smokers at baseline, which ranged from 6.1 to 44.2 percent. Mean or median body mass index (BMI) at baseline was only reported in six trials and ranged from 24.0 to 29.2 kg/m2.^54,56,58,59,43,44^ Six trials reported the percent of patients with hypertension at baseline, which ranged from 9.9 to 68.0 percent in five trials,43,55,57-59 and one trial was exclusively in participants with hypertension.56 Only four trials reported dyslipidemia frequency at baseline, ranging from 29.5 to 53.0 percent.43,55,58,59 Nine trials reported diabetes comorbidity, with four trials including 2.0 to 3.0 percent participants with diabetes,53,57,58 45 one trial including 8.0 percent diabetes patients,56 one trial including 17 percent diabetes patients,59 and three trials were exclusively conducted in diabetes patients.43,44,55 Three trials reported less than 10 percent of participants had prior CVD.55-57

### Results by Outcome

#### Effect of Aspirin on All-Cause Mortality

Ten trials reported the outcome of all-cause mortality with all showing nonstatistically significant results.43-45,53-59 Nine trials reported RRs of 0.81 to 0.96 and one trial reported an RR crossing 1 (Figure 2, Table 3).54 A pooled analysis showed that aspirin has a statistically significant effect on all-cause mortality (RR, 0.94 [95% confidence interval (CI), 0.88 to 0.99]; I^2^=0%). A sensitivity analysis using the Peto OR yielded similar results (OR, 0.93 [95% CI, 0.88 to 0.99]; I^2^=0%) (Table 4). The Antithrombotic Trialists (ATT) IPD meta-analysis of six trials did not show an all-cause mortality benefit with aspirin use (RR, 0.95 [95% CI, 0.88 to 1.02]).33

Figure 2 Forest Plot of All-Cause Mortality, Sorted by Length of Followup

Figure 2 displays a forest plot of studies reporting the relative risk for the intervention group versus the control group for all-cause mortality. This figure is described further under KQ 1 of the review.

Table 3 Summary of Composite and Mortality Outcomes of Included Trials for Aspirin for Primary Prevention of Cardiovascular Events

| | BMD, 1988^57^ | PHS I, 1989^53^ | ETDRS, 1992^55^ | HOT, 1998^56^ | TPT, 1998^54^ | PPP, 2001^59^ | WHS, 2005^58^ | JPAD, 2008^43^ | POPADAD, 2008^44^ | AAA, 2010^45^
Quality | | Fair | Good | Fair | Fair | Fair | Fair | Good | Fair | Fair | Fair
Mean Followup | | 6 years | 6 years | 5 years | 3.8 years | 6.8 years^**^ | 3.6 years | 10.1 years | 4.4 years^**^ | 6.7 years^**^ | 8.2 years
Primary Composite CVD Outcome Reported in Trials^¶^ | IG events/n (%) | NR | 307/11,037 (2.8%) | 350/1,856 (18.9%) | 315/9,399 (3.4%) | 83/1,268 (6.5%) | 45/2,226 (2.0%) | 477/19,934 (2.4%) | 68/1,262 (5.4%) | 116/638 (18.2%) | 181/1,675 (10.8%)
Primary Composite CVD Outcome Reported in Trials^¶^ | CG events/n (%) | NR | 370/11,034 (3.4%) | 379/1,855 (20.4%) | 368/9,391 (3.9%) | 107/1,272 (8.4%) | 64/2,269 (2.8%) | 522/19,942 (2.6%) | 86/1,277 (6.7%) | 117/638 (18.3%) | 176/1,675 (10.5%)
Primary Composite CVD Outcome Reported in Trials^¶^ | IG vs. CG | NR | Adj RR^‡^ (95% CI): 0.82 (0.70 to 0.96), p=0.01 | Adj RR^§^ (99% CI): 0.90 (0.74 to 1.09), Z test: -1.21 | RR (95% CI): 0.85 (0.73 to 0.99), p=0.03 | NR | RR (95% CI): 0.71 (0.48 to 1.04), p=0.04 | AdjRR║ (95% CI): 0.91 (0.80 to 1.03), p=0.13 | HR (95% CI): 0.80 (0.58 to 1.10), p=0.16 | HR (95% CI): 0.98 (0.76 to 1.26), p=0.86 | Adj HR^†^ (95% CI): 1.00 (0.81 to 1.23)
Composite Fatal MI/Coronary Events + Stroke + CVD Death | IG events/n (%) | 119/3,429 (3.5%)^*^ | 66/11,037 (0.6%)^*^ | 244/1,856 (13.1%) | 133/9,399 (1.4%) | 42/1,268 (3.3%)^*^ | 17/2,226 (0.8%) | 120/19,934 (0.6%)^*^ | 1/1,262 (0.1%) | 43/638 (6.7%) | 35/1,675 (2.1%)^*^
Composite Fatal MI/Coronary Events + Stroke + CVD Death | CG events/n (%) | 59/1,710 (3.4%)^*^ | 72/11,034 (0.7%)^*^ | 275/1,855 (14.8%) | 140/9,391 (1.5%) | 40/1,272 (3.1%)^*^ | 31/2,269 (1.4%) | 126/19,942 (0.6%)^*^ | 10/1,277 (0.8%) | 35/638 (5.5%) | 30/1,675 (1.8%)^*^
Composite Fatal MI/Coronary Events + Stroke + CVD Death | IG vs. CG | RR (95% CI): 1.01 (0.74 to 1.37)^*^ | RR (95% CI): 0.92 (0.66 to 1.28) | Adj RR^§^ (99% CI): 0.87 (0.69 to 1.09), Z test: -1.47 | RR (95% CI): 0.95 (0.75 to 1.20), p=0.65 | RR (95% CI): 1.05 (0.69 to 1.61)^*^ | Adj RR (95% CI): 0.56 (0.31 to 0.99), p=0.049 | RR (95% CI): 0.95 (0.74 to 1.22)^*^ | HR (95% CI): 0.10 (0.01 to 0.79), p=0.0037 | HR (95% CI): 1.23 (0.79 to 1.93), p=0.36 | RR (95% CI): 1.17 (0.72 to 1.89)^*^
Composite Nonfatal MI/Coronary Events + Stroke | IG events/n (%) | 141/3,429 (4.1%)^*^ | 239/11,037 (2.2%)^*^ | NR | NR | 63/1,268 (5.0%)^*^ | 30/2,226 (1.3%)^*^ | 382/19,934 (1.9%)^*^ | 39/1,262 (3.1%)^*^ | 84/638 (13.2%)^*^ | 99/1,675 (5.9%)^*^
Composite Nonfatal MI/Coronary Events + Stroke | CG events/n (%) | 68/1,710 (4.0%)^*^ | 305/11,034 (2.8%)^*^ | NR | NR | 98/1,272 (7.7%)^*^ | 40/2,269 (1.8%)^*^ | 425/19,942 (2.1%)^*^ | 36/1,277 (2.8%)^*^ | 97/638 (15.2%)^*^ | 106/1,675 (6.3%)^*^
Composite Nonfatal MI/Coronary Events + Stroke | IG vs. CG | RR (95% CI): 1.03 (0.78 to 1.37)^*^ | RR (95% CI): 0.78 (0.66 to 0.93)^*^ | NR | NR | RR (95% CI): 0.64 (0.47 to 0.88)^*^ | RR (95% CI): 0.76 (0.48 to 1.22)^*^ | RR (95% CI): 0.90 (0.78 to 1.03)^*^ | RR (95% CI): 1.10 (0.70 to 1.71)^*^ | RR (95% CI): 0.87 (0.66 to 1.14)^*^ | RR (95% CI): 0.93 (0.72 to 1.22)^*^
All-Cause Mortality | IG events/n (%) | 270/3,429 (7.9%)^*^ | 217/11,037 (2.0%) | 340/1,856 (18.3%) | 284/9,399 (3.0%) | 113/1,268 (8.9%) | 62/2,226 (2.8%) | 609/19,934 (3.1%) | 34/1,262 (2.7%) | 94/638 (14.7%) | 176/1,675 (10.5%)
All-Cause Mortality | CG events/n (%) | 151/1,710 (8.8%)^*^ | 227/11,034 (2.1%) | 366/1,855 (19.7%) | 305/9,391 (3.2%) | 110/1,272 (8.6%) | 78/2,269 (3.4%) | 642/19,942 (3.2%) | 38/1,277 (3.0%) | 101/638 (15.8%) | 186/1,675 (11.1%)
All-Cause Mortality | IG vs. CG | RR (95% CI): 0.89 (0.74 to 1.08)^*^ p=NS | Adj RR^‡^ (95% CI): 0.96 (0.8 to 1.14), p=0.64 | Adj RR^§^ (99% CI): 0.91 (0.75 to 1.11), Z test: -1.10 | RR (95% CI): 0.93 (0.79 to 1.09), p=0.36 | RR (95% CI): 1.03 (0.80 to 1.32)^*^ | RR (95% CI): 0.81 (0.58 to 1.13) | Adj RR║ (95% CI): 0.95 (0.85 to 1.06), p=0.32 | HR (95% CI): 0.90 (0.57 to 1.14), p=0.67 | HR (95% CI): 0.93 (0.71 to 1.24), p=0.63 | HR (95% CI): 0.95 (0.77 to 1.16)
Mortality From Other Causes | IG events/n (%) | NR | NR | 87/1,856 (4.7%) | NR | NR | 45/2,226 (2.0%) | NR | 18/1,262 (1.4%)^*^ | NR | NR
Mortality From Other Causes | CG events/n (%) | NR | NR | 85/1,855 (4.6%) | NR | NR | 47/2,269 (2.0%) | NR | 9/1,277 (0.7%)^*^ | NR | NR
Mortality From Other Causes | IG vs. CG | NR | NR | Z test: 0.15 | NR | NR | RR (95% CI): 0.98 (0.65 to 1.46) | NR | NR | NR | NR

* Calculated.

† Adjusted for baseline age, ankle-brachial index, cholesterol, systolic blood pressure, smoking, and socioeconomic status.

‡ RR adjusted for age and assignment to beta-carotene.

§ Adjusted for age >30 years; age >50 years; male; nonwhite; type I diabetes; type 2 diabetes; and clinical center. P-values reported only for unadjusted RRs, adjusted RRs abstracted above.

║ RR adjusted for age and treatment assignment.

¶ See Table 2 for definitions of composites reported in trials.

** Median.

Abbreviations: AAA = Aspiring for Asymptomatic Atherosclerosis Trial; Adj = adjusted; BMD = British Medical Doctor's Study; CG = control group; CI = confidence interval; CVD = cardiovascular disease; ETDRS = Early Treatment Diabetic Retinopathy Study; HOT = Hypertension Optimal Treatment Study; HR = hazard ratio; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes Study; MI = myocardial infarction; n = population; NR = not reported; NS = not significant; PHS = Physician's Health Study; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; PPP = Primary Prevention Project; RR = relative risk; TPT = Thrombosis Prevention Trial; WHS = Women's Health Study.

Table 4 Primary Meta-Analysis Results

Outcome | k | Mantel-Haenszel Fixed Effects RR (95% CI) | I^2^ (%) | Peto OR (95% CI) | I^2^ (%)
Primary Outcomes
Death from MI/coronary events, stroke, other CVD | 10 | 0.94 (0.85 to 1.03) | 16.4 | 0.93 (0.84 to 1.03) | 31.3
Nonfatal stroke | 9 | 0.94 (0.84 to 1.06) | 32.3 | 0.94 (0.84 to 1.06) | 31.8
Nonfatal MI/coronary events | 9 | 0.80 (0.72 to 0.88) | 62.8 | 0.79 (0.71 to 0.88) | 61.4
All-cause mortality | 10 | 0.94 (0.88 to 0.99) | 0 | 0.93 (0.88 to 0.99) | 0
Secondary Outcomes
Total stroke | 10 | 0.95 (0.86 to 1.05) | 28.4 | 0.95 (0.86 to 1.05) | 28.6
Total MI/coronary events | 10 | 0.85 (0.79 to 0.92) | 52.1 | 0.84 (0.78 to 0.91) | 51.4
Fatal MI/coronary events | 10 | 0.94 (0.82 to 1.09) | 15.5 | 0.93 (0.81 to 1.08) | 17.4
Fatal MI/coronary events plus fatal stroke | 9 | 0.96 (0.83 to 1.10) | 29.5 | 0.94 (0.82 to 1.09) | 41.8
Nonfatal MI/coronary events plus nonfatal stroke | 8 | 0.86 (0.79 to 0.93) | 16.2 | 0.86 (0.79 to 0.93) | 16.9
MI/coronary events and stroke (fatal plus nonfatal) plus CVD death | 10 | 0.89 (0.84 to 0.95) | 0 | 0.88 (0.83 to 0.94) | 0
Any reported CVD composite | 9 | 0.89 (0.84 to 0.94) | 0 | 0.88 (0.82 to 0.94) | 0

Abbreviations: CI = confidence interval; CVD = cardiovascular disease; k = number of studies; OR = odds ratio; MI = myocardial infarction; RR = relative risk.

#### Effect of Aspirin on MI/Coronary Events

Table 5 presents MI/coronary event results for the 10 trials included for this KQ.43-45,53-59 Total MI/coronary event incidence in the control group ranged from 1 percent over 10.1 years in WHS43,58 (annualized 0.1% per year assuming constant event rate) to 15 percent over 5 years in ETDRS (annualized 3.1% per year),55 which reflects a wide range of baseline risk. For total MI/coronary events (fatal combined with nonfatal), two trials showed a statistically significant benefit with aspirin53,56 and the remaining eight trials had CIs crossing 1, with five trials favoring aspirin,43,54,55,57,59 two trials favoring the control,44,45 and one showing no effect (Figure 3, Table 5).58 The two trials53,56 that showed a statistically significant benefit reported an RR of 0.67 (95% CI, 0.55 to 0.80) and 0.74 (95% CI, 0.60 to 0.91). A pooled analysis for total MI/coronary events showed a statistically significant effect with high heterogeneity (RR, 0.85 [95% CI, 0.79 to 0.92]; I^2^=52.1%) (Figure 3, Table 4). While diabetes status, aspirin dose, year of publication, and effect size were explored to explain the high heterogeneity, none of these variables elucidated its presence.

Table 5 Summary of MI/Coronary Event Outcomes of Included Trials for Aspirin for Primary Prevention of Cardiovascular Events

| | BMD, 1988^57^ | PHS I, 1989^53,¶^ | ETDRS, 1992^55^ | HOT, 1998^56^ | TPT, 1998^54^ | PPP, 2001^59^ | WHS, 2005^58^ | JPAD, 2008^43^ | POPADAD, 2008^44^ | AAA, 2010^45^
Quality | | Fair | Good | Fair | Fair | Fair | Fair | Good | Fair | Fair | Fair
Mean Followup | | 6 years | 6 years | 5 years | 3.8 years | 6.8 years^†^ | 3.6 years | 10.1 years | 4.37 years^†^ | 6.7 years^†^ | 8.2 years
Total MI/Coronary Events | IG events/n (%) | 169/3,429 (4.9%)^*^ | 139/11,037 (1.2%) | 241/1,856 (13.0%) | 153/9,399 (1.6%)^*^ | 83/1,268 (6.5%)^*^ | 19/2,226 (0.8%) | 198/19,934 (1.0%) | 12/1,262 (1.0%)^*^ | 90/638 (14.1%)^*^ | 90/1,675 (5.4%)^*^
Total MI/Coronary Events | CG events/n (%) | 88/1,710 (5.1%)^*^ | 239/11,034 (2.2%) | 283/1,855 (15.3%) | 207/9,391 (2.2%)^*^ | 107/1,272 (8.4%)^*^ | 28/2,269 (1.2%) | 193/19,942 (1.0%) | 14/1,277 (1.1%)^*^ | 82/638 (12.9%)^*^ | 86/1,675 (5.1%)^*^
Total MI/Coronary Events | IG vs. CG | RR (95% CI): 0.96 (0.75 to 1.23)^*^ | Adj RR^‡^ (95% CI): 0.56 (0.45 to 0.70), p<0.00001 | Adj RR^§^ (99% CI): 0.82 (0.65 to 1.03), Z test: -1.99 | RR (95% CI): 0.74 (0.60 to 0.91)^*^ | RR (95% CI): 0.78 (0.59 to 1.03)^*^ | RR (95% CI): 0.69 (0.38 to 1.23) | Adj RR║ (95% CI): 1.02 (0.84 to 1.25), p=0.83 | RR (95% CI): 0.87 (0.40 to 1.87)^*^ | RR (95% CI): 1.10 (0.83 to 1.45)^*^ | RR (95% CI): 1.05 (0.78 to 1.40)^*^
Fatal MI/Coronary Events | IG events/n (%) | 89/3,429 (2.6%)^*^ | 56/11,037 (0.5%)^*^ | 47/1,856 (2.5%) | 85/9,399 (0.9%)^*^ | 36/1,268 (2.8%) | 4/2,226 (0.2%)^*^ | 14/19,934 (0.1%) | 0/1,262 (0%) | 35/638 (5.5%) | 28/1,675 (1.7%)
Fatal MI/Coronary Events | CG events/n (%) | 47/1,710 (2.7%)^*^ | 65/11,034 (0.6%)^*^ | 67/1,855 (3.6%) | 94/9,391 (1.0%)^*^ | 34/1,272 (2.7%) | 6/2,269 (0.3%)^*^ | 12/19,942 (0.1%) | 5/1,277 (0.4%) | 26/638 (4.1%) | 18/1,675 (1.1%)
Fatal MI/Coronary Events | IG vs. CG | RR (95% CI): 0.94 (0.67 to 1.34)^*^, p=NS | RR (95% CI): 0.86 (0.60 to 1.23)^*^ | RR (95% CI): 0.70 (0.49 to 1.01)^*^ Z test: -1.91 | RR (95% CI): 0.90 (0.67 to 1.21)^*^ | RR (95% CI): 1.06 (0.67 to 1.69)^*^ | RR (95% CI): 0.68 (0.19 to 2.40)^*^ | Adj RR║ (95% CI): 1.16 (0.54 to 2.51), p=0.70 | RR (95% CI): 0.10 (0.01 to 1.85)^*^ | HR (95% CI): 1.35 (0.81 to 2.25), p=0.24 | RR (95% CI): 1.56 (0.86 to 2.80)^*^
Nonfatal MI/Coronary Events | IG events/n (%) | 80/3,429 (2.3%)^*^ | 129/11,037 (1.2%) | NR | 68/9,399 (0.7%)^*^ | 47/1,268 (3.7%) | 15/2,226 (0.7%) | 184/19,934 (0.9%) | 12/1,262 (1.0%) | 55/638 (8.6%) | 62/1,675 (3.7%)
Nonfatal MI/Coronary Events | CG events/n (%) | 41/1,710 (2.4%)^*^ | 213/11,034 (1.9%) | NR | 113/9,391 (1.2%)^*^ | 73/1,272 (5.7%) | 22/2,269 (1.0%) | 181/19,942 (0.9%) | 9/1,277 (0.7%) | 56/638 (8.8%) | 68/1,675 (4.1%)
Nonfatal MI/Coronary Events | IG vs. CG | RR (95% CI): 0.97 (0.67 to 1.41)^*^, p=NS | Adj RR^‡^ (95% CI): 0.59 (0.47 to 0.74), p<0.00001 | NR | RR (95% CI): 0.60 (0.45 to 0.81)^*^ | RR (95% CI): 0.65 (0.45 to 0.92)^*^ | RR (95% CI): 0.69 (0.36 to 1.33) | Adj RR║ (95% CI): 1.01 (0.83 to 1.24), p=0.90 | HR (95% CI): 1.34 (0.57 to 3.19), p=0.50 | HR (95% CI): 0.98 (0.68 to 1.43), p=0.93 | RR (95% CI): 0.91 (0.65 to 1.28)^*^

* Calculated.

† Median.

‡ RR adjusted for age and assignment to beta-carotene.

§ Adjusted for age >30 years; age >50 years; male; nonwhite; type 1 diabetes; type 2 diabetes; and clinical center. P-values reported only for unadjusted RRs, adjusted RRs abstracted above.

║ RR adjusted for age and treatment assignment.

¶ Fatal and nonfatal events may not add up to total events because of first-event analyses in some outcomes.

Abbreviations: AAA = Aspiring for Asymptomatic Atherosclerosis Trial; Adj = adjusted; BMD = British Medical Doctor's Study; CG = control group; CI = confidence interval; ETDRS = Early Treatment Diabetic Retinopathy Study; HOT = Hypertension Optimal Treatment Study; HR = hazard ratio; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes Study; MI = myocardial infarction; n = population; NR = not reported; NS = not significant; PHS = Physician Health Study; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; PPP = Primary Prevention Project; RR = relative risk; TPT = Thrombosis Prevention Trial; WHS = Women's Healthy Study.

Figure 3 Forest Plot of Total MI/Coronary Events (Fatal and Nonfatal), Sorted by Length of Followup

Figure 3 displays a forest plot of studies reporting the relative risk for the intervention group versus the control group for total MI/coronary events. This figure is described further under KQ 1 of the review.

As with total MI/coronary events, fatal event rates in the control groups varied widely, with the lowest annualized incidence in WHS and highest in ETDRS55,58 (Figure 4, Table 5). All trials reported no statistically significant effect of aspirin on fatal MI/coronary events. Six trials reported a trend favoring aspirin,43,53,55-57,59 while the other four trials favored the control group.44,45,54,58 A pooled analysis from these 10 trials showed a nonstatistically significant reduction in fatal MI/coronary events (RR, 0.94 [95% CI, 0.82 to 1.09]; I^2^=15.5%) (Figure 4, Table 4). Sensitivity analyses using the Peto OR yielded similar results (Table 4).

Figure 4 Forest Plot of Fatal MI/Coronary Events, Sorted by Length of Followup

Figure 4 displays a forest plot of studies reporting the relative risk for the intervention group versus the control group for fatal MI/coronary events. This figure is described further under KQ1 of the review.

Nonfatal MI/coronary event rates in the control group again varied among the nine trials, with the lowest annualized incidence in WHS and highest in POPADAD.44,58 Three trials showed a statistically significant benefit for aspirin53,54,56 and two additional trials showed results trending in this direction (Figure 5, Table 4).45,59 While three trials' point estimates were near 1^44,57,58^ and only one trial showed a trend toward favoring the control group, these results were based on few reported events (9/1,277 in the control group, 12/1,262 in the aspirin group).43 A pooled analysis showed a statistically significant benefit for aspirin in preventing nonfatal MI/coronary events similar to that seen for total MI/coronary events and again, heterogeneity was high (RR, 0.80 [95% CI, 0.72 to 0.88]; I^2^=62.8%) (Figure 5, Table 4). A sensitivity analysis using the Peto OR yielded similar results (Peto OR, 0.79 [95% CI, 0.71 to 0.88]; I^2^=61.4%) (Table 4). Exploration of this heterogeneity by aspirin dose, date of publication, and diabetes status did not explain heterogeneity.

Figure 5 Forest Plot of Nonfatal MI/Coronary Events, Sorted by Length of Followup

Figure 5 displays a forest plot of studies reporting the relative risk for the intervention group versus the control group for nonfatal MI/coronary events. This figure is described further under KQ1 of the review.

#### Effect of Aspirin on Stroke

Table 6 presents stroke results for the 10 trials. Total stroke incidence ranged from 1.3 percent over 10.1 years in WHS (annualized rate of 0.13% per year assuming a constant event rate) to 7.8 percent over 6.7 years in POPADAD (annualized rate of 1.2% per year) in the control groups.44,58 For total stroke (fatal combined with nonfatal), one trial showed a statistically significant benefit favoring aspirin (RR, 0.83 [95% CI, 0.69 to 0.99]);58 four trials showed a similar trend, although their results were not statistically significant (Figure 6, Table 6).43,45,54,59 Conversely, three trials showed a nonstatistically significant trend favoring the control, with RR point estimates ranging from 1.16 to 1.22.^53,55,57^ A pooled analysis examining aspirin's effect on total stroke events showed no effect (RR, 0.95 [95% CI, 0.86 to 1.05]; I^2^=28.4%) (Figure 6, Table 4). Sensitivity analyses showed that pooling only trials using low-dose aspirin (defined as ≤100 mg) showed a modest statistically significant benefit (RR, 0.85 [95% CI, 0.76 to 0.96]; I^2^=0), while pooling the high-dose trials alone showed no difference (RR, 1.19 [95% CI, 1.00 to 1.42]; I^2^=0%), suggesting a stroke benefit using lower doses of aspirin (Table 7).

Table 6 Summary of Stroke Outcomes of Included Trials for Aspirin for Primary Prevention of Cardiovascular Events

| | BMD, 1988^57^ | PHS I, 1989^53,#^ | ETDRS, 1992^55^ | HOT, 1998^56^ | TPT, 1998^54^ | PPP, 2001^59^ | WHS, 2005^58^ | JPAD, 2008^43^ | POPADAD, 2008^44^ | AAA, 2010^45^
Quality | | Fair | Good | Fair | Fair | Fair | Fair | Good | Fair | Fair | Fair
Mean Followup | | 6 years | 6 years | 5 years | 3.8 years | 6.8 years^†^ | 3.6 years | 10.1 years | 4.37 years^†^ | 6.7 years^†^ | 8.2 years
Total Stroke | IG events/n (%) | 91/3,429 (2.7%)^*^ | 119/11,037 (1.1%) | 92/1,856 (5.0%) | 146/9,399 (1.6%) | 18/1,268 (1.4%) | 16/2,226 (0.7%) | 221/19,934 (1.1%) | 28/1,262 (2.2%) | 37/638 (5.8%)^*^ | 44/1,675 (2.6%)^*^
Total Stroke | CG events/n (%) | 39/1,710 (2.3%)^*^ | 98/11,034 (0.9%) | 78/1,855 (4.2%) | 148/9,391 (1.6%) | 26/1,272 (2.0%) | 24/2,269 (1.1%) | 266/19,942 (1.3%) | 32/1,277 (2.5%) | 50/638 (7.8%)^*^ | 50/1,675 (3.0%)^*^
Total Stroke | IG vs. CG | RR (95% CI): 1.16 (0.80 to 1.69)^*^ | Adj RR^‡^ (95% CI): 1.22 (0.93 to 1.60), p=0.15 | Adj RR^§^ (99% CI): 1.17 (0.79 to 1.74), Z test: 1.10 | RR (95% CI): 0.98 (0.78 to 1.24), p=0.88 | RR (95% CI): 0.69 (0.38 to 1.26)^*^ | RR (95% CI): 0.67 (0.36 to 1.27) | Adj RR║ (95% CI): 0.83 (0.69 to 0.99), p=0.04 | HR (95% CI): 0.84 (0.53 to 1.32), p=0.44 | RR (95% CI): 0.74 (0.49 to 1.12)^*^ | RR (95% CI): 0.88 (0.59 to 1.31)^*^
Fatal Stroke | IG events/n (%) | 30/3,429 (0.9%)^*^ | 10/11,037 (0.1%)^*^ | 25/1,856 (1.3%) | NR | 2/1,268 (0.2%) | 1/2,226 (0.04%)^*^ | 23/19,934 (0.1%) | 1/1,262 (0.1%) | 8/638 (1.3%) | 7/1,675 (0.4%)
Fatal Stroke | CG events/n (%) | 12/1,710 (0.7%)^*^ | 7/11,034 (0.01%)^*^ | 25/1,855 (1.3%) | NR | 1/1,272 (0.1%) | 6/2,269 (0.3%)^*^ | 22/19,942 (0.1%) | 5/1,277 (0.4%) | 9/638 (1.4%) | 12/1,675 (0.7%)
Fatal Stroke | IG vs. CG | RR (95% CI): 1.25 (0.64 to 2.43)^*^ | RR (95% CI): 1.44 (0.54 to 3.88)^*^ | RR (95% CI): 1.00 (0.58 to 1.73)^*^ Z test: 0.00 | NR | RR (95% CI): 2.01 (0.18 to 22.10)^*^ | RR (95% CI): 0.17 (0.02 to 1.41)^*^ | Adj RR║ (95% CI): 1.04 (0.58 to 1.86), p=0.90 | HR (95% CI): 0.20 (0.024 to 1.74), p=0.15 | HR (95% CI): 0.89 (0.34 to 2.30), p=0.80 | RR (95% CI): 0.58 (0.23 to 1.48)^*^
Nonfatal Stroke | IG events/n (%) | 61/3,429 (1.8%)^*^ | 110/11,037 (1.0%) | 67/1,856 (3.6%)^*^ | NR | 16/1,268 (1.3%)^*^ | 15/2,226 (0.7%) | 198/19,934 (1.0%) | 27/1,262 (2.1%)^*^ | 29/638 (4.6%) | 37/1,675 (2.2%)
Nonfatal Stroke | CG events/n (%) | 27/1,710 (1.6%)^*^ | 92/11,034 (0.8%) | 53/1,855 (2.9%)^*^ | NR | 25/1,272 (2.0%)^*^ | 18/2,269 (0.8%) | 244/19,942 (1.2%) | 27/1,277 (2.1%)^*^ | 41/638 (6.4%) | 38/1,675 (2.3%)
Nonfatal Stroke | IG vs. CG | RR (95% CI): 1.13 (0.72 to 1.77), p=NS | Adj RR^‡^ (95% CI): 1.20 (0.91 to 1.59), p=0.20 | RR (95% CI): 1.26 (0.89 to 1.80)^*^ | NR | RR (95% CI): 0.64 (0.34 to 1.20)^*^ | RR (95% CI): 0.84 (0.42 to 1.67) | Adj RR║ (95% CI): 0.81 (0.67 to 0.97), p=0.02 | RR (95% CI): 1.01 (0.60 to 1.72)^*^ | HR (95% CI): 0.71 (0.44 to 1.14), p=0.15 | RR (95% CI): 0.97 (0.62 to 1.52)^*^
Total Ischemic Stroke | IG events/n (%) | NR | 91/11,037 (0.8%) | NR | NR | 10/1,268 (0.8%) | NR | 170/19,934 (0.8%) | NR | NR | 30/1,675 (1.8%)^*^
Total Ischemic Stroke | CG events/n (%) | NR | 82/11,034 (0.7%) | NR | NR | 18/1,272 (1.4%) | NR | 221/19,942 (1.1%) | NR | NR | 37/1,675 (2.2%)^*^
Total Ischemic Stroke | IG vs. CG | NR | Adj RR^‡^ (95% CI): 1.11 (0.82 to 1.50), p=0.50 | NR | NR | RR (95% CI): 0.56 (0.26 to 1.20)^*^ | NR | Adj RR║ (95% CI): 0.76 (0.63 to 0.93), p=0.009 | NR | NR | RR (95% CI): 0.81 (0.50 to 1.31)^*^
Fatal Ischemic Stroke | IG events/n (%) | 8/3,429 (0.2%)^*^ | 3/11,037 (0.03%) | NR | NR | NR | NR | NR | NR | 3/638 (0.5%) | 2/1,675 (0.1%)
Fatal Ischemic Stroke | CG events/n (%) | 3/1,710 (0.2%)^*^ | 3/11,034 (0.03%) | NR | NR | NR | NR | NR | NR | 5/638 (0.8%) | 7/1,675 (0.4%)
Fatal Ischemic Stroke | IG vs. CG | RR (95% CI): 1.33 (0.35 to 5.01)^*^ | RR (95% CI): 1.00 (0.20 to 4.95)^*^ | NR | NR | NR | NR | NR | NR | RR (95% CI): 0.60 (0.14 to 2.50)^*^ | RR (95% CI): 0.29 (0.06 to 1.37)^*^
Nonfatal Ischemic Stroke | IG events/n (%) | 13/3,429 (0.4%)^*^ | 88/11,037 (0.8%)^*^ | NR | NR | NR | NR | NR | 22/1,262 (1.7%) | NR | 28/1,675 (1.7%)
Nonfatal Ischemic Stroke | CG events/n (%) | 4/1,710 (0.2%)^*^ | 79/11,034 (0.7%)^*^ | NR | NR | NR | NR | NR | 24/1,277 (1.9%) | NR | 30/1,675 (1.8%)
Nonfatal Ischemic Stroke | IG vs. CG | RR (95% CI): 1.62 (0.53 to 4.96)^*^ | RR (95% CI): 1.11 (0.82 to 1.51)^*^ | NR | NR | NR | NR | NR | HR (95% CI): 0.93 (0.52 to 1.66), p=0.80 | NR | RR (95% CI): 0.93 (0.56 to 1.56)^*^

* Calculated.

† Median.

‡ RR adjusted for age and assignment to beta-carotene.

§ Adjusted for age >30 years; age >50 years; male; nonwhite; type 1 diabetes; type 2 diabetes; and clinical center. P-values reported only for unadjusted RRs, adjusted RRs abstracted above.

║ RR adjusted for age and treatment assignment.

¶ Adjusted for baseline age, ankle-brachial index, cholesterol, systolic blood pressure, smoking, socioeconomic status, and sex.

# Fatal and nonfatal events may not add up to total events because of first-event analyses in some outcomes.

Abbreviations: AAA = Aspiring for Asymptomatic Atherosclerosis Trial; Adj = adjusted; BMD = British Medical Doctor's Study; CG = control group; CI = confidence interval; ETDRS = Early Treatment Diabetic Retinopathy Study; HOT = Hypertension Optimal Treatment Study; HR = hazard ratio; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes Study; n = population; NR = not reported; NS = not significant; PHS = Physician's Health Study; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; PPP = Primary Prevention Project; RR = relative risk; TPT = Thrombosis Prevention Trial; WHS = Women's Health Study.

Figure 6 Forest Plot of Total Stroke Events (Fatal and Nonfatal), Sorted by Length of Followup

Figure 6 displays a forest plot of studies reporting the relative risk for the intervention group versus the control group for total stroke events. This figure is described further under KQ1 of the review.

Table 7 Results of Dose Sensitivity Analyses for Total Stroke

Outcome | k | Mantel-Haenszel Fixed Effects RR (95% CI) | I^2^ (%) | Peto OR (95% CI) | I^2^ (%)
Total stroke low dose (<325 mg) | 8 | 0.90 (0.81 to 1.01) | 18.3 | 0.91 (0.81 to 1.01) | 19.5
Total stroke high dose (≥325 mg) | 2 | 1.18 (0.93 to 1.49) | 0 | 1.18 (0.93 to 1.49) | 0
Total stroke low dose (≤100 mg) | 7 | 0.85 (0.76 to 0.96) | 0 | 0.86 (0.76 to 0.96) | 0
Total stroke high dose (>100 mg) | 3 | 1.19 (1.00 to 1.42) | 0 | 1.19 (1.00 to 1.43) | 0

Abbreviations: CI = confidence interval; OR = odds ratio; RR = relative risk.

Fatal stroke events were rare in the control group and varied among the trials with the lowest annualized incidence in WHS and the highest in ETDRS (Figure 7, Table 6).55,58 Four trials showed a nonstatistically significant trend favoring aspirin, with RR point estimates ranging from 0.17 to 0.89.^43-45,59^ Two trials showed no difference with an RR of 1^55,58^ and three trials53,54,57 showed a nonstatistically significant trend favoring the control with RRs of 1.25 to 2.01. We did not conduct a pooled analysis examining aspirin's effect on fatal stroke events because of the rarity of the event (six RCTs reported ≤10 events in either treatment group).

Figure 7 Forest Plot of Fatal Stroke Events, Sorted by Length of Followup

Figure 7 displays a forest plot of studies reporting the relative risk for the intervention group versus the control group for fatal stroke events. This figure is described further under KQ1 of the review.

The annualized incidence of nonfatal stroke reported in the control groups varied 10-fold between WHS with the lowest incidence and POPADAD with the highest (Table 6).44,58 Results were mixed, however, with RR point estimates ranging from 0.64 to 1.26 (Figure 8).54,55 One trial showed a statistically significant benefit for aspirin,58 three trials showed a trend toward benefit with aspirin,44,54,59 and two trials showed essentially no difference.43,45 Three included trials, on the other hand, showed a nonstatistically significant trend favoring the control.53,55,57 A pooled analysis from these nine trials showed no difference in nonfatal stroke effects in the aspirin group compared to the control group (RR, 0.94 [95% CI, 0.84 to 1.06]; I^2^=32.3%) (Figure 8, Table 4).

Figure 8 Forest Plot of Nonfatal Stroke Events, Sorted by Length of Followup

Figure 8 displays a forest plot of studies reporting the relative risk for the intervention group versus the control group for nonfatal stroke events. This figure is described further under KQ1 of the review.

In the four trials that reported total stroke by subtype,45,53,54,58 one trial showed a statistically significant reduction in total ischemic stroke (fatal combined with nonfatal) in the aspirin group,58 two trials showed a trend in this direction,45,54 and one trial showed a nonstatistically significant trend favoring the control (Figure 9, Table 6).53 We did not pool data for stroke by subtype because few studies reported this rare outcome.

Figure 9 Forest Plot of Total Ischemic Stroke Events (Fatal and Nonfatal), Sorted by Length of Followup

Figure 9 displays a forest plot of studies reporting the relative risk for the intervention group versus the control group for total ischemic stroke events. This figure is described further under KQ1 of the review.

The majority of ischemic strokes were nonfatal (Table 6). The two trials reporting both fatal and nonfatal ischemic strokes showed that fatal ischemic stroke represented only 3.6 and 13.4 percent of total ischemic strokes.45,53 Fatal ischemic events were rare in the four trials reporting this outcome, with three to seven events in the control groups and mixed results with no statistically significant findings (Figure 10, Table 6).44,45,53,57 Similarly, four trials reported nonfatal ischemic stroke outcomes and reported no statistically significant results in any of the trials with mixed results,43,45,53,57 with the two trials with higher dosage aspirin trending toward favoring the control (Figure 11, Table 6).53,57 Hemorrhagic stroke is later addressed as a harm in KQ 2 results.

Figure 10 Forest Plot of Fatal Ischemic Stroke Events, Sorted by Length of Followup

Figure 10 displays a forest plot of studies reporting the relative risk for the intervention group versus the control group for fatal ischemic stroke events. This figure is described further under KQ1 of the review.

Figure 11 Forest Plot of Nonfatal Ischemic Stroke Events, Sorted by Length of Followup

Figure 11 displays a forest plot of studies reporting the relative risk for the intervention group versus the control group for nonfatal ischemic stroke events. This figure is described further under KQ1 of the review.

#### Effect of Aspirin on Fatal MI/Coronary Events Combined With Fatal Stroke

Nine trials contributed events to the composite outcome of fatal MI/coronary events combined with fatal stroke (Figure 12).43-45,53-55,57-59 Only one trial reported a statistically significant reduction in this fatal composite, appearing as an outlier with the most impressive RR in favor of aspirin and a wide CI (RR, 0.10 [95% CI, 0.01 to 0.79]).43 The remaining eight trials showed no statistically significant difference. Of these, three trials showed trends in favor of aspirin, two in favor of the control,53,55,59 and three trials with RRs near 1.^53,54,57,58^ A pooled analysis showed a nonsignificant effect with aspirin treatment (RR, 0.96 [95% CI, 0.83 to 1.10]; I^2^=29.5%) (Figure 12, Table 4). Sensitivity analyses revealed similar conclusions (Peto OR, 0.94 [95% CI, 0.82 to 1.09]; I^2^=41.8%) (Table 4).

Figure 12 Forest Plot of Fatal MI/Coronary Events Combined With Fatal Stroke Events, Sorted by Length of Followup

Figure 12 displays a forest plot of studies reporting the relative risk for the intervention group versus the control group for fatal MI/coronary events combined with fatal stroke events. This figure is described further under KQ1 of the review.

#### Effect of Aspirin on Fatal MI/Coronary Events Combined With Fatal Stroke and CVD Mortality

Ten trials contributed to the composite outcome of fatal MI/coronary events combined with fatal stroke and CVD mortality (Figure 13). Results for individual trials were not substantially different for this composite compared to the fatal MI/coronary events combined with fatal stroke composite. A pooled analysis showed no statistically significant effect with aspirin (RR, 0.94 [0.85 to 1.03]; I^2^=16.4%) (Figure 13, Table 4). Sensitivity analyses yielded similar results (Table 4).

Figure 13 Forest Plot of Fatal MI/Coronary Events Combined With Fatal Stroke Events and CVD Mortality, Sorted by Length of Followup

Figure 13 displays a forest plot of studies reporting the relative risk for the intervention group versus the control group for fatal MI/coronary events combined with fatal stroke events and CVD mortality. This figure is described further under KQ1 of the review.

#### Effect of Aspirin on Nonfatal MI/Coronary Events Combined With Nonfatal Stroke

Eight trials contributed to the composite outcome of nonfatal MI/coronary events combined with nonfatal stroke (Figure 14). Two trials showed a statistically significant reduction in events,53,54 four trials showed a nonsignificant trend in the same direction,44,45,58,59 and two trials showed nonsignificant RRs just above 1.^43,57^ A pooled analysis showed a statistically significant benefit in this nonfatal composite outcome (RR, 0.86 [95% CI, 0.79 to 0.93]; I^2^= 16.2%) (Figure 14, Table 4). Sensitivity analyses yielded nearly identical results (Table 4).

Figure 14 Forest Plot of Nonfatal MI/Coronary Events Combined With Nonfatal Stroke Events, Sorted by Length of Followup

Figure 14 displays a forest plot of studies reporting the relative risk for the intervention group versus the control group for nonfatal MI/coronary events combined with nonfatal stroke events. This figure is described further under KQ1 of the review.

#### Effect of Aspirin on Total MI/Coronary Events Combined With Total Stroke and CVD Mortality

Ten trials contributed to the composite outcome of total MI/coronary events combined with total stroke and CVD mortality (Figure 15).43-45,53-59 Three trials showed a statistically significant benefit with RR point estimates ranging from 0.76 to 0.85,^53,54,59^ while five trials had nonstatistically significant results in the same direction.43,44,55,56,58 Two trials had RRs near 1.^45,57^ A meta-analysis of these trials demonstrated that aspirin had a statistically significant beneficial effect on this composite outcome (RR, 0.89 [95% CI, 0.84 to 0.94]; I^2^=0%) (Figure 15, Table 4). Sensitivity analyses yielded nearly identical results (Table 4).

Figure 15 Forest Plot of Total MI/Coronary Events (Fatal and Nonfatal) Combined With Total Stroke Events (Fatal and Nonfatal) and CVD Mortality, Sorted by Length of Followup

Figure 15 displays a forest plot of studies reporting the relative risk for the intervention group versus the control group for total MI/coronary events combined with total stroke events and CVD mortality. This figure is described further under KQ1 of the review.

#### Effect on Quality of Life

No included trial reported quality of life outcomes.

## KQ 1a Does the Effect Vary Between a Priori Subgroups: Age, Sex, Smoking Status, Race/Ethnicity, 10-Year Cardiovascular Risk, or Related Risk Conditions?

### Summary of Results

All 10 trials described in KQ 1 addressed issues of effect modification by subgroup.43-45,53-59 In addition to these individual trials, the ATT IPD meta-analysis pooled the results from six of the aforementioned primary prevention trials53,54,56-59 (n=95,000; 660,000 person-years), which provided additional information on subgroup related issues.33 Our analysis defined a priori subpopulations of interest to include age, sex, diabetes status, smoking history, CVD risk status, patients with abnormal ABI, patients with elevated hypertension, and patients with elevated lipids.

Six trials reported age-specific results (Tables 8–10).53,44,45,43,58,60 Three trials showed a consistent pattern of greater RR reduction in total MI/coronary events with older age,53,58,60 with two of these trials showing statistically significant interactions.58,60 Additionally, three trials showed aspirin had no effect on stroke events by age group. Likewise, none of the age strata showed a statistically significant benefit, and the one trial that performed interaction testing showed no interaction between age and stroke events.54,58,60 Six trials showed conflicting results for the interaction between age and various measured composite CVD outcomes, and three trials performing interaction testing found no statistically significant interaction between age and reported CVD composite outcomes.43-45,53,58,60 The ATT IPD meta-analysis did not show any heterogeneity of effect for composite CVD events based on age (<65 vs. ≥65 years).33 Additionally, one trial showed no statistically significant difference in all-cause mortality in either patients age 65 years or younger or those age 65 years or older.60

Table 8 Age Subgroup: Composite CVD Outcomes, All-Cause Mortality, and Major GI Bleeding^*^

Study Reference Quality Rating Mean Followup | Type of Analysis P-Value for Interaction | Age, years | Fatal MI/Coronary Events + Fatal Stroke Events/Participants (%) RR (95% CI) | Fatal MI/Coronary Events + Fatal Stroke + CVD Death (Not Specified) Events/Participants (%) RR (95% CI) | Fatal MI/Coronary Events + Fatal Stroke + CVD Death (Not Specified) + Nonfatal MI/Coronary Events + Nonfatal Stroke Events/Participants (%) RR (95% CI) | Other CVD Composite Reported in the Trial Events/Participants (%) RR (95% CI) | All-Cause Mortality Events/Participants (%) RR (95% CI) | Major GI Bleeding, Events/Participants (%) RR (95% CI)
AAA Fowkes, 2010^45^ Fair 8.2 years | A priori p-value for interaction: NR | <62 | NR | NR | NR | Primary composite outcome: (Initial fatal or nonfatal coronary event or stroke or revascularization) Events/per 1,000 p-y (95% CI): IG: 57/8.6 (6.5 to 11.2) CG: 70/10.2 (8.0 to 12.9) HR: 0.85 (95% CI: 0.60 to 1.20) | NR | NR
AAA Fowkes, 2010^45^ Fair 8.2 years | A priori p-value for interaction: NR | ≥62 | NR | NR | NR | IG: 124/18.8 (15.6 to 22.4) CG: 106/16.6 (13.6 to 20.1) HR: 1.13 (95% CI, 0.87 to 1.47) | NR | NR
HOT Kjeldsen, 2000^60^ Fair 38 years | Specification unclear p-value for interaction: NR | <65 | NR | IG: 2.1/1,000 p-y CG: 2.6/1,000 p-y 0.80 (0.55 to 1.16) | IG: 6.5/1,000 p-y CG: 8.2/1,000 p-y 0.79 (0.64 to 0.98) | NR | IG: 4.9/1,000 p-y CG: 5.5/1,000 p-y 0.90 (0.70 to 1.15) | Fatal bleeding (mainly GI and cerebral): IG: 0.2/1,000 p-y CG: 0.2/1,000 p-y NR Nonfatal major bleeding (requiring hospitalization, including GI, cerebral, and nasal): IG: 3.0/1,000 p-y CG: 1.7/1,000 p-y NR
HOT Kjeldsen, 2000^60^ Fair 38 years | Specification unclear p-value for interaction: NR | ≥65 | NR | IG: 7.4/1,000 p-y CG: 6.8/1,000 p-y 1.08 (0.79 to 1.48) | IG: 14.4/1,000 p-y CG: 15.6/1,000 p-y 0.92 (0.74 to 1.15) | NR | IG: 14.7/1,000 p-y CG: 15.3/1,000 p-y 0.96 (0.77 to 1.19) | Fatal bleeding: IG: 0.3/1,000 p-y CG: 0.4/1,000 p-y NR Nonfatal major bleeding: IG: 4.3/1,000 p-y CG: 2.6/1,000 p-y NR
JPAD Ogawa, 2008^43^ Fair 4.4 years^†^ | A priori p-value for interaction: 0.27 for primary composite outcome | <65 | NR | NR | NR | Primary composite outcome: (sudden death; death from coronary, cerebrovascular, and aortic causes; nonfatal acute MI; unstable angina; newly developed exertional angina; nonfatal ischemic and hemorrhagic stroke; TIA; or nonfatal aortic and peripheral vascular disease) IG: 23/543 (4.2%) CG: 27/633 (4.3%) 0.99 (0.58 to 1.71)║ | NR | NR
JPAD Ogawa, 2008^43^ Fair 4.4 years^†^ | A priori p-value for interaction: 0.27 for primary composite outcome | ≥65 | NR | NR | NR | IG: 45/719 (6.3%) CG: 59/644 (9.2%) 0.68 (0.47 to 0.99)║ | NR | NR
PHS I Physician's Health Study, 1989^53^ Good 5 years | Specification unclear p-value for interaction: NR | 40-84 | NR | Authors state that there was no consistent effect of age on CVD mortality; data not shown | NR | NR | NR | NR
POPADAD Belch, 2008^44^ Fair 6.7 years^†^ | Specification unclear p-value for interaction: 0.44 for primary composite; 0.77 for death from CHD or stroke | <60 | IG: 10/297 (3.4%) CG: 10/315 (3.2%) 1.06 (0.45 to 2.51)║ | NR | NR | Primary composite outcome: (death from CHD or stroke, nonfatal MI or stroke, or above ankle amputation for critical limb ischemia) IG: 38/297 (12.8%) CG: 36/315 (11.4%) 1.12 (0.73 to 1.72)║ | NR | NR
POPADAD Belch, 2008^44^ Fair 6.7 years^†^ | Specification unclear p-value for interaction: 0.44 for primary composite; 0.77 for death from CHD or stroke | ≥60 | IG: 33/341 (9.7%) CG: 25/323 (7.7%) 1.25 (0.76 to 2.06)║ | NR | NR | IG: 78/341 (22.9%) CG: 81/323 (25.1%) 0.91 (0.70 to 1.20)║ | NR | NR
WHS Ridker, 2005^58^ Good 10.1 years | A priori p-value for interaction: 0.05 for total CV events | 45-54 | NR | NR | IG: 163/12,210 (1.3%)^‡^ CG: 161/12,224 (1.3%)^‡^ 1.01 (0.81 to 1.26)^§^ | NR | NR | NR
WHS Ridker, 2005^58^ Good 10.1 years | A priori p-value for interaction: 0.05 for total CV events | 55-64 | NR | NR | IG: 183/5,751 (3.2%)^‡^ CG: 186/5,743 (3.2%)^‡^ 0.98 (0.80 to 1.20)^§^ | NR | NR | NR
WHS Ridker, 2005^58^ Good 10.1 years | A priori p-value for interaction: 0.05 for total CV events | ≥65 | NR | NR | IG: 131/1,983 (6.6%)^‡^ CG: 175/1,984 (8.8%)^‡^ 0.74 (0.59 to 0.92)^§^ | NR | NR | NR

Within study comparisons listed first.

* Nonfatal composite outcome not reported by age for any trial.

† Median.

‡ All denominator Ns (and event %) in each group back-calculated from Table 1 in Rexrode 2000 (Ns for IG and CG by age category not reported). Back-calculation results in a discrepancy of 10 participants in the IG and 9 participants in the CG, likely due to rounding.

§ Adjusted for age and treatment assignment to vitamin E and beta carotene.

║ Calculated.

Abbreviations: CG = control group; CI = confidence interval; CHD = coronary heart disease; CVD = cardiovascular disease; GI = gastrointestinal; HOT = Hypertension Optimal Treatment Study; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes Study; MI = myocardial infarction; NR = not reported; PHS = Physician Health Study; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; p-y= person- years; RR = relative risk; TIA = transient ischemic attack; WHS = Women's Health Study.

Table 9 Age Subgroup: Total, Fatal, and Nonfatal MI/Coronary Events

Study Reference Quality Rating Mean Followup | Type of Analysis P-Value For Interaction | Age, years | All MI Events/Participants (%) RR (95% CI) | Fatal MI Events/Participants (%) RR (95% CI) | Nonfatal MI Events/Participants (%) RR (95% CI)
HOT Kjeldsen, 2000^60^ Fair 3.8 years | Specification unclear p-value for interaction: NR | <65 | IG: 2.2/1,000 p-y CG: 3.4/1,000 p-y 0.66 (0.47 to 0.93) | NR | NR
HOT Kjeldsen, 2000^60^ Fair 3.8 years | Specification unclear p-value for interaction: NR | ≥65 | IG: 2.5/1,000 p-y CG: 4.1/1,000 p-y 0.62 (0.38 to 0.98) | NR | NR
PHS I Physician's Health Study, 1989^53^ Good 5 years | Specification unclear p-value for interaction: reported as p-value for trend in relative risk, 0.02 for total MI | 40-49 | IG: 27/4,527 (0.6%) CG: 24/4,524 (0.5%) 1.12 (0.65 to 1.94)^§^ | NR | NR
PHS I Physician's Health Study, 1989^53^ Good 5 years | Specification unclear p-value for interaction: reported as p-value for trend in relative risk, 0.02 for total MI | 50-59 | IG: 51/3,725 (1.4%) CG: 87/3,725 (2.3%) 0.59 (0.42 to 0.83)^§^ | NR | NR
PHS I Physician's Health Study, 1989^53^ Good 5 years | Specification unclear p-value for interaction: reported as p-value for trend in relative risk, 0.02 for total MI | 60-69 | IG: 39/2,045 (1.9%) CG: 84/2,045 (4.1%) 0.46 (0.32 to 0.68)^*,§^ | NR | NR
PHS I Physician's Health Study, 1989^53^ Good 5 years | Specification unclear p-value for interaction: reported as p-value for trend in relative risk, 0.02 for total MI | 70-84 | IG: 22/740 (3.0%) CG: 44/740 (6.0%) 0.50 (0.30 to 0.83)^*,§^ | NR | NR
WHS Ridker, 2005^58^ Good 10.1 years | A priori p-value for interaction: 0.03 for total MI | 45-54 | IG: 69/12,210 (0.6%)^†^ CG: 56/12,224 (0.5%)^†^ 1.23 (0.87 to 1.75)^‡^ | NR | NR
WHS Ridker, 2005^58^ Good 10.1 years | A priori p-value for interaction: 0.03 for total MI | 55-64 | IG: 88/5,751 (1.5%)^†^ CG: 75/5,743 (1.3%)^†^ 1.17 (0.86 to 1.59)^‡^ | NR | NR
WHS Ridker, 2005^58^ Good 10.1 years | A priori p-value for interaction: 0.03 for total MI | ≥65 | IG: 41/1,983 (2.1)^†^ CG: 62/1,984 (3.1)^†^ 0.66 (0.44 to 0.97)^‡^ | NR | NR

Within study comparisons listed first.

* Adjusted for treatment assignment to beta carotene.

† All denominator Ns (and event %) in each group back-calculated from Table 1 in Rexrode 2000 (Ns for IG and CG by age category not reported). Back-calculation results in a discrepancy of 10 participants in the IG and 9 participants in the CG, likely due to rounding.

‡ Adjusted for age and treatment assignment to vitamin E and beta carotene.

§ Calculated.

Abbreviations: CG = control group; CI = confidence interval; HOT = Hypertension Optimal Treatment Study; IG = intervention group; MI = myocardial infarction; NR = not reported; PHS = Physician Health Study; p-y = person-years; RR = relative risk; TIA = transient ischemic attack; WHS = Women's Health Study.

Table 10 Age Subgroup: Total, Fatal, and Nonfatal Stroke

Study Reference Quality Rating Mean Followup | Type of Analysis P-Value for Interaction | Age, years | All Stroke Events/Participants (%) RR (95% CI) | Fatal Stroke Events/Participants (%) RR (95% CI) | Nonfatal Stroke Events/Participants (%) RR (95% CI)
HOT Kjeldsen, 2000^60^ Fair 3.8 years | Specification unclear p-value for interaction: NR | <65 | IG: 3.0/1,000 p-y CG: 2.7/1,000 p-y 1.14 (0.82 to 1.60) | NR | NR
HOT Kjeldsen, 2000^60^ Fair 3.8 years | Specification unclear p-value for interaction: NR | ≥65 | IG: 6.6/1,000 p-y CG: 7.5/1,000 p-y 0.87 (0.64 to 1.19) | NR | NR
TPT TPT Authors, 1998^54^ Meade, 2000^66^ Fair 6.8 years^*^ | Specification unclear p-value for interaction: 0.85 | 45-49 | IG: 0/1,447 (0.0%)^†^ CG: 1/1,502 (0.7%)^†^ NR | NR | NR
TPT TPT Authors, 1998^54^ Meade, 2000^66^ Fair 6.8 years^*^ | Specification unclear p-value for interaction: 0.85 | 50-54 | IG: 3/1,905 (1.6%)^†^ CG: 0/1,899 (0.0%)^†^ NR | NR | NR
TPT TPT Authors, 1998^54^ Meade, 2000^66^ Fair 6.8 years^*^ | Specification unclear p-value for interaction: 0.85 | 55-59 | IG: 4/1,663 (2.4%) CG: 11/1,812 (6.1%) 0.40 (NR)^‡^ | NR | NR
TPT TPT Authors, 1998^54^ Meade, 2000^66^ Fair 6.8 years^*^ | Specification unclear p-value for interaction: 0.85 | 60-64 | IG: 7/1,811 (3.9%) CG: 9/1,756 (5.1%) 0.99 (NR)^‡^ | NR | NR
TPT TPT Authors, 1998^54^ Meade, 2000^66^ Fair 6.8 years^*^ | Specification unclear p-value for interaction: 0.85 | 65-69 | IG: 4/1,279 (3.1%) CG: 5/1,102 (4.5%) 0.59 (NR)^‡^ | NR | NR
WHS Ridker, 2005^58^ Good 10.1 years | A priori p-value for interaction: NR | 45-54 | IG: 77/12,210 (0.6%)^§^ CG: 90/12,224 (0.7%)^§^ 0.85 (0.63 to 1.16)║ | NR | NR
WHS Ridker, 2005^58^ Good 10.1 years | A priori p-value for interaction: NR | 55-64 | IG: 76/5,751 (1.3%)^§^ CG: 90/5,743 (1.6%)^§^ 0.84 (0.62 to 1.14)║ | NR | NR
WHS Ridker, 2005^58^ Good 10.1 years | A priori p-value for interaction: NR | ≥65 | IG: 68/1,983 (3.4%)^§^ CG: 86/1,984 (4.3%)^§^ 0.78 (0.57 to 1.08)║ | NR | NR

Within study comparisons listed first.

* Median

† Events/p-y at entry (rates per 1,000 p-y).

‡ Adjusted for factors used in risk scoring procedure (history of smoking, family history of premature coronary heart disease, body mass index, total cholesterol, plasma fibrinogen, plasma factor VII coagulant).

§ All denominator Ns (and event %) in each group back-calculated from Table 1 in Rexrode 2000 (Ns for IG and CG by age category not reported). Back-calculation results in a discrepancy of 10 participants in the IG and 9 participants in the CG, likely due to rounding.

║ Adjusted for age and treatment assignment to vitamin E and beta carotene.

Abbreviations: CG = control group; HOT = Hypertension Optimal Treatment Study; IG = intervention group; p-y = person-years; RR = relative risk; TPT = Thrombosis Prevention Trial; WHS = Women's Health Study.

Ten trials reported sex-specific results.43-45,53-55,57,58,60,61 Three of these trials were conducted exclusively among men53,54,57 and one trial was conducted exclusively among women (Tables 11–13).58 In the six trials that included both men and women,43-45,55,56,59 only two trials clearly specified sex as an a priori subgroup.43,45 Three trials adjusted for confounders: ETDRS (adjusted for age, diabetes type, and clinical center), PHS, and WHS (adjusted for age and treatment assignment).53,55,58 The ATT IPD meta-analysis showed that the apparent sex-specific differences in MI/coronary events and ischemic stroke events were no longer statistically significant after controlling for multiple comparisons.33 The four additional trials not included in the ATT IPD meta-analysis43-45,55 showed no difference in composite CVD outcomes between the sexes; the one trial that reported individual event outcomes by sex55 showed no difference in the individual outcomes of total MI/coronary events or total stroke between the sexes.

Table 11 Sex Subgroup: Composite CVD Outcomes, All-Cause Mortality, and Major GI Bleeding

Study Reference Quality Rating Mean Followup | Type of Analysis | Outcome | Men Events/Participants (%) RR (95% CI) | Women Events/Participants (%) RR (95% CI) | P-Value for Interaction
AAA Fowkes, 2010^45^ Fair 8.2 years | A priori | Fatal MI/coronary events + fFatal stroke | NR | NR | NR
AAA Fowkes, 2010^45^ Fair 8.2 years | A priori | Fatal MI/coronary events + fatal stroke + CVD death (not specified) | NR | NR | NR
AAA Fowkes, 2010^45^ Fair 8.2 years | A priori | Nonfatal MI/coronary events + nonfatal stroke | NR | NR | NR
AAA Fowkes, 2010^45^ Fair 8.2 years | A priori | Fatal MI/coronary events + fatal stroke + CVD death (not specified) + nonfatal MI/coronary events + nonfatal stroke | NR | NR | NR
AAA Fowkes, 2010^45^ Fair 8.2 years | A priori | Other CVD composite reported in the trial | Primary composite outcome: initial (earliest) fatal or nonfatal coronary event or stroke or revascularization IG: 96/481 (20.0%) CG: 83/473 (17.5%) 1.14 (0.87 to 1.48)^#^ | Primary composite outcome: initial (earliest) fatal or nonfatal coronary event or stroke or revascularization IG: 85/1,194 (7.1%) CG: 93/1,202 (7.7%) 0.92 (0.69 to 1.22)^#^ | NR
AAA Fowkes, 2010^45^ Fair 8.2 years | A priori | All-cause mortality | NR | NR | NR
AAA Fowkes, 2010^45^ Fair 8.2 years | A priori | Major GI bleeding | NR | NR | NR
ETDRS ETDRS, 1992^55^ Fair 5 years | Specification unclear | Fatal MI/coronary events + fatal stroke | NR | NR | NR
ETDRS ETDRS, 1992^55^ Fair 5 years | Specification unclear | Fatal MI/coronary events + fatal stroke + CVD death (not specified) | IG: 8.6^*^/1,031 CG: 10.2^*^/1,065 0.83 (99% CI, 0.61 to 1.14)^†^ | IG: 10.1^*^/825 CG: 12.5^*^/790 0.92 (99% CI, 0.66 to 1.28)^†^ | NR
ETDRS ETDRS, 1992^55^ Fair 5 years | Specification unclear | Nonfatal MI/coronary events + nonfatal stroke | NR | NR
ETDRS ETDRS, 1992^55^ Fair 5 years | Specification unclear | Fatal MI/coronary events + fatal stroke + CVD death (not specified) + nonfatal MI/coronary events + nonfatal stroke | Primary composite outcome: CV death, nonfatal MI, or stroke IG: 13.5^*^/1,031 CG: 16.5^*^/1,065 0.81 (99% CI, 0.63 to 1.05)^†^ | Primary composite outcome: CV death, nonfatal MI, or stroke IG: 14.6^*^/825 CG: 16.8^*^/790 1.00 (99% CI, 0.75 to 1.34)^†^ | NR
ETDRS ETDRS, 1992^55^ Fair 5 years | Specification unclear | Other CVD composite reported in the trial | Composite outcome: all deaths, nonfatal MI, or stroke IG: 16.8^*^/1,031 CG: 19.8^*^/1,065 0.88 (99% CI, 0.70 to 1.11)^†^ | Composite outcome: all deaths, nonfatal MI, or stroke IG: 16.2^*^/825 CG: 20.2^*^/790 0.97 (99% CI, 0.75 to 1.26)^†^ | NR
ETDRS ETDRS, 1992^55^ Fair 5 years | Specification unclear | All-cause mortality | IG: 12.4^*^/1,031 CG: 13.8^*^/1,065 0.94 (99% CI, 0.73 to 1.22)^†^ | IG: 11.6^*^/825 CG: 16.2^*^/790 0.88 (99% CI, 0.65 to 1.17)^†^ | NR
ETDRS ETDRS, 1992^55^ Fair 5 years | Specification unclear | Major GI bleeding | NR | NR | NR
HOT Kjeldsen, 2000^60^ Fair 3.8 years | Specification unclear | Fatal MI/coronary events + fatal stroke | NR | NR | NR
HOT Kjeldsen, 2000^60^ Fair 3.8 years | Specification unclear | Fatal MI/coronary events + fatal stroke + CVD death (not specified) | IG: 4.4/1,000 p-y CG: 5.0/1,000 p-y 0.89 (0.66 to 1.19) | IG: 3.0/1,000 p-y CG: 2.8/1,000 p-y 1.06 (0.72 to 1.59) | NR
HOT Kjeldsen, 2000^60^ Fair 3.8 years | Specification unclear | Nonfatal MI/coronary events + nonfatal stroke | NR | NR | NR
HOT Kjeldsen, 2000^60^ Fair 3.8 years | Specification unclear | Fatal MI/coronary events + fatal stroke + CVD death (not specified) + nonfatal MI/coronary events + nonfatal stroke | Primary composite outcome: major CV events consisting of MI, stroke, and death due to CVD IG: 11.2/1,000 p-y CG: 12.8/1,000 p-y 0.87 (0.72 to 1.05) | Primary composite outcome: major CV events consisting of MI, stroke, and death due to CVD IG: 6.5/1,000 p-y CG: 8.0/1,000 p-y 0.81 (0.63 to 1.04) | NR
HOT Kjeldsen, 2000^60^ Fair 3.8 years | Specification unclear | Other CVD composite reported in the trial | NR | NR | NR
HOT Kjeldsen, 2000^60^ Fair 3.8 years | Specification unclear | All-cause mortality | IG: 9.2/1,000 p-y CG: 11.1/1,000 p-y 0.83 (0.68 to 1.02) | IG: 6.6/1,000 p-y CG: 5.9/1,000 p-y 1.12 (0.86 to 1.47) | NR
HOT Kjeldsen, 2000^60^ Fair 3.8 years | Specification unclear | Major GI bleeding | Fatal bleeding (mainly GI and cerebral) IG: 0.3/1,000 p-y CG: 0.2/1,000 p-y RR NR; p=NS Nonfatal major bleeding (requiring hospitalization and including GI, cerebral, and nasal) IG: 4.1/1,000 p-y CG: 2.5/1,000 p-y RR NR; p=0.010 | Fatal bleeding (mainly GI and cerebral) IG: 0.1/1,000 p-y CG: 0.2/1,000 p-y RR NR; p=NS Nonfatal major bleeding (requiring hospitalization and including GI, cerebral, and nasal) IG: 2.7/1,000 p-y CG: 1.3/1,000 p-y RR NR; p=0.006 | NR
JPAD Ogawa, 2008^43^ Fair 4.4 years^‡^ | A priori | Fatal MI/coronary events + fatal stroke | NR | NR | NR
JPAD Ogawa, 2008^43^ Fair 4.4 years^‡^ | A priori | Fatal MI/coronary events + fatal stroke + CVD death (not specified) | NR | NR | NR
JPAD Ogawa, 2008^43^ Fair 4.4 years^‡^ | A priori | Nonfatal MI/coronary events + nonfatal stroke | NR | NR | NR
JPAD Ogawa, 2008^43^ Fair 4.4 years^‡^ | A priori | Fatal MI/coronary events + fatal stroke + CVD death (not specified) + nonfatal MI/coronary events + nonfatal stroke | NR | NR | NR
JPAD Ogawa, 2008^43^ Fair 4.4 years^‡^ | A priori | Other CVD composite reported in the trial | Primary composite outcome: sudden death; death from coronary, cerebrovascular, and aortic causes; nonfatal acute MI; unstable angina; newly developed exertional angina; nonfatal ischemic and hemorrhagic stroke; TIA; or nonfatal aortic and peripheral vascular disease IG: 40/706 (5.7%) CG: 51/681 (7.5%) 0.76 (0.51 to 1.13)^#^ | Primary composite outcome: sudden death; death from coronary, cerebrovascular, and aortic causes; nonfatal acute MI; unstable angina; newly developed exertional angina; nonfatal ischemic and hemorrhagic stroke; TIA; or nonfatal aortic and peripheral vascular disease IG: 28/556 (5.0%) CG: 35/596 (5.9%) 0.86 (0.53 to 1.39)^#^ | NR
JPAD Ogawa, 2008^43^ Fair 4.4 years^‡^ | A priori | All-cause mortality | NR | NR | NR
JPAD Ogawa, 2008^43^ Fair 4.4 years^‡^ | A priori | Major GI bleeding | NR | NR | NR
POPADAD Belch, 2008^44^ Fair 6.7 years^‡^ | Specification unclear | Fatal MI/coronary events + fatal stroke | NR | NR | NR
POPADAD Belch, 2008^44^ Fair 6.7 years^‡^ | Specification unclear | Fatal MI/coronary events + fatal stroke + CVD death (not specified) | IG: 26/286 (9.1%) CG: 19/277 (6.9%) 1.32 (0.75 to 2.34)^#^ | IG: 17/352 (4.8%) CG: 16/361 (4.4%) 1.09 (0.56 to 2.12)^#^ | 0.68
POPADAD Belch, 2008^44^ Fair 6.7 years^‡^ | Specification unclear | Nonfatal MI/coronary events + nonfatal stroke | NR | NR | NR
POPADAD Belch, 2008^44^ Fair 6.7 years^‡^ | Specification unclear | Fatal MI/coronary events + fatal stroke + CVD death (not specified) + nonfatal MI/coronary events + nonfatal stroke | NR | NR | NR
POPADAD Belch, 2008^44^ Fair 6.7 years^‡^ | Specification unclear | Other CVD composite reported in the trial | Primary composite outcome: death from CHD or stroke, nonfatal MI or stroke, or above ankle amputation for critical limb ischemia IG: 68/286 (23.8%) CG: 62/277 (22.4%) 1.06 (0.78 to 1.44)^#^ | Primary composite outcome: death from CHD or stroke, nonfatal MI or stroke, or above ankle amputation for critical limb ischemia IG: 48/352 (13.6%) CG: 55/361 (15.2%) 0.90 (0.63 to 1.28)^#^ | 0.54
POPADAD Belch, 2008^44^ Fair 6.7 years^‡^ | Specification unclear | All-cause mortality | NR | NR | NR
POPADAD Belch, 2008^44^ Fair 6.7 years^‡^ | Specification unclear | Major GI bleeding | NR | NR | NR
PPP Berger, 2006^61^ Fair 3.6 years | Specification unclear | Fatal MI/coronary events + fatal stroke | NR | NR | NR
PPP Berger, 2006^61^ Fair 3.6 years | Specification unclear | Fatal MI/coronary events + fatal stroke + CVD death (not specified) | IG: 11/949 (1.2%) CG: 16/963 (1.7%) 0.70 (0.32 to 1.50)^#^ | IG: 6/1,277 (0.5%) CG: 15/1,306 (1.1%) 0.41 (0.16 to 1.05)^#^ | NR
PPP Berger, 2006^61^ Fair 3.6 years | Specification unclear | Nonfatal MI/coronary events + nonfatal stroke | NR | NR | NR
PPP Berger, 2006^61^ Fair 3.6 years | Specification unclear | Fatal MI/coronary events + fatal stroke + CVD death (not specified) + nonfatal MI/coronary events + nonfatal stroke | Primary composite outcome: major CV events (CV mortality, nonfatal MI, nonfatal stroke) IG: 28/949 (3.0%) CG: 38/963 (3.9%) 0.75 (0.46 to 1.21)^#^ | Primary composite outcome: major CV events (CV mortality, nonfatal MI, nonfatal stroke) IG: 17/1,277 (1.3%) CG: 26/1,306 (2.0%) 0.67 (0.36 to 1.23)^#^ | NR
PPP Berger, 2006^61^ Fair 3.6 years | Specification unclear | Other CVD composite reported in the trial | Same as total CVD event composite | Same as total CVD event composite | NR
PPP Berger, 2006^61^ Fair 3.6 years | Specification unclear | All-cause mortality | IG: 42/949 (4.4%) CG: 44/963 (4.6%) 0.97 (0.64 to 1.46)^#^ | IG: 20/1,277 (1.6%) CG: 34/1,306 (2.6%) 0.60 (0.35 to 1.04)^#^ | NR
PPP Berger, 2006^61^ Fair 3.6 years | Specification unclear | Major GI bleeding | Major bleeding (not defined): IG: 15/949 (1.6%) CG: 4/963 (0.4%) 3.80 (1.27 to 11.42)^#^ | Major bleeding (not defined): IG: 9/1,277 (0.7%) CG: 2/1,306 (0.2%) 4.60 (1.00 to 21.26)^#^ | NR
BMD Peto, 1988^57^ Fair 6 years | N/A; trial in males only | Fatal MI/coronary events + fatal stroke | IG: 119/3,429 (3.5%)^#^ CG: 59/1,710 (3.5%)^#^ 1.01 (0.74 to 1.37)^#^ | NA | NA
BMD Peto, 1988^57^ Fair 6 years | N/A; trial in males only | Fatal MI/coronary events + fatal stroke + CVD death (not specified) | Same as clean fatal composite | NA | NA
BMD Peto, 1988^57^ Fair 6 years | N/A; trial in males only | Nonfatal MI/coronary events + nonfatal stroke | IG: 141/3,429 (4.1%)^#^ CG: 68/1,710 (4.0%)^#^ 1.03 (0.78 to 1.37)^#^ | NA | NA
BMD Peto, 1988^57^ Fair 6 years | N/A; trial in males only | Fatal MI/coronary events + fatal stroke + CVD death (not specified) + nonfatal MI/coronary events + nonfatal stroke | IG: 260/3,429 (7.6%)^#^ CG: 127/1,710 (7.4%)^#^ 1.02 (0.83 to 1.25)^#^ | NA | NA
BMD Peto, 1988^57^ Fair 6 years | N/A; trial in males only | Other CVD composite reported in the trial | NR | NA | NA
BMD Peto, 1988^57^ Fair 6 years | N/A; trial in males only | All-cause mortality | IG: 270/3,429 (7.9%)^#^ CG: 151/1,710 (8.8%)^#^ 0.89 (0.74 to 1.08)^#^ | NA | NA
BMD Peto, 1988^57^ Fair 6 years | N/A; trial in males only | Major GI bleeding | Fatal gastric hemorrhage, fatal hemorrhagic peptic ulcer, fatal perforated peptic ulcer IG: 3/3,429 (0.1%)^#^ CG: 3/1,710 (0.2%)^#^ 0.50 (0.10 to 2.47)^#^ | NA | NA
PHS I Physician's Health Study, 1989^53^ Good 5 years | N/A; trial in males only | Fatal MI/coronary events + fatal stroke | IG: 66/11,037 (0.6%)^#^ CG: 72/11,034 (0.7%)^#^ 0.92 (0.66 to 1.28)^#^ | NA | NA
PHS I Physician's Health Study, 1989^53^ Good 5 years | N/A; trial in males only | Fatal MI/coronary events + fatal stroke + CVD death (not specified) | Same as clean fatal composite | NA | NA
PHS I Physician's Health Study, 1989^53^ Good 5 years | N/A; trial in males only | Nonfatal MI/coronary events + nonfatal stroke | IG: 239/11,037 (2.2%)^#^ CG: 305/11,034 (2.8%)^#^ 0.78 (0.66 to 0.93)^#^ | NA | NA
PHS I Physician's Health Study, 1989^53^ Good 5 years | N/A; trial in males only | Fatal MI/coronary events + fatal stroke + CVD death (not specified) + nonfatal MI/coronary events + nonfatal stroke | Primary composite outcome (nonfatal MI, nonfatal stroke, death from CV cause) IG: 307/11,037 (2.8%) CG: 370/11,034 (3.4%) 0.82 (0.70 to 0.96)^§^ | NA | NA
PHS I Physician's Health Study, 1989^53^ Good 5 years | N/A; trial in males only | Other CVD composite reported in the trial | Same as total CVD event composite | NA | NA
PHS I Physician's Health Study, 1989^53^ Good 5 years | N/A; trial in males only | All-cause mortality | IG: 217/11,037 (2.0%) CG: 227/11,034 (2.1%) 0.96 (0.80 to 1.14)^§^ | NA | NA
PHS I Physician's Health Study, 1989^53^ Good 5 years | N/A; trial in males only | Major GI bleeding | IG: 49/11,037 (0.4%)^#^║ CG: 28/11,034 (0.3%)^#^║ 1.75 (1.10 to 2.78)^#^ | NA | NA
TPT TPT Authors, 1998^54^ Fair 6.8 years^‡^ | N/A; trial in males only | Fatal MI/coronary events + fatal stroke | IG: 38/1,268 (3.0%) CG: 35/1,272 (2.8%) 1.09 (0.69 to 1.71)^#^ | NA | NA
TPT TPT Authors, 1998^54^ Fair 6.8 years^‡^ | N/A; trial in males only | Fatal MI/coronary events + fatal stroke + CVD death (not specified) | IG: 42/1,268 (3.3%)^#^ CG: 40/1,272 (3.1%)^#^ 1.05 (0.69 to 1.61)^#^ | NA | NA
TPT TPT Authors, 1998^54^ Fair 6.8 years^‡^ | N/A; trial in males only | Nonfatal MI/coronary events + nonfatal stroke | IG: 63/1,268 (5.0%)^#^ CG: 98/1,272 (7.7%)^#^ 0.64 (0.47 to 0.88)^#^ | NA | NA
TPT TPT Authors, 1998^54^ Fair 6.8 years^‡^ | N/A; trial in males only | Fatal MI/coronary events + fatal stroke + CVD death (not specified) + nonfatal MI/coronary events + nonfatal stroke | IG: 105/1,268 (8.3%)^#^ CG: 138/1,272 (10.8%)^#^ 0.76 (0.60 to 0.97)^#^ | NA | NA
TPT TPT Authors, 1998^54^ Fair 6.8 years^‡^ | N/A; trial in males only | Other CVD composite reported in the trial | Primary composite outcome: sum of fatal and nonfatal IHD events (coronary death and fatal and nonfatal MI) IG: 83/1,268 (6.5%) CG: 107/1,272 (8.4%) 0.78 (0.59 to 1.03)^#^ | NA | NA
TPT TPT Authors, 1998^54^ Fair 6.8 years^‡^ | N/A; trial in males only | All-cause mortality | IG: 113/1,268 (8.9%) CG: 110/1,272 (8.6%) 1.03 (0.80 to 1.32)^#^ | NA | NA
TPT TPT Authors, 1998^54^ Fair 6.8 years^‡^ | N/A; trial in males only | Major GI bleeding | IG: 6/1,268 (0.5%)^#^ CG: 2/1,272 (0.2%)^#^ 3.01 (0.61 to 14.88)^#^ | NA
WHS Ridker, 2005^58^ Rexrode, 2000^69^ Good 10.1 years | N/A; trial in females only | Fatal MI/coronary events + fatal stroke | NA | IG: 37/19,934 (0.2%)^#^ CG: 34/19,942 (0.2%)^#^ 1.09 (0.68 to 1.73)^#^ | NA
WHS Ridker, 2005^58^ Rexrode, 2000^69^ Good 10.1 years | N/A; trial in females only | Fatal MI/coronary events + fatal stroke + CVD death (not specified) | NA | IG: 120/19,934 (0.6%) CG: 126/19,942 (0.6%) 0.95 (0.74 to 1.22)^¶^ | NA
WHS Ridker, 2005^58^ Rexrode, 2000^69^ Good 10.1 years | N/A; trial in females only | Nonfatal MI/coronary events + nonfatal stroke | NA | IG: 382/19,934 (1.9%)^#^ CG: 425/19,942 (2.1%)^#^ 0.90 (0.78 to 1.03)^#^ | NA
WHS Ridker, 2005^58^ Rexrode, 2000^69^ Good 10.1 years | N/A; trial in females only | Fatal MI/coronary events + fatal stroke + CVD death (not specified) + nonfatal MI/coronary events + nonfatal stroke | NA | Primary composite outcome: nonfatal MI, nonfatal stroke, or CVD death IG: 477/19,934 (2.4%) CG: 522/19,942 (2.6%) 0.91 (0.80 to 1.03)^¶^ | NA
WHS Ridker, 2005^58^ Rexrode, 2000^69^ Good 10.1 years | N/A; trial in females only | Other CVD composite reported in the trial | NA | Same as total CVD event composite | NA
WHS Ridker, 2005^58^ Rexrode, 2000^69^ Good 10.1 years | N/A; trial in females only | All-cause mortality | NA | IG: 609/19,934 (3.1%) CG: 642/19,942 (3.2%) 0.95 (0.85 to 1.06)^¶^ | NA
WHS Ridker, 2005^58^ Rexrode, 2000^69^ Good 10.1 years | N/A; trial in females only | Major GI bleeding | NA | IG: 129/19,934 (0.6%)^#^║ CG: 94/19,942 (0.5%)^#^║ 1.37 (1.05 to 1.79)^#^ | NA

Within study comparisons listed first.

* 5-year life table rates.

† Adjusted for age, nonwhite race, diabetes type, and clinical center.

‡ Median.

§ Adjusted for age and assignment to beta carotene.

║ Death from GI hemorrhage plus bleeding requiring transfusion.

¶ Adjusted for age and treatment assignment to vitamin E and beta carotene.

# Calculated.

Abbreviations: AAA = Aspiring for Asymptomatic Atherosclerosis Trial; BMD = British Medical Doctor's Study; CG = control group; CHD = coronary heart disease; CI = confidence interval; CV = cardiovascular; CVD = cardiovascular disease; ETDRS = Early Treatment Diabetic Retinopathy Study; GI = gastrointestinal; HOT = Hypertension Optimal Treatment Study; IG = intervention group; IHD = ischemic heart disease; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes Study; MI = myocardial infarction; N/A = not applicable; NR = not reported; PHS = Physician Health Study; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; PPP = Primary Prevention Project; p-y= person-years; RR = relative risk; TIA = transient ischemic attack; TPT = Thrombosis Prevention Trial; WHS = Women's Health Study.

Table 12 Sex Subgroup: Total, Fatal, and Nonfatal MI/Coronary Events

Study Reference Quality Rating Mean Followup | Type of Analysis | Outcome | Men Events/Participants (%) RR (95% CI) | Women Events/Participants (%) RR (95% CI) | P-Value for Interaction
ETDRS ETDRS, 1992^55^ Fair 5 years | Specification unclear | Total MI/Coronary Events | IG: 8.6^*^/1,031 CG: 12.0^*^/1,065 (99% CI): 0.74 (0.54 to 1.00)^†^ | IG: 9.8^*^/825 CG: 12.6^*^/790 (99% CI): 0.91 (0.65 to 1.28)^†^ | NR
ETDRS ETDRS, 1992^55^ Fair 5 years | Specification unclear | Fatal MI/Coronary Events | NR | NR | NR
ETDRS ETDRS, 1992^55^ Fair 5 years | Specification unclear | Nonfatal MI/Coronary Events | NR | NR | NR
HOT Kjeldsen, 2000^60^ Fair 3.8 years | Specification unclear | Total MI/Coronary Events | IG: 2.9/1,000 p-y CG: 5.0/1,000 p-y 0.58 (0.41 to 0.81) | IG: 1.7/1,000 p-y CG: 2.1/1,000 p-y 0.81 (0.49 to 1.31) | NR
HOT Kjeldsen, 2000^60^ Fair 3.8 years | Specification unclear | Fatal MI/Coronary Events | NR | NR | NR
HOT Kjeldsen, 2000^60^ Fair 3.8 years | Specification unclear | Nonfatal MI/Coronary Events | NR | NR | NR
PPP Berger, 2006^61^ Fair 3.6 years | Specification unclear | Total MI/Coronary Events | IG: 11/949 (1.2%) CG: 22/963 (2.3%) 0.51 (0.25 to 1.04)^**^ | IG: 8/1,277 (0.6%) CG: 6/1,306 (0.4%) 1.36 (0.47 to 3.92)^**^ | NR
PPP Berger, 2006^61^ Fair 3.6 years | Specification unclear | Fatal MI/Coronary Events | NR | NR | NR
PPP Berger, 2006^61^ Fair 3.6 years | Specification unclear | Nonfatal MI/Coronary Events | NR | NR | NR
BMD Peto, 1988^57^ Fair 6 years | N/A; trial in males only | Total MI/Coronary Events | IG: 169/3,429^‡^ (4.9%)^**^ CG: 88/1,710^‡^ (5.1%)^**^ 0.96 (0.75 to 1.23)^**^ | NA | NA
BMD Peto, 1988^57^ Fair 6 years | N/A; trial in males only | Fatal MI/Coronary Events | IG: 89/3,429 (2.6%) CG: 47/1,710 (2.7%) 0.94 (0.67 to 1.34)^**^ | NA | NA
BMD Peto, 1988^57^ Fair 6 years | N/A; trial in males only | Nonfatal MI/Coronary Events | IG: 80/3,429^§^ (2.3%) CG: 41/1,710^§^ (2.4%) 0.97 (0.67 to 1.41)^**^ | NA | NA
PHS I Physician's Health Study, 1989^53^ Good 5 years | N/A; trial in males only | Total MI/Coronary Events | IG: 185/11,037 (1.7%)^**^ CG: 278/11,034 (2.5%)^**^ 0.67 (0.55 to 0.80)^**^ | NA | NA
PHS I Physician's Health Study, 1989^53^ Good 5 years | N/A; trial in males only | Fatal MI/Coronary Events | IG: 56/11,037 (0.5%)^**^ CG: 65/11,034 (0.6%)^**^ 0.86 (0.60 to 1.23)^**^ | NA | NA
PHS I Physician's Health Study, 1989^53^ Good 5 years | N/A; trial in males only | Nonfatal MI/Coronary Events | IG: 129/11,037 (1.2%) CG: 213/11,034 (1.9%) 0.59 (0.47 to 0.74)║ | NA | NA
TPT TPT Authors, 1998^54^ Fair 6.8 years^¶^ | N/A; trial in males only | Total MI/Coronary Events | IG: 83/1,268 (6.5%) CG: 107/1,272 (8.4%) 0.78 (0.59 to 1.03)^**^ | NA | NA
TPT TPT Authors, 1998^54^ Fair 6.8 years^¶^ | N/A; trial in males only | Fatal MI/Coronary Events | IG: 36/1,268 (2.8%) CG: 34/1,272 (2.7%) 1.06 (0.67 to 1.69)^**^ | NA | NA
TPT TPT Authors, 1998^54^ Fair 6.8 years^¶^ | N/A; trial in males only | Nonfatal MI/Coronary Events | IG: 47/1,268 (3.7%) CG: 73/1,272 (5.7%) 0.65 (0.45 to 0.92)^**^ | NA | NA
WHS Ridker, 2005^58^ Good 10.1 years | N/A; trial in females only | Total MI/Coronary Events | NA | IG: 198/19,934 (1.0%) CG: 193/19,942 (1.0%) 1.02 (0.84 to 1.25)^#^ | NA
WHS Ridker, 2005^58^ Good 10.1 years | N/A; trial in females only | Fatal MI/Coronary Events | NA | IG: 14/19,934 (0.07%) CG: 12/19,942 (0.06%) 1.16 (0.54 to 2.51)^#^ | NA
WHS Ridker, 2005^58^ Good 10.1 years | N/A; trial in females only | Nonfatal MI/Coronary Events | NA | IG: 184/19,934 (0.9%) CG: 181/19,942 (0.9%) 1.01 (0.83 to 1.24)^#^ | NA

Within study comparisons listed first.

* 5-year life table rates.

† Adjusted for age, sex, race/ethnicity, diabetes type, and clinical center.

‡ Fatal MI plus confirmed nonfatal MI.

§ Confirmed nonfatal MI; possible MI also reported.

║ Adjusted for age and assignment to beta carotene.

¶ Median.

# Adjusted for age and treatment assignment to vitamin E and beta carotene.

** Calculated.

Abbreviations: BMD = British Medical Doctor's Study; CG = control group; CI = confidence interval; ETDRS = Early Treatment Diabetic Retinopathy Study; HOT = Hypertension Optimal Treatment Study; IG = intervention group; MI = myocardial infarction; N/A = not applicable; NR = not reported; PHS = Physician Health Study; PPP = Primary Prevention Project; RR = relative risk; TPT = Thrombosis Prevention Trial; WHS = Women's Healthy Study.

Table 13 Sex Subgroup: Total, Fatal, and Nonfatal Stroke

Study Reference Quality Rating Mean Followup | Type of Analysis | Outcome | Men Events/Participants (%) RR (95% CI) | Women Events/Participants (%) RR (95% CI) | P-Value for Interaction
ETDRS ETDRS, 1992^55^ Fair 5 years | Specification unclear | All Stroke | IG: 4.4/1,031^*^ CG: 3.9/1,065^*^ (99% CI): 1.07 (0.63 to 1.83) | IG: 4.6/825^*^ CG: 3.8/790^*^ (99% CI): 1.31 (0.71 to 2.39) | NR
ETDRS ETDRS, 1992^55^ Fair 5 years | Specification unclear | Fatal Stroke | NR | NR | NR
ETDRS ETDRS, 1992^55^ Fair 5 years | Specification unclear | Nonfatal Stroke | NR | NR | NR
HOT Kjeldsen, 2000^60^ Fair 3.8 years | Specification unclear | All Stroke | IG: 5.0/1,000 p-y CG: 4.3/1,000 p-y 1.16 (0.86 to 1.56) | IG: 3.2/1,000 p-y CG: 4.0/1,000 p-y 0.78 (0.54 to 1.12) | NR
HOT Kjeldsen, 2000^60^ Fair 3.8 years | Specification unclear | Fatal Stroke | NR | NR | NR
HOT Kjeldsen, 2000^60^ Fair 3.8 years | Specification unclear | Nonfatal Stroke | NR | NR | NR
PPP Berger, 2006^61^ Fair 3.6 years | Specification unclear | All Stroke | IG: 10/949 (1.0%) CG: 13/963 (1.3%) 0.78 (0.34 to 1.77)^††^ | IG: 6/1,277 (0.5%) CG: 11/1,306 (0.8%) 0.56 (0.21 to 1.50)^††^ | NR
PPP Berger, 2006^61^ Fair 3.6 years | Specification unclear | Fatal Stroke | NR | NR | NR
PPP Berger, 2006^61^ Fair 3.6 years | Specification unclear | Nonfatal Stroke | NR | NR | NR
BMD Peto, 1988^57^ Fair 6 years | N/A; trial in males only | All Stroke | IG: 91/3,429 (2.7%)^‡,††^ CG: 39/1,710 (2.3%)^‡,††^ 1.16 (0.80 to 1.69)^††^ | NA | NA
BMD Peto, 1988^57^ Fair 6 years | N/A; trial in males only | Fatal Stroke | IG: 30/3,429 (0.9%)^††^ CG: 12/1,710 (0.7%)^††^ 1.25 (0.64 to 2.43)^††^ | NA | NA
BMD Peto, 1988^57^ Fair 6 years | N/A; trial in males only | Nonfatal Stroke | IG: 61/3,429 (1.8%)^§^ CG: 27/1,710 (1.6%)^§^ 1.13 (0.72 to 1.77)^††^ | NA | NA
PHS I Physician's Health Study, 1989^53^ Good 5 years | N/A; trial in males only | All Stroke | IG: 119/11,037 (1.1%)^††^║ CG: 98/11,034 (0.9%)^††^║ 1.22 (0.93 to 1.60)^¶^ | NA | NA
PHS I Physician's Health Study, 1989^53^ Good 5 years | N/A; trial in males only | Fatal Stroke | IG: 10/11,037 (0.09%) CG: 7/11,034 (0.06%) 1.44 (0.54 to 3.88)^¶^ | NA | NA
PHS I Physician's Health Study, 1989^53^ Good 5 years | N/A; trial in males only | Nonfatal Stroke | IG: 110/11,037 (1.0%) CG: 92/11,034 (0.8%) 1.20 (0.91 to 1.59)^¶^ | NA | NA
TPT TPT Authors, 1998^54^ Fair 6.8 years^#^ | N/A; trial in males only | All Stroke | IG: 18/1,268 (1.4%) CG: 26/1,272 (2.0%) 0.69 (0.38 to 1.26)^††^ | NA | NA
TPT TPT Authors, 1998^54^ Fair 6.8 years^#^ | N/A; trial in males only | Fatal Stroke | IG: 2/1,268 (0.2%) CG: 1/1,272 (0.1%) 2.01 (0.18 to 22.10)^††^ | NA | NA
TPT TPT Authors, 1998^54^ Fair 6.8 years^#^ | N/A; trial in males only | Nonfatal Stroke | IG: 16/1,268 (1.3%) CG: 25/1,272 (2.0%) 0.64 (0.34 to 1.20)^††^ | NA | NA
WHS Ridker, 2005^58^ Good 10.1 years | N/A; trial in females only | All Stroke | NA | IG: 221/19,934 (1.1%) CG: 266/19,942 (1.3%) 0.83 (0.69 to 0.99)^**^ | NA
WHS Ridker, 2005^58^ Good 10.1 years | N/A; trial in females only | Fatal Stroke | NA | IG: 23/19,934 (0.1%) CG: 22/19,942 (0.1%) 1.04 (0.58 to 1.86)^**^ | NA
WHS Ridker, 2005^58^ Good 10.1 years | N/A; trial in females only | Nonfatal Stroke | NA | IG: 198/19,934 (1.0%) CG: 244/19,942 (1.2%) 0.81 (0.67 to 0.97)^**^ | NA

Within study comparisons listed first.

* 5-year life table rates.

† Adjusted for age, sex, race/ethnicity, diabetes type, and clinical center.

‡ Fatal stroke plus confirmed nonfatal stroke.

§ Confirmed nonfatal stroke; possible stroke also reported.

║ First stroke event.

¶ Adjusted for age and assignment to beta carotene.

# Median.

** Adjusted for age and treatment assignment to vitamin E and beta carotene.

†† Calculated.

Abbreviations: BMD = British Medical Doctor's Study; CG = control group; CI = confidence interval; ETDRS = Early Treatment Diabetic Retinopathy Study; HOT = Hypertension Optimal Treatment Study; IG = intervention group; NR = not reported; PHS = Physician's Health Study; PPP = Primary Prevention Project; RR = relative risk; TPT = Thrombosis Prevention Trial; WHS = Women's Health Study.

Three trials specifically recruited patients with diabetes.43,44,55 An additional five trials performed subgroup analyses on patients with diabetes,45,53,58,62,63 although only one trial clearly designated the analysis a priori (Tables 14–16).58 Three of these additional trials performed interaction testing53,62,63 and two trials adjusted for confounders.53,58 These trials reported no statistically significant benefit for aspirin in diabetes patients for all-cause mortality, MI/coronary events, or stroke. Likewise, the results for composite CVD outcomes were nonsignificant and conflicting. The ATT IPD meta-analysis analyzed a composite outcome of serious vascular events and showed no statistically significant effect of aspirin in patients with diabetes and no heterogeneity of effect by diabetes status.33

Table 14 Diabetes Subgroup: Composite CVD Outcomes, All-Cause Mortality, and Major GI Bleeding

Study Reference Quality Rating Mean Followup | Type of Analysis Diabetes Diagnostic Criteria | Outcome | Diabetes Events/Participants (%) RR (95% CI) | No Diabetes Events/Participants (%) RR (95% CI) | P-Value for Interaction
AAA Fowkes, 2010^45^ Fair 8.2 years | Post hoc Diagnostic criteria: self-reported DM | Fatal MI/coronary events + Fatal stroke | NR | NR | NR
AAA Fowkes, 2010^45^ Fair 8.2 years | Post hoc Diagnostic criteria: self-reported DM | Fatal MI/coronary events + Fatal stroke + CVD death (not specified) | NR | NR | NR
AAA Fowkes, 2010^45^ Fair 8.2 years | Post hoc Diagnostic criteria: self-reported DM | Nonfatal MI/coronary events + nonfatal stroke | NR | NR | NR
AAA Fowkes, 2010^45^ Fair 8.2 years | Post hoc Diagnostic criteria: self-reported DM | Fatal MI/coronary events + Fatal stroke + CVD death (not specified) + nonfatal MI/coronary events + nonfatal stroke | NR | NR | NR
AAA Fowkes, 2010^45^ Fair 8.2 years | Post hoc Diagnostic criteria: self-reported DM | Other CVD composite reported in the trial | NR | Primary composite outcome: (initial fatal or nonfatal coronary event or stroke or revascularization) per 1,000 p-y (95% CI) IG: 13.7 (11.7 to 15.9) CG: 12.8 (10.9 to 14.9) HR: 1.07 (0.87 to 1.33) | NR
AAA Fowkes, 2010^45^ Fair 8.2 years | Post hoc Diagnostic criteria: self-reported DM | All-cause mortality | NR | NR | NR
AAA Fowkes, 2010^45^ Fair 8.2 years | Post hoc Diagnostic criteria: self-reported DM | Major GI bleeding | NR | NR | NR
HOT Zanchetti, 2007^62^ Fair 3.8 years | Specification unclear Diagnostic criteria: NR | Fatal MI/coronary events + Fatal stroke | NR | NR | NR
HOT Zanchetti, 2007^62^ Fair 3.8 years | Specification unclear Diagnostic criteria: NR | Fatal MI/coronary events + Fatal stroke + CVD death (not specified) | IG: 23/752 (3.0%) CG: 26/749 (3.5%) 0.89 (0.51 to 1.57) | IG: 110/8,647 (1.3%) CG: 114/8,642 (1.3%) 0.96 (0.74 to 1.25) | NS (value NR)
HOT Zanchetti, 2007^62^ Fair 3.8 years | Specification unclear Diagnostic criteria: NR | Nonfatal MI/coronary events + nonfatal stroke | NR | NR | NR
HOT Zanchetti, 2007^62^ Fair 3.8 years | Specification unclear Diagnostic criteria: NR | Fatal MI/coronary events + Fatal stroke + CVD death (not specified) + nonfatal MI/coronary events + nonfatal stroke | IG: 47/752 (6.2%) CG: 54/749 (7.2%) 0.87 (0.59 to 1.28) | IG: 268/8,647 (3.1%) CG: 314/8,642 (3.6%) 0.85 (0.72 to 1.00) | NS (value NR)
HOT Zanchetti, 2007^62^ Fair 3.8 years | Specification unclear Diagnostic criteria: NR | Other CVD composite reported in the trial | Same as total CVD event composite | Same as total CVD event composite | NR
HOT Zanchetti, 2007^62^ Fair 3.8 years | Specification unclear Diagnostic criteria: NR | All-cause mortality | IG: 40/752 (5.3%) CG: 36/749 (4.8%) 1.12 (0.72 to 1.76) | IG: 244/8,647 (2.8%) CG: 269/8,642 (3.1%) 0.90 (0.76 to 1.07) | NS (value NR)
HOT Zanchetti, 2007^62^ Fair 3.8 years | Specification unclear Diagnostic criteria: NR | Major GI bleeding | NR | NR | NR
PPP^*^ Sacco, 2003^63^ Fair 3.7 years | Post hoc Diagnostic criteria: fasting venous plasma glucose ≥7.8 mmol/L on at least 2 separate occasions or treatment with antidiabetes drugs | Fatal MI/coronary events + Fatal stroke | NR | NR | NR
PPP^*^ Sacco, 2003^63^ Fair 3.7 years | Post hoc Diagnostic criteria: fasting venous plasma glucose ≥7.8 mmol/L on at least 2 separate occasions or treatment with antidiabetes drugs | Fatal MI/coronary events + Fatal stroke + CVD death (not specified) | IG: 10/519 (1.9%) CG: 8/512 (1.6%) 1.23 (0.49 to 3.10) | IG: 8/1,875^†^ (0.4%) CG: 25/1,889^†^ (1.3%) 0.32 (0.14 to 0.72) | 0.3
PPP^*^ Sacco, 2003^63^ Fair 3.7 years | Post hoc Diagnostic criteria: fasting venous plasma glucose ≥7.8 mmol/L on at least 2 separate occasions or treatment with antidiabetes drugs | Nonfatal MI/coronary events + nonfatal stroke | NR | NR | NR
PPP^*^ Sacco, 2003^63^ Fair 3.7 years | Post hoc Diagnostic criteria: fasting venous plasma glucose ≥7.8 mmol/L on at least 2 separate occasions or treatment with antidiabetes drugs | Fatal MI/coronary events + Fatal stroke + CVD death (not specified) + nonfatal MI/coronary events + nonfatal stroke | Primary composite outcome (CV death, nonfatal MI, and nonfatal stroke) IG: 20/519 (3.9%) CG: 22/512 (4.3%) 0.90 (0.50 to 1.62) | Primary composite outcome (CV death, nonfatal MI, and nonfatal stroke) IG: 30/1,875^†^ (1.6%) CG: 51/1,889^†^ (2.7%) 0.59 (0.37 to 0.94) | NR
PPP^*^ Sacco, 2003^63^ Fair 3.7 years | Post hoc Diagnostic criteria: fasting venous plasma glucose ≥7.8 mmol/L on at least 2 separate occasions or treatment with antidiabetes drugs | Other CVD composite reported in the trial | All CV events or diseases (CV death, nonfatal MI, nonfatal stroke, angina, TIA, PAD, and revascularization) IG: 53/519 (10.2%) CG: 59/512 (11.5%) 0.89 (0.62 to 1.26) | All CV events or diseases (CV death, nonfatal MI, nonfatal stroke, angina, TIA, PAD, and revascularization) IG: 98/1,875^†^ (5.3%) CG: 142/1,889^†^ (7.5%) 0.69 (0.53 to 0.90) | NR
PPP^*^ Sacco, 2003^63^ Fair 3.7 years | Post hoc Diagnostic criteria: fasting venous plasma glucose ≥7.8 mmol/L on at least 2 separate occasions or treatment with antidiabetes drugs | All-cause mortality | IG: 25/519 (4.8%) CG: 20/512 (3.9%) 1.23 (0.69 to 2.19) | IG: 42/1,875^†^ (2.3%) CG: 61/1,889^†^ (3.2%) 0.70 (0.47 to 1.04) | NR
PPP^*^ Sacco, 2003^63^ Fair 3.7 years | Post hoc Diagnostic criteria: fasting venous plasma glucose ≥7.8 mmol/L on at least 2 separate occasions or treatment with antidiabetes drugs | Major GI bleeding | NR | NR | NR
WHS Ridker, 2005^58^ Rexrode, 2000^69^ Good 10.1 years | A priori Diagnostic criteria: assumption is self-reported history of diabetes from the enrollment questionnaire | Fatal MI/coronary events + Fatal stroke | NR | NR | NR
WHS Ridker, 2005^58^ Rexrode, 2000^69^ Good 10.1 years | A priori Diagnostic criteria: assumption is self-reported history of diabetes from the enrollment questionnaire | Fatal MI/coronary events + Fatal stroke+ CVD death (not specified) | NR | NR | NR
WHS Ridker, 2005^58^ Rexrode, 2000^69^ Good 10.1 years | A priori Diagnostic criteria: assumption is self-reported history of diabetes from the enrollment questionnaire | Nonfatal MI/coronary events + nonfatal stroke | NR | NR | NR
WHS Ridker, 2005^58^ Rexrode, 2000^69^ Good 10.1 years | A priori Diagnostic criteria: assumption is self-reported history of diabetes from the enrollment questionnaire | Fatal MI/coronary events + Fatal stroke + CVD death (not specified) + nonfatal MI/coronary events + nonfatal stroke | IG: 58/528^‡^ (11.0%) CG: 62/499^‡^ (12.4%) 0.9 (0.63 to 1.29)^§^ | IG: 418/19,406^‡^ (2.2%) CG: 460/19,443^‡^ (2.4%) 0.9 (0.79 to 1.03)^§^ | NR
WHS Ridker, 2005^58^ Rexrode, 2000^69^ Good 10.1 years | A priori Diagnostic criteria: assumption is self-reported history of diabetes from the enrollment questionnaire | Other CVD composite reported in the trial | Same as total CVD event composite | Same as total CVD event composite | NR
WHS Ridker, 2005^58^ Rexrode, 2000^69^ Good 10.1 years | A priori Diagnostic criteria: assumption is self-reported history of diabetes from the enrollment questionnaire | All-cause mortality | NR | NR | NR
WHS Ridker, 2005^58^ Rexrode, 2000^69^ Good 10.1 years | A priori Diagnostic criteria: assumption is self-reported history of diabetes from the enrollment questionnaire | Major GI bleeding | NR | NR | NR
ETDRS ETDRS, 1992^55^ Fair 5 years | NA (trial in DM only) Diagnostic criteria: clinical diagnosis of type 1 or 2 DM (additionally, must have diabetic retinopathy) | Fatal MI/coronary events + Fatal stroke | IG: 72/1,856 (3.9%) CG: 92/1,855 (5.0%) 0.78 (0.58 to 1.06)^**^ | NA | NA
ETDRS ETDRS, 1992^55^ Fair 5 years | NA (trial in DM only) Diagnostic criteria: clinical diagnosis of type 1 or 2 DM (additionally, must have diabetic retinopathy) | Fatal MI/coronary events + Fatal stroke + CVD death (not specified) | IG: 244/1,856 (13.1%) CG: 275/1,855 (14.8%) 0.89 (0.76 to 1.04)^**^ | NA | NA
ETDRS ETDRS, 1992^55^ Fair 5 years | NA (trial in DM only) Diagnostic criteria: clinical diagnosis of type 1 or 2 DM (additionally, must have diabetic retinopathy) | Nonfatal MI/coronary events + nonfatal stroke | NR | NA | NA
ETDRS ETDRS, 1992^55^ Fair 5 years | NA (trial in DM only) Diagnostic criteria: clinical diagnosis of type 1 or 2 DM (additionally, must have diabetic retinopathy) | Fatal MI/coronary events + Fatal stroke + CVD death (not specified) + nonfatal MI/coronary events + nonfatal stroke | IG: 350/1,856 (18.9%) CG: 379/1,855 (20.4%) 0.92 (0.81 to 1.05)^**^ | NA | NA
ETDRS ETDRS, 1992^55^ Fair 5 years | NA (trial in DM only) Diagnostic criteria: clinical diagnosis of type 1 or 2 DM (additionally, must have diabetic retinopathy) | Other CVD composite reported in the trial | Same as total CVD event composite | NA | NA
ETDRS ETDRS, 1992^55^ Fair 5 years | NA (trial in DM only) Diagnostic criteria: clinical diagnosis of type 1 or 2 DM (additionally, must have diabetic retinopathy) | All-cause mortality | IG: 340/1,856 (18.3%) CG: 366/1,855 (19.7%) 0.93 (0.81 to 1.06)^**^ | NA | NA
ETDRS ETDRS, 1992^55^ Fair 5 years | NA (trial in DM only) Diagnostic criteria: clinical diagnosis of type 1 or 2 DM (additionally, must have diabetic retinopathy) | Major GI bleeding | NR | NA | NA
JPAD Ogawa, 2008^43^ Fair 4.4 years║ | NA (trial in DM only) Diagnostic criteria: diagnosis of type 2 DM | Fatal MI/coronary events + Fatal stroke | IG: 1/1,262 (0.08%) CG: 10/1,277 (0.8%) 0.10 (0.01 to 0.79)^**^ | NA | NA
JPAD Ogawa, 2008^43^ Fair 4.4 years║ | NA (trial in DM only) Diagnostic criteria: diagnosis of type 2 DM | Fatal MI/coronary events + Fatal stroke + CVD death (not specified) | IG: 1/1,262 (0.08%) CG: 10/1,277 (0.8%) 0.10 (0.01 to 0.79)^**^ | NA | NA
JPAD Ogawa, 2008^43^ Fair 4.4 years║ | NA (trial in DM only) Diagnostic criteria: diagnosis of type 2 DM | Nonfatal MI/coronary events + nonfatal stroke | IG: 39/1,262 (3.1%)^**^ CG: 36/1,277 (2.8%)^**^ 1.10 (0.70 to 1.71)^**^ | NA | NA
JPAD Ogawa, 2008^43^ Fair 4.4 years║ | NA (trial in DM only) Diagnostic criteria: diagnosis of type 2 DM | Fatal MI/coronary events + Fatal stroke + CVD death (not specified) + nonfatal MI/coronary events + nonfatal stroke | IG: 40/1,262 (3.2%)^**^ CG: 46/1,277 (3.6%)^**^ 0.88 (0.58 to 1.33)^**^ | NA | NA
JPAD Ogawa, 2008^43^ Fair 4.4 years║ | NA (trial in DM only) Diagnostic criteria: diagnosis of type 2 DM | Other CVD composite reported in the trial | Primary composite outcome (sudden death; death from coronary, cerebrovascular, and aortic causes; nonfatal acute MI; unstable angina; newly developed exertional angina; nonfatal ischemic and hemorrhagic stroke; TIA; or nonfatal aortic and peripheral vascular disease) IG: 68/1,262 (5.4%) CG: 86/1,277 (6.7%) 0.80 (0.59 to 1.09)^**^ | NA | NA
JPAD Ogawa, 2008^43^ Fair 4.4 years║ | NA (trial in DM only) Diagnostic criteria: diagnosis of type 2 DM | All-cause mortality | IG: 34/1,262 (2.7%) CG: 38/1,277 (3.0%) 0.91 (0.57 to 1.43)^**^ | NA | NA
JPAD Ogawa, 2008^43^ Fair 4.4 years║ | NA (trial in DM only) Diagnostic criteria: diagnosis of type 2 DM | Major GI bleeding | IG 4/1,262^¶^ (0.3%) CG 0/1,277^¶^ (0%) 8.10 (0.43 to 152.96)^**^ | NA | NA
POPADAD Belch, 2008^44^ Fair 6.7 years║ | NA (trial in DM only) Diagnostic criteria: type 1 or 2 diabetes, not further specified | Fatal MI/coronary events + Fatal stroke | IG: 43/638 (6.7%) CG: 35/638 (5.5%) 1.23 (0.80 to 1.89)^**^ | NA | NA
POPADAD Belch, 2008^44^ Fair 6.7 years║ | NA (trial in DM only) Diagnostic criteria: type 1 or 2 diabetes, not further specified | Fatal MI/coronary events + Fatal stroke + CVD death (not specified) | IG: 43/638 (6.7%) CG: 35/638 (5.5%) 1.23 (0.80 to 1.89)^**^ | NA | NA
POPADAD Belch, 2008^44^ Fair 6.7 years║ | NA (trial in DM only) Diagnostic criteria: type 1 or 2 diabetes, not further specified | Nonfatal MI/coronary events + nonfatal stroke | IG: 84/638 (13.2%)^**^ CG: 97/638 (15.2%)^**^ 0.87 (0.66 to 1.14)^**^ | NA | NA
POPADAD Belch, 2008^44^ Fair 6.7 years║ | NA (trial in DM only) Diagnostic criteria: type 1 or 2 diabetes, not further specified | Fatal MI/coronary events + Fatal stroke+ CVD death (not specified) + nonfatal MI/coronary events + nonfatal stroke | IG: 127/638 (19.9%)^**^ CG: 132/638 (20.7%)^**^ 0.96 (0.77 to 1.20)^**^ | NA | NA
POPADAD Belch, 2008^44^ Fair 6.7 years║ | NA (trial in DM only) Diagnostic criteria: type 1 or 2 diabetes, not further specified | Other CVD composite reported in the trial | Primary composite outcome (death from CHD or stroke, nonfatal MI or stroke, or above ankle amputation for critical limb ischemia) IG: 116/638 (18.2%) CG: 117/638 (18.3%) 0.99 (0.79 to 1.25)^**^ | NA | NA
POPADAD Belch, 2008^44^ Fair 6.7 years║ | NA (trial in DM only) Diagnostic criteria: type 1 or 2 diabetes, not further specified | All-cause mortality | IG: 94/638 (14.7%) CG: 101/638 (15.8%) 0.93 (0.72 to 1.21)^**^ | NA | NA
POPADAD Belch, 2008^44^ Fair 6.7 years║ | NA (trial in DM only) Diagnostic criteria: type 1 or 2 diabetes, not further specified | Major GI bleeding | NR^#^ | NA | NA

Within study comparisons listed first.

* There are an additional 289 patients with DM in this publication compared with Roncaglioni 2001 because “in parallel with the main trial, we also involved 14 DM clinics with the aim of recruiting additional sample of DM patients.”

† N for patients with no DM in IG and CG back-calculated from % with event reported in Figure 2 (Ns are not reported in the article), resulting in a discrepancy of 11 participants, likely due to rounding. Back-calculation was performed using primary endpoint; resulting Ns are different depending on which outcome was used.

‡ All denominator Ns in each group back-calculated from Table 3 in Rexrode 2000 (Ns for IG and CG for those with and without DM not reported). Back-calculation results in a discrepancy of 24 participants, likely due to rounding.

§ RRs adjusted for age and treatment assignment to vitamin E and beta carotene.

║ Median.

¶ Severe GI bleeding requiring transfusion.

# Severity of reported GI bleeding events unknown; thus, we did not classify as major.

** Calculated

Abbreviations: AAA = Aspiring for Asymptomatic Atherosclerosis Trial; BMD = British Medical Doctor's Study; CG = control group; CI = confidence interval; CV = cardiovascular; CVD = cardiovascular disease; DM = diabetes mellitus; ETDRS = Early Treatment Diabetic Retinopathy Study; HOT = Hypertension Optimal Treatment Study; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes Study; MI = myocardial infarction; N/A = not applicable; NR = not reported; PAD = peripheral artery disease; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; PPP = Primary Prevention Project; RR = relative risk; TIA = transient ischemic attack; WHS = Women's Health Study.

Table 15 Diabetes Subgroup: Total, Fatal, and Nonfatal MI/Coronary Events

Study Reference Quality Rating Mean Followup | Type of Analysis Diabetes Diagnostic Criteria | Outcome | Diabetes Events/Participants (%) RR (95% CI) | No Diabetes Events/Participants (%) RR (95% CI) | P-Value for Interaction
HOT Zanchetti, 2007^62^ Fair 3.8 years | Specification unclear Diagnostic criteria: NR | Total MI/Coronary Events | IG: 11/752 (1.5%) CG: 18/749 (2.4%) 0.61 (0.29 to 1.29) | IG: 71/8,647 (0.8%) CG: 109/8,642 (1.3%) 0.65 (0.48 to 0.87) | NS (value NR)
HOT Zanchetti, 2007^62^ Fair 3.8 years | Specification unclear Diagnostic criteria: NR | Fatal MI/Coronary Events | NR | NR | NR
HOT Zanchetti, 2007^62^ Fair 3.8 years | Specification unclear Diagnostic criteria: NR | Nonfatal MI/Coronary Events | NR | NR | NR
PHS I Physician's Health Study, 1989^53^ Good 5 years | Specification unclear Diagnostic criteria: NR | Total MI/Coronary Events | IG: 11/275 (4.0%) CG: 26/258 (10.1%) 0.40 (0.20 to 0.79) [c] | IG: 128/10,750 (1.2%) CG: 213/10,763 (2.0%) 0.60 (0.48 to 0.75) [c] | 0.22^†^
PHS I Physician's Health Study, 1989^53^ Good 5 years | Specification unclear Diagnostic criteria: NR | Fatal MI/Coronary Events | NR | NR | NR
PHS I Physician's Health Study, 1989^53^ Good 5 years | Specification unclear Diagnostic criteria: NR | Nonfatal MI/Coronary Events | NR | NR | NR
PPP^‡^ Sacco, 2003^63^ Fair 3.7 years | Post hoc Diagnostic criteria: fasting venous plasma glucose ≥7.8 mmol/L on at least 2 separate occasions or treated with antidiabetes drug | Total MI/Coronary Events | IG: 5/519 (1.0%) CG: 10/512 (2.0) 0.49 (0.17 to 1.40) | IG: 15/1,875^§^ (0.8%) CG: 22/1,889^§^ (1.2%) 0.69 (0.36 to 1.35) | NR
PPP^‡^ Sacco, 2003^63^ Fair 3.7 years | Post hoc Diagnostic criteria: fasting venous plasma glucose ≥7.8 mmol/L on at least 2 separate occasions or treated with antidiabetes drug | Fatal MI/Coronary Events | NR | NR | NR
PPP^‡^ Sacco, 2003^63^ Fair 3.7 years | Post hoc Diagnostic criteria: fasting venous plasma glucose ≥7.8 mmol/L on at least 2 separate occasions or treated with antidiabetes drug | Nonfatal MI/Coronary Events | NR | NR | NR
WHS Ridker, 2005^58^ Rexrode, 2000^69^ Good 10.1 years | A priori Diagnostic criteria: Assumed self-reported history of diabetes from the enrollment questionnaire | Total MI/Coronary Events | IG: 36/528║ (6.8%) CG: 24/499║ (4.8%) 1.48 (0.88 to 2.49)^¶^ | IG: 162/19,406║ (0.8%) CG: 169/19,443║ (0.9%) 0.96 (0.77 to 1.18)^¶^ | NR
WHS Ridker, 2005^58^ Rexrode, 2000^69^ Good 10.1 years | A priori Diagnostic criteria: Assumed self-reported history of diabetes from the enrollment questionnaire | Fatal MI/Coronary Events | NR | NR | NR
WHS Ridker, 2005^58^ Rexrode, 2000^69^ Good 10.1 years | A priori Diagnostic criteria: Assumed self-reported history of diabetes from the enrollment questionnaire | Nonfatal MI/Coronary Events | NR | NR | NR
ETDRS ETDRS, 1992^55^ Fair 5 years | NA (trial in DM only) Diagnostic criteria: clinical diagnosis of type 1 or 2 DM (additionally, must have diabetic retinopathy) | Total MI/Coronary Events | IG: 241/1,856 (13.0%) CG: 283/1,855 (15.3%) 0.85 (0.73 to 1.00)^††^ | NA | NA
ETDRS ETDRS, 1992^55^ Fair 5 years | NA (trial in DM only) Diagnostic criteria: clinical diagnosis of type 1 or 2 DM (additionally, must have diabetic retinopathy) | Fatal MI/Coronary Events | IG: 47/1,856 (2.5%)^#^ CG: 67/1,855 (3.6%)^#^ 0.70 (0.49 to 1.01)^††^ | NA | NA
ETDRS ETDRS, 1992^55^ Fair 5 years | NA (trial in DM only) Diagnostic criteria: clinical diagnosis of type 1 or 2 DM (additionally, must have diabetic retinopathy) | Nonfatal MI/Coronary Events | NR | NA | NA
JPAD Ogawa, 2008^43^ Fair 4.4 years^**^ | NA (trial in DM only) Diagnostic criteria: diagnosis of type 2 DM, not further specified | Total MI/Coronary Events | IG: 12/1,262 (1.0%) CG: 14/1,277 (1.1%) 0.87 (0.40 to 1.87)^††^ | NA | NA
JPAD Ogawa, 2008^43^ Fair 4.4 years^**^ | NA (trial in DM only) Diagnostic criteria: diagnosis of type 2 DM, not further specified | Fatal MI/Coronary Events | IG: 0/1,262 (0%) CG: 5/1,277 (0.4%) 0.10 (0.01 to 1.85)^††^ | NA | NA
JPAD Ogawa, 2008^43^ Fair 4.4 years^**^ | NA (trial in DM only) Diagnostic criteria: diagnosis of type 2 DM, not further specified | Nonfatal MI/Coronary Events | IG: 12/1,262 (1.0%) CG: 9/1,277 (0.7%) 1.35 (0.57 to 3.19)^††^ | NA | NA
POPADAD Belch, 2008^44^ Fair 6.7 years^**^ | NA (trial in DM only) Diagnostic criteria: type 1 or 2 diabetes, not further specified | Total MI/Coronary Events | IG: 90/638 (14.1%) CG: 82/638 (12.8%) 1.10 (0.83 to 1.45)^††^ | NA | NA
POPADAD Belch, 2008^44^ Fair 6.7 years^**^ | NA (trial in DM only) Diagnostic criteria: type 1 or 2 diabetes, not further specified | Fatal MI/Coronary Events | IG: 35/638 (5.5%) CG: 26/638 (4.1%) 1.35 (0.81 to 2.25)^††^ | NA | NA
POPADAD Belch, 2008^44^ Fair 6.7 years^**^ | NA (trial in DM only) Diagnostic criteria: type 1 or 2 diabetes, not further specified | Nonfatal MI/Coronary Events | IG: 55/638 (8.6%) CG: 56/638 (8.8%) 0.98 (0.69 to 1.40)^††^ | NA | NA

Within study comparisons listed first.

† P-value of trend in relative risk.

‡ There are an additional 289 patients with DM in this publication compared with Roncaglioni 2001 because “in parallel with the main trial, we also involved 14 DM clinics with the aim of recruiting additional sample of DM patients.”

§ N for patients with no DM in IG and CG back-calculated from % with event reported in Figure 2 (these Ns are not reported in the article), resulting in a discrepancy of 11 participants, likely due to rounding. Back-calculation was performed using primary endpoint; resulting Ns are different depending on the outcome.

║ All denominator Ns in each group back-calculated from Table 3 in Rexrode 2000 (Ns for IG and CG for those with and without DM not reported). Back-calculation results in a discrepancy of 24 participants, likely due to rounding.

¶ Adjusted for age and treatment assignment to vitamin E and beta carotene.

# Sudden coronary death.

** Median.

†† Calculated.

Abbreviations: CG = control group; CI = confidence interval; DM = diabetes mellitus; ETDRS = Early Treatment Diabetic Retinopathy Study; HOT = Hypertension Optimal Treatment Study; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes Study; MI = myocardial infarction; NA = not applicable; NR = not reported; PHS = Physicians Health Study; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; PPP = Primary Prevention Project; RR = relative risk; WHS = Women's Health Study.

Table 16 Diabetes Subgroup: Total, Fatal, and Nonfatal Stroke

Study Reference Quality Rating Mean Followup | Type of Analysis Diabetes Diagnostic Criteria | Outcome | Diabetes Events/Participants (%) RR (95% CI) | No Diabetes Events/Participants (%) RR (95% CI) | P-Value for Interaction
HOT Zanchetti, 2007^62^ Fair 3.8 years | Specification unclear Diagnostic criteria: NR | Total Stroke | IG: 20/752 (2.6%) CG: 22/749 (2.9%) 0.91 (0.50 to 1.67) | IG: 126/8,647 (1.4%) CG: 126/8,642 (1.4%) 1.00 (0.78 to 1.27) | NS (value NR)
HOT Zanchetti, 2007^62^ Fair 3.8 years | Specification unclear Diagnostic criteria: NR | Fatal Stroke | NR | NR | NR
HOT Zanchetti, 2007^62^ Fair 3.8 years | Specification unclear Diagnostic criteria: NR | Nonfatal Stroke | NR | NR | NR
PPP^*^ Sacco, 2003^63^ Fair 3.7 years | Post hoc Diagnostic criteria: fasting venous plasma glucose ≥7.8 mmol/L on at least 2 separate occasions or treated with antidiabetes drugs | Total Stroke | IG: 9/519 (1.7%) CG: 10/512 (2.0%) 0.89 (0.36 to 2.17) | IG: 11/1,875^†^ (0.6%) CG: 19/1,889^†^ (0.1%) 0.59 (0.28 to 1.25) | NR
PPP^*^ Sacco, 2003^63^ Fair 3.7 years | Post hoc Diagnostic criteria: fasting venous plasma glucose ≥7.8 mmol/L on at least 2 separate occasions or treated with antidiabetes drugs | Fatal Stroke | NR | NR | NR
PPP^*^ Sacco, 2003^63^ Fair 3.7 years | Post hoc Diagnostic criteria: fasting venous plasma glucose ≥7.8 mmol/L on at least 2 separate occasions or treated with antidiabetes drugs | Nonfatal Stroke | NR | NR | NR
WHS Ridker, 2005^58^ Rexrode, 2000^69^ Good 10.1 years | A priori Diagnostic criteria: assumed self-reported history of diabetes from the enrollment questionnaire | Total Stroke | IG: 15/528^‡^ (2.8%) CG: 31/499^‡^ (6.2%) 0.46 (0.25 to 0.85)^§^ | IG: 206/19,406^‡^ (1.1%) CG: 235/19,443^‡^ (1.2%) 0.87 (0.72 to 1.05)^§^ | NR
WHS Ridker, 2005^58^ Rexrode, 2000^69^ Good 10.1 years | A priori Diagnostic criteria: assumed self-reported history of diabetes from the enrollment questionnaire | Fatal Stroke | NR | NR | NR
WHS Ridker, 2005^58^ Rexrode, 2000^69^ Good 10.1 years | A priori Diagnostic criteria: assumed self-reported history of diabetes from the enrollment questionnaire | Nonfatal Stroke | NR | NR | NR
ETDRS ETDRS, 1992^55^ Fair 5 years | NA (trial in DM only) Diagnostic criteria: clinical diagnosis of type 1 or 2 DM (additionally, must have diabetic retinopathy) | Total Stroke | IG: 92/1,856 (5.0%) CG: 78/1,855 (4.2%) 1.18 (0.88 to 1.58)^¶^ | NA | NA
ETDRS ETDRS, 1992^55^ Fair 5 years | NA (trial in DM only) Diagnostic criteria: clinical diagnosis of type 1 or 2 DM (additionally, must have diabetic retinopathy) | Fatal Stroke | IG: 25/1,856 (1.3%) CG: 25/1,855 (1.3%) 1.00 (0.58 to 1.73)^¶^ | NA | NA
ETDRS ETDRS, 1992^55^ Fair 5 years | NA (trial in DM only) Diagnostic criteria: clinical diagnosis of type 1 or 2 DM (additionally, must have diabetic retinopathy) | Nonfatal Stroke | IG: 67/1,856 (3.6%) CG: 53/1,855 (2.8%) 1.26 (0.89 to 1.80)^¶^ | NA | NA
JPAD Ogawa, 2008^43^ Fair 4.4 years║ | NA (trial in DM only) Diagnostic criteria: diagnosis of type 2 DM, not further specified | Total Stroke | IG: 28/1,262 (2.2%) CG: 32/1,277 (2.5%) 0.89 (0.54 to 1.46)^¶^ | NA | NA
JPAD Ogawa, 2008^43^ Fair 4.4 years║ | NA (trial in DM only) Diagnostic criteria: diagnosis of type 2 DM, not further specified | Fatal Stroke | IG: 1/1,262 (0.08%) CG: 5/1,277 (0.4%) 0.20 (0.02 to 1.73)^¶^ | NA | NA
JPAD Ogawa, 2008^43^ Fair 4.4 years║ | NA (trial in DM only) Diagnostic criteria: diagnosis of type 2 DM, not further specified | Nonfatal Stroke | IG: 27/1,262 (2.1%) CG: 27/1,277 (2.1%) 1.01 (0.60 to 1.72)^¶^ | NA | NA
POPADAD Belch, 2008^44^ Fair 6.7 years║ | NA (trial in DM only) Diagnostic criteria: type 1 or 2 diabetes, not further specified | Total Stroke | IG: 37/638 (5.8%) CG: 50/638 (7.8%) 0.74 (0.49 to 1.12)^¶^ | NA | NA
POPADAD Belch, 2008^44^ Fair 6.7 years║ | NA (trial in DM only) Diagnostic criteria: type 1 or 2 diabetes, not further specified | Fatal Stroke | IG: 8/638 (1.3%) CG: 9/638 (1.4%) 0.89 (0.35 to 2.29)^¶^ | NA | NA
POPADAD Belch, 2008^44^ Fair 6.7 years║ | NA (trial in DM only) Diagnostic criteria: type 1 or 2 diabetes, not further specified | Nonfatal Stroke | IG: 29/638 (4.6%) CG: 41/638 (6.4%) 0.71 (0.45 to 1.12)^¶^ | NA | NA

Within study comparisons listed first.

* There are an additional 289 patients with DM in this publication compared with Roncaglioni 2001 because “in parallel with the main trial, we also involved 14 DM clinics with the aim of recruiting additional sample of DM patients.”

† N for patients with no DM in IG and CG back-calculated from % with event reported in Figure 2 (these Ns are not reported in the article), resulting in a discrepancy of 11 participants, likely due to rounding. Back-calculation was performed using primary endpoint; resulting Ns are different depending on the outcome.

‡ Note: All denominator Ns in each group back-calculated from Table 3 in Rexrode 2000 (Ns for IG and CG for those with and without DM not reported). Back-calculation results in a discrepancy of 24 participants, likely due to rounding.

§ Adjusted for age and treatment assignment to vitamin E and beta carotene.

║ Median.

¶ Calculated.

Abbreviations: CG = control group; CI = confidence interval; DM = diabetes mellitus; ETDRS = Early Treatment Diabetic Retinopathy Study; HOT = Hypertension Optimal Treatment Study; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes Study; MI = myocardial infarction; NA = not applicable; NR = not reported; NS = not significant; PHS = Physician's Health Study; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; PPP = Primary Prevention Project; RR = relative risk; WHS = Women's Health Study.

Six trials reporting subgroup results for smoking, CVD risk, and abnormal ABI showed varied results.43-45,53,58,64 For smoking, two trials showed no interaction or statistically significant trend in MI/coronary events or stroke with smoking.43,53 Conversely, another trial showed a trend of statistically significant benefit in patients who have never smoked, which was not seen in current/past smokers for total stroke, ischemic stroke, and a CVD event composite.58 Overall, no clear relationship between smoking status and aspirin effects was apparent. For CVD risk, two trials58,64 performed risk-based subanalyses and a third trial was conducted in a high-risk CVD population.54 None of these trials clearly reported interaction testing or adjustments for confounders and only one analysis was clearly reported as a priori.58 One trial with subgroup analysis by CVD risk showed that only participants with greater than 20 percent 10-year risk had a statistically significant reduction in total MI and the trial's reported CVD composite;56 one exclusively female trial showed that only participants with a greater than or equal to10 percent 10-year CVD risk had a statistically significant reduction in total stroke.58 The one trial conducted in high-risk men showed a statistically significant reduction in nonfatal MI/coronary events and in a nonfatal composite CVD outcome.54 The ATT IPD meta-analysis showed a statistically significant reduction in total serious vascular events only in the patients with less than 5 percent 5-year CVD risk, but heterogeneity testing revealed no statistical heterogeneity between the risk groups.33 Based on two trials recruiting participants with an abnormal ABI, there appears to be no modification of treatment benefit based on ABI threshold.44,45

Trials examining the subgroup effects of patients with elevated blood pressure or lipid levels reported conflicting results, making it difficult to draw any conclusions about a differential benefit of aspirin in these groups. Five trials performed subgroup analyses in hypertensive and normotensive groups or for systolic blood pressure (SBP)/diastolic blood pressure (DBP) levels with varied results.53,58,64-66 One of these trials, HOT, showed a trend of higher SBP and DBP being associated with a greater reduction in major cardiovascular events and total MI.64 Conversely, another of these trials reported an interaction with lower SBP leading to a greater RR reduction in total stroke,66 but the timing of their analysis is unclear. Further, one trial reported no trends in the RR of total MI/coronary events or CVD mortality by SBP/DBP level.53 As a result, the results of these studies were inconsistent.

Four trials reported subgroup analyses by total cholesterol levels or by presence or absence of dyslipidemia (defined as total cholesterol ≥240 mg/dL in WHS; not defined in JPAD).43,53,58,66 While two of these trials performed subgroup analyses a priori,43,58 the other two trials do not specify the timing of their analyses.53,66 Two trials were conducted exclusively in men and showed an interaction between aspirin use and lipid levels, with greater aspirin benefit seen in patients with the lowest cholesterol levels for total MI/coronary events or total stroke.53,66 Another trial, which was conducted exclusively in women, showed a statistically significant reduction in composite CVD outcomes, total stroke, and ischemic stroke with aspirin therapy, which was not seen in the normal cholesterol group.58

### Age

#### Trial Characteristics

In the seven studies that reported mean ages, the mean age was relatively young and ranged from 54.6 to 64.5 years.43-45,54,56,58,59 Ninety percent of WHS participants were younger than age 65 years and 75 percent of PHS participants were younger than age 60 years. In three trials, approximately half of participants were older than age 60 to 65 years.43,44,59 The upper age limit was specified in the inclusion criteria for six trials, ranging from 69 to 85 years.43,45,53-56

Three trials reported age as an a priori subgroup: JPAD (<65 and ≥65 years), AAA (<62 and ≥62 years), and WHS (45 to 54, 55 to 64, and ≥65 years).43,45,58 The only two trials that compared the same age group strata were JPAD and HOT (<65 and ≥65 years).43,60 The ATT IPD meta-analysis analyzed the composite outcome of serious vascular events (defined as MI, stroke, or death from a vascular cause, including sudden death, pulmonary embolism, and hemorrhage) by patients younger than age 65 and patients age 65 years or older.33

#### Results by Outcome

##### Effect of Aspirin on All-Cause Mortality by Age

Only one trial, HOT, reported all-cause mortality by age and reported no statistically significant effect of aspirin on all-cause mortality in either patients younger than age 65 years or those age 65 years or older (Table 8).60

##### Effect of Aspirin on MI/Coronary Events by Age

Three trials provided subgroup analyses by age for total MI, but only WHS had an a priori analysis (Table 9).53,58,60 HOT and WHS both showed a statistically significant reduction in total MI/coronary event among patients age 65 years or older (HOT: RR, 0.62 [95% CI, 0.38 to 0.98];60 WHS: adjusted (adj)RR, 0.66 [95% CI, 0.44 to 0.97]58). PHS showed a greater RR reduction with older age: it decreased from 1.12 (ages 40 to 49 years) to 0.49 (ages 70 to 84 years), with a statistically significant trend (p=0.02).53 These studies appear to show a consistent trend of greater RR reduction in total MI/coronary events with aspirin use with older age; both PHS and WHS reported p-values for interaction of 0.02 and 0.03 with age.53,58 A 2011 post hoc analysis of WHS showed that aspirin treatment resulted in less than 1 percent absolute risk reduction in major cardiovascular events among the majority of patients (>90%); age was the strongest determinant of treatment effect, where older women (age ≥65 years) had the highest absolute treatment effects.67

The ATT IPD meta-analysis did not find any heterogeneity of effect on major coronary events by age.33

##### Effect of Aspirin on Stroke by Age

Three trials provided subgroup analyses by age for total stroke, but again, only WHS clearly specified theirs as an a priori analysis (Table 10).54,58,60 None of these trials showed a statistically significant difference in stroke outcomes between the aspirin and control groups for any age strata. These trials revealed no trend in nonsignificant RRs. Of these trials, only TPT conducted interaction testing, showing no interaction between stroke and age (p=0.85 for interaction).54 WHS showed no statistically significant benefit for ischemic stroke in any of the age strata (45 to 64, 55 to 64, or ≥65 years).58

##### Effect of Aspirin on Composite Outcomes by Age

Six trials provided subgroup analyses by age for composite outcomes (Table 8).43-45,53,58,60 JPAD, POPADAD, and WHS performed interaction testing; JPAD and POPADAD showed no interaction between age and composite outcomes measured, while WHS showed a borderline statistically significant interaction (p=0.05).43,44,58 Additionally, AAA and HOT showed nonstatistically significant interactions for their fatal CVD composite outcome; however, both trials showed trends of benefit favoring aspirin among younger patients (<62 or 65 years) and among the older age groups (≥62 or 65 years) favoring control.45,60 Further, HOT showed a statistically significant reduction in its total CVD composite among patients younger than age 65 years (RR, 0.79 [95% CI, 0.64 to 0.98]), but not in patients age 65 years or older.60 Conversely, WHS showed a statistically significant reduction in its CVD event composite only among patients in the oldest age group (≥65 years) (adjRR, 0.74 [95% CI, 0.59 to 0.92]), which comprised only 10 percent of its total trial population.58

The ATT IPD meta-analysis showed a statistically significant reduction in its composite of serious vascular events (defined as MI, stroke, or death from a vascular cause, including sudden death, pulmonary embolism, and hemorrhage) among patients younger than age 65 years, but not among patients age 65 years or older, and found no heterogeneity of effect on serious vascular events by age.33

### Sex

#### Trial Characteristics

All 10 trials included in this KQ reported sex-specific outcomes.43-45,53-55,57,58,60,61 Four trials recruited a single sex: BMD, PHS, and TPT recruited only men, while WHS recruited only women.53,54,57,58 Two trials reported outcomes for an a priori sex subgroup analysis.43,45 Four trials reported outcomes by sex without specifying if the analysis was prespecified or post hoc.44,55,60,61 WHS was the largest trial (n=39,876) with the longest followup (10.1 years) that contributed sex-specific information.58 The six trials that included both sexes recruited study populations that were between 43.5 and 72.0 percent women.43-45,55,56,59 The ATT IPD meta-analysis33 included sex-specific results for the outcomes of ischemic stroke and major coronary events (defined as MI, coronary death, or sudden death), and performed interaction testing and adjustments for multiple comparisons. In 2013, 8 years after the completion of WHS, an observational followup of a median of 18 years comprising 33,682 patients out of the original 39,876 randomized trial participants (88.6%) was published using annual participant questionnaires and medical record review.68 These results were similar to the previously published results and reported no differences between treatment groups for major CVD events, MI, total stroke, or CVD mortality. These results did find, however, a statistically significant reduction in ischemic stroke events.68

#### Results by Outcome

##### Effect of Aspirin on All-Cause Mortality by Sex

All-cause mortality by sex was reported in seven trials, with aspirin showing no effect when men and women were analyzed separately (Table 11).53,57,58 54,55,60,61

##### Effect of Aspirin on MI/Coronary Events by Sex

Seven trials reported total MI/coronary events by sex, with BMD, TPT, and PHS providing results for fatal and nonfatal MI/coronary events separately (Table 12).53-55,57,58,60,61 For total MI, only HOT showed a beneficial effect in men, but not women (men: RR, 0.58 [95% CI, 0.41 to 0.81]; women: RR, 0.81 [95% CI, 0.49 to 1.31]).60 PHS showed a reduction in total MI/coronary events with aspirin (RR, 0.67 [95% CI, 0.55 to 0.80]),53 but the other two trials conducted exclusively in men54,57 showed no effect of aspirin on total MI/coronary events. WHS showed no effect of aspirin on total MI/coronary events in women.58 The ATT IPD meta-analysis reported major coronary events (defined as MI/coronary events, coronary death, or sudden death) and showed that after testing for heterogeneity or trend, the only statistically significant subgroup difference was between men and women (p=0.03). This finding, however, was no longer significant when adjusted for multiple comparisons (p=0.33).33 All three of the trials conducted only in men showed no effect of aspirin for fatal MI.53,54,57 Two of these trials showed a reduction in nonfatal MI/coronary events53,54 and the remaining trial showed no effect of nonfatal MI/coronary events.57

##### Effect of Aspirin on Stroke by Sex

Seven trials reported total stroke events by sex (Table 13).53-55,57,58,60,61Only one trial showed a statistically significant reduction in total stroke in women.58 The other six trials showed no statistically significant effect of aspirin in either men or women.53,57 54 55,60,61 BMD, PHS, TPT, and WHS reported fatal and nonfatal stroke separately and all showed no statistically significant difference in fatal stroke events, which were relatively rare in most trials.53,54,57,58 The three trials conducted exclusively in men showed no effect of aspirin on nonfatal stroke events53,54,57 and the one trial conducted in women showed a statistically significant reduction in nonfatal stroke events (adjRR, 0.81 [95% CI, 0.67 to 0.97]).58

Five trials reported stroke subtype by sex, but interpretation is limited by the rarity of stroke events, especially when broken down by subtype and fatal versus nonfatal.53,54,57,58,61 Looking at all ischemic stroke, only WHS showed a statistically significant reduction in all ischemic stroke among women (adjRR, 0.76 [95% CI, 0.63 to 0.93]).58 The ATT IPD meta-analysis analyzed ischemic stroke by sex. After testing for heterogeneity of effect, this trial reported that any subgroup difference between men and women (p=0.08) was no longer significant when adjusted for multiple comparisons (p=0.88).33

##### Effect of Aspirin on Composite Outcomes by Sex

For composite CVD outcomes, trials reported no statistically significant effect of aspirin, with the exception of two trials conducted exclusively in men (Table 11).53,54 Both of these studies—TPT and PHS—showed a statistically significant reduction in a total CVD composite (TPT: RR, 0.76 [95% CI, 0.60 to 0.97]; PHS: adjRR, 0.82 [95% CI, 0.70 to 0.96]) and a CVD composite comprised of nonfatal stroke/MI/coronary events (TPT: RR, 0.64 [95% CI, 0.47 to 0.88]; PHS: RR, 0.78 [95% CI, 0.66 to 0.93]). Additionally, WHS did not show a statistically significant benefit for any composite outcomes.58 The ATT IPD meta-analysis of the composite outcome of serious vascular events (defined as MI, stroke, or death from a vascular cause, including sudden death, pulmonary embolism, and hemorrhage) by sex revealed no significant heterogeneity between men and women (p=0.9).33

### Diabetes

#### Trial Characteristics

Three trials only recruited patients with diabetes43,44,55 and an additional five trials performed subgroup analyses on patients with diabetes.45,53,58,62,63 ETDRS likely had participants with the most advanced diabetes out of the three diabetes trials, as more than 80 percent of participants were using daily insulin, more than 40 percent had a hemoglobin A1c level of 10 percent or higher, and all participants had diabetic retinopathy.55 POPADAD's mean baseline hemoglobin A1c level was approximately 8 percent, and 30 percent of participants were treated with insulin.44 JPAD, on the other end of the disease severity spectrum, likely had patients with the least severe diabetic disease, reporting a baseline mean hemoglobin A1c level of 7 percent, and 13 percent of participants taking daily insulin.43

#### Results by Outcome

##### Effect of Aspirin on All-Cause Mortality by Diabetes Status

Five trials reported all-cause mortality by diabetes status or were trials recruiting only diabetes patients, with no trials showing a statistically significant benefit with aspirin (Table 14).43,44,55,62,63 HOT and PPP showed nonstatistically significant results for both patients with and without diabetes, with point estimates greater than 1 for diabetes patients (PPP: RR, 1.23; HOT: RR, 1.12).62,63 The three trials conducted exclusively in diabetes patients showed nonstatistically significant results for all-cause mortality and reported point estimates in the range of 0.91 to 0.93.^43,44,55^

##### Effect of Aspirin on MI/Coronary Events by Diabetes Status

Seven trials reported total MI/coronary events,43,44,53,55,58,62,63 with the three trials conducted exclusively in patients with diabetes further reporting fatal and/or nonfatal MI/coronary events (Table 15).43,44,55 Of all the trials, only HOT showed a statistically significant reduction in total MI/coronary events among those without diabetes.62 The remaining six trials reported nonstatistically significant results for both those with and without diabetes for MI/coronary events.43,44,53,55,58,63 Only PHS performed a test for interaction, showing no differential effect by diabetes status (p=0.22).53 The three trials that only recruited diabetes patients showed nonstatistically significant results for total MI, with two trials reporting RR point estimates of 0.85 and 0.87. The RR point estimate in the remaining trial was 1.10.^44^ These three trials showed similar nonstatistically significant differences in fatal and nonfatal MI/coronary events.43,44,55

##### Effect of Aspirin on Stroke by Diabetes Status

For total stroke, five trials showed nonstatistically significant results in participants with diabetes, with all point estimates being less than 1 and ranging from 0.74 in POPADAD to 0.91 in HOT, except ETDRS, which reported a nonstatistically significant RR point estimate of 1.18 (Table 16).43,44,55,62,63 WHS, on the other hand, reported a significant reduction in total stroke in patients with diabetes (RR, 0.46 [95% CI, 0.25 to 0.85]).58 For fatal and nonfatal stroke, all three trials that were conducted exclusively in diabetes patients showed nonsignificant results, with inconsistency across studies for nonfatal and fatal events. This result was likely due the fact that fatal stroke events were rare and the populations were heterogeneous. ETDRS showed a nonstatistically significant RR point estimate of 1.00 for fatal stroke and 1.26 for nonfatal stroke, while JPAD reported an RR of 0.20 for fatal stroke and 1.01 for nonfatal stroke.43,55 POPADAD reported an RR of 0.89 for fatal stroke and 0.71 for nonfatal stroke, with all results being statistically insignificant.44 Three trials provided results for diabetes patients by stroke subtype.43,55,58 WHS showed a statistically significant reduction in ischemic stroke among those with diabetes, but not those without (without diabetes: adjRR, 0.42 [95% CI, 0.22 to 0.82]). JPAD reported nonfatal ischemic strokes and found no difference among treatment groups. Likewise, POPADAD showed no difference in fatal ischemic strokes between treatment groups.43,44

##### Effect of Aspirin on Composite Outcomes by Diabetes Status

Seven trials contributed at least one composite outcome analyzed by diabetes status (Table 14).43-45,55,58,62,63 All trials except JPAD and PPP reported nonstatistically significant findings in patients with diabetes, regardless of composite reported, without consistency in trends across studies. Five trials44,55,58,62,63 showed fatal composite outcomes for the diabetes subgroup, with only two trials reporting RRs greater than 1.^44,63^ Two trials reported a nonfatal CVD composite with conflicting, nonstatistically significant results—JPAD favoring the control and POPADAD favoring aspirin.43,44 The ATT IPD meta-analysis looked at a composite of serious vascular events (defined as MI, stroke, or death from vascular causes, including sudden death, pulmonary embolism, and hemorrhage) and found a nonstatistically significant effect of aspirin in patients with diabetes (ratio of yearly event rates, with diabetes: 0.88 [95% CI, 0.67 to 1.15]; without diabetes: 0.87 [95% CI, 0.79 to 0.96]), but heterogeneity testing revealed no significant heterogeneity between any prespecified subgroups, including diabetes (global heterogeneity=0.7).33

### Smoking

#### Trial Characteristics

Two trials reported a priori subgroup analyses for smoking status.43,58 One additional trial53 did not specify whether analysis was a priori or post hoc. PHS and WHS categorized smokers as never, past, or current. JPAD categorized individuals as current/past or nonsmoker.43,53,58

#### Results by Outcome

##### Effect of Aspirin on All-cause Mortality by Smoking Status

None of the trials reported smoking-specific results for all-cause mortality.

##### Effect of Aspirin on MI/Coronary Events or Stroke by Smoking Status

PHS reported that smoking status had no consistent effect on MI/coronary events (p=0.99) and cigarette smoking did not modify the effect of aspirin on stroke (p-value not reported).53 WHS showed a trend of lower RR point estimates in past or never smokers compared to current smokers for total MI, total stroke, and ischemic stroke, with statistically significant findings in the never smokers for all of these outcomes except total MI.

##### Effect of Aspirin on Composite Outcomes by Smoking Status

PHS reported that cigarette smoking modified the effect of aspirin for a cardiovascular mortality composite (defined as acute MI, other IHD, sudden death, stroke [ischemic, hemorrhagic, unknown], other [hypertensive heart disease, acute and subacute endocarditis, other diseases of endocardium, cardiomyopathy, heart failure ,complications from heart disease, other cerebrovascular disease, atherosclerosis, aortic aneurysm]) (p=0.05). Despite this result, neither the observed reduction in risk among nonsmokers (p=0.18) nor the increased risk among current smokers (p=0.20) were significant.

JPAD reported that the CIs overlapped for current/past smokers and nonsmokers for its primary composite outcome (composed of sudden death; death from coronary, cerebrovascular, and aortic causes; nonfatal acute MI; unstable angina; newly developed exertional angina; nonfatal ischemic and hemorrhagic stroke; TIA; or nonfatal aortic and peripheral vascular disease) in current or past smokers (RR, 0.73 [95% CI, 0.47 to 1.14]) and nonsmokers (RR, 0.83 [95% CI, 0.53 to 1.31]).43

WHS showed a trend of lower RR point estimates in past or never smokers compared to current smokers for the primary composite outcome of major cardiovascular events (nonfatal MI, nonfatal stroke, or CVD mortality) (RR, 0.80 [95% CI, 0.69 to 0.93]).58

### Race/Ethnicity

None of the trials reported outcomes by race/ethnicity.

### 10-Year Cardiovascular Risk

#### Trial Characteristics

Two trials specifically reported outcomes by 10-year risk score for CHD or CVD: HOT and WHS.58,64 TPT specifically recruited male participants in the top 20 percent risk stratum, based on the Northwick Park Heart Study algorithm, or those in the top 25 percent risk stratum if from regions with high IHD rates.54 HOT reported outcomes by 10-year CVD risk score of 15 to 20 percent and greater than 20 percent based on established risk factors (age, sex, smoking, diabetes, high cholesterol, history of premature CVD, and history of cardiovascular or renal disease) and risk groups deemed low-, medium-, high-, and very high-risk per the 1999 WHO/International Society of Hypertension (ISH) guidelines. Half of the trial participants were categorized as medium-risk and the other half were categorized as either high- or very high-risk.64 WHS performed an a priori subgroup analysis using 10-year CHD risk based on Framingham risk score with three risk categories (<5.0%, 5.0% to 9.9%, and ≥10.0%).58 Neither HOT nor WHS clearly reported interaction testing.58,64,69

Additionally, JPAD reported results of analyses stratified by cardiovascular risk, which was defined by age and the presence of risk factors in addition to diabetes. Specifically, high-risk was defined as men older than age 50 years and women older than age 60 years with one or more of the following additional risk factors: current smoking, hypertension, dyslipidemia, family history of coronary artery disease, or proteinuria. More than 70% of the population was classified as high-risk, with the most common risk factor being hypertension (prevalence of about 70%). Authors did not specify whether analyses were prespecified or post hoc, but interaction testing was performed.

#### Results by Outcome

##### Effect of Aspirin on All-Cause Mortality by 10-Year CVD Risk

None of the trials reported 10-year CVD risk-specific results for all-cause mortality.

##### Effect of Aspirin on MI/Coronary Events or Stroke by 10-Year CVD Risk

HOT, in a subgroup analysis, reported that that only participants with greater than 20 percent 10-year CVD risk had a statistically significant reduction in total MI (RR, 0.64 [95% CI, 0.45 to 0.91]), but not those in the medium-risk category (15% to 20% risk).64 WHS's subgroup analysis showed there was no difference between the aspirin and control group for total MI/coronary events and total ischemic stroke in any of the three CHD risk categories, but did show that participants with a 10 percent or greater 10-year CVD risk had a statistically significant reduction in total stroke (RR, 0.54 [95% CI, 0.30 to 0.98]).58 TPT, the one trial conducted exclusively in high-risk men, showed a statistically significant reduction in nonfatal MI/coronary events.54

##### Effect of Aspirin on Composite Outcomes by 10-Year CVD Risk

HOT showed that there was only a statistically significant reduction in its primary CVD composite (all MI/coronary events, all stroke, or other CVD deaths) seen in the high- to very high-risk CVD category patients (>20% risk) (RR, 0.78 [95% CI, 0.65 to 0.94]), but not in the medium-risk category (15% to 20% risk) (RR, 1.00 [95% CI, 0.77 to 1.30]).64 Additionally, WHS reported that there was no difference between the aspirin and control group in any of the three CHD risk categories for its primary composite outcome of CVD events (nonfatal MI/coronary events, nonfatal stroke, or CVD death).58 Conversely, TPT showed a reduction in a composite outcome of nonfatal MI/coronary events combined with nonfatal stroke (RR, 0.64 [95% CI, 0.47 to 0.88]).54 JPAD showed no statistically significant benefit of aspirin for a broadly defined primary outcome of any atherosclerotic event in either the high-risk (adjHR, 0.78 [95% CI, 0.55 to 1.11]) or low-risk (adjHR, 0.53 [95% CI, 0.23 to 1.21]) group (p=0.26 for interaction).

While the ATT IPD meta-analysis showed a statistically significant reduction in total serious vascular events only among patients in the less than 5 percent 5-year CHD risk group (ratio of yearly event rates: 0.87 [95% CI, 0.76 to 0.99] in <2.5% risk group; 0.82 [95% CI, 0.68 to 0.98] in 2.5% to 5% risk group), the highest risk group was so small that estimates were unreliable, and testing for heterogeneity revealed no difference in effect based on risk strata (p=0.3).33

### Decreased ABI

#### Trial Characteristics

POPADAD and AAA specifically recruited participants with reduced ABI.44,45 POPADAD recruited men and women age 40 years or younger with type 1 or 2 diabetes and asymptomatic peripheral artery disease, as detected by an ABI of less than or equal to 0.99.^44^ AAA recruited men and women ages 50 to 75 years with no history of MI, stroke, angina, or peripheral artery disease who also had an ABI of less than or equal to 0.95, as determined by screening by trialists.45 Only one trial reported CVD mortality,44 while both trials reported a primary composite outcome by ABI strata (for AAA: ≤0.95, ≤0.90, ≤0.85, and ≤0.80; for POPADAD: ≤0.90 and 0.91 to 0.99).44,45 In AAA, this analysis was conducted post hoc. It is unclear if the analysis was post hoc or a priori in POPADAD. AAA reported no interaction testing and POPADAD reported testing for interactions.45

#### Results by Outcome

##### Effect of Aspirin on All-Cause Mortality by Decreased ABI

None of the trials reported ABI-specific results for all-cause mortality.

##### Effect of Aspirin on MI/Coronary Events or Stroke by Decreased ABI

None of the trials reported ABI-specific results for stroke or MI/coronary events.

##### Effect of Aspirin on Composite Outcome by Decreased ABI

AAA showed no statistically significant difference in its primary outcome (defined as initial [earliest] fatal or nonfatal coronary event or stroke or revascularization) for any of the four ABI groups.45 Similarly, POPADAD showed no statistically significant difference in the trial's primary composite outcome (defined as death from CHD or stroke, nonfatal MI/coronary events or stroke, or above ankle amputation for critical limb ischemia) for either of the two ABI groups and found no significant interaction (p=0.089). POPADAD additionally reported CVD mortality (defined as death from CHD or stroke) and found no heterogeneity of treatment effect in ABI subgroups (p=0.17).44

### Elevated Blood Pressure

#### Trial Characteristics

One trial64 specifically recruited patients with hypertension and reported outcomes by blood pressure level. Four additional trials reported subgroup analyses by either hypertension status or blood pressure level.53,58,65,66 JPAD reported subgroup analyses by hypertension status and WHS reported a priori subgroup analyses both by hypertension status and blood pressure level.58,65 While TPT reported outcomes by SBP, we were not able to determine if the analysis was prespecified or post hoc.66

#### Results by Outcome

##### Effect of Aspirin on All-Cause Mortality by Blood Pressure Level

None of the trials reported all-cause mortality by blood pressure level.

##### Effect of Aspirin on MI/Coronary Events or Stroke by Blood Pressure Level

Four trials reported subgroup data for MI/coronary events and/or stroke by hypertension status. HOT found that total MI/coronary events were reduced in its subgroup analysis, with a greater benefit seen among the higher SBP and DBP levels; statistical significance was reached in the two higher SBP groups and the 104 to l07 mm Hg DBP group. These were all unadjusted RRs, so confounders, including medications used and age, could have contributed to these findings.64

PHS reported no significant interaction between SBP or DBP level and aspirin treatment for total MI/coronary events (p=0.88 for SBP and p=0.48 for DBP). Additionally, TPT reported a statistically significant interaction between SBP levels (<130, 130 to 145, and >145 mm Hg) and total stroke (p=0.006). Lower SBP levels were associated with a greater RR reduction when adjusting for age, smoking history, family history of premature CVD, BMI, total cholesterol, plasma fibrinogen, and plasma factor VII.66 Similarly, WHS reported a statistically significant reduction in total stroke and ischemic stroke after adjusting for age and treatment group in the hypertensive group, but not the normotensive group (total stroke in hypertensive group: adjRR, 0.76 [95% CI, 0.59 to 0.98]; ischemic stroke in hypertensive group: adjRR, 0.73 [95% CI, 0.56 to 0.96]). This trial, however, did not report a statistically significant reduction in total MI.58

##### Effect of Aspirin on Composite Outcome by Blood Pressure Level

HOT found no statistically significant difference in major CVD events (defined as fatal and nonfatal MI/coronary events, all stroke, or other CVD death) in any of the SBP or DBP target groups, except the highest DBP level (≥107 mm Hg), but there appears to be a trend toward a lower RR with higher blood pressure levels (p-value not reported). Similarly, JPAD showed no statistically significant findings when comparing the hypertensive and normotensive subgroups for the primary composite outcome (defined as sudden death; death from coronary, cerebrovascular, and aortic causes; nonfatal MI; unstable angina; newly developed angina; nonfatal ischemic and hemorrhagic stroke; TIA; or nonfatal aortic and peripheral vascular disease). It does appear that there is a trend toward a reduction in total stroke events among the aspirin group compared to the control group, but it was not statistically significant in the hypertensive group (3.3% vs. 5.2%; p-value not significant).65

Further, PHS reported that blood pressure levels had no consistent effect on CVD-related mortality (data not reported). Likewise, WHS reported no statistically significant reduction in its primary composite outcome (defined as nonfatal MI, nonfatal stroke, or CVD death).

### Elevated Lipids

#### Trial Characteristics

Four trials reported subgroup analyses by total cholesterol levels or by the presence or absence of dyslipidemia (defined as total cholesterol ≥240 mg/dL in WHS; not defined in JPAD).43,53,58,66 Two of these trials performed subgroup analyses a priori,43,58 while the other two trials did not specify the timing of their analysis.53,66 Two trials reported interaction testing or statistical testing for trends.53,66

#### Results by Outcome

##### Results of Aspirin on All-Cause Mortality by Lipid Level

None of the trials reported all-cause mortality by lipid levels.

##### Results of Aspirin on MI/Coronary Events or Stroke by Lipid Level

PHS showed a statistically significant trend with greater aspirin benefit in total MI/coronary events seen in the lowest total cholesterol quartile (<159 mg/dL: adjRR, 0.23; p=0.04 for trend).53 The same trend was reported in TPT for total stroke, with a statistically significant interaction with greater aspirin benefit observed in the lowest total cholesterol tertile (<5.9 mmol/L: adjRR, 0.20; p for trend=0.036).66 WHS, on the other hand, reported a consistent pattern of greater aspirin benefit that reached statistical significance in the hyperlipidemia group, but not the normal lipids group, for total stroke and total ischemic stroke.58

##### Results of Aspirin on Composite Outcome by Lipid Level

JPAD reported no statistically significant difference in its primary composite outcome (defined as sudden death; death from coronary, cerebrovascular, and aortic causes; nonfatal MI; unstable angina; newly developed angina; nonfatal ischemic and hemorrhagic stroke; TIA; or nonfatal aortic and peripheral vascular disease) in the aspirin and control groups for those with and without dyslipidemia.43 Following the same trend reported for total stroke and total ischemic stroke, WHS reported a greater aspirin benefit (statistically significant in the hyperlipidemia group, but not the normal lipid group) for its primary composite outcome.58

## KQ 1b Does the Effect Vary by Dose, Formulation, or Duration of Aspirin Use?

### Summary of Results

Trials using aspirin doses of 100 mg/day or less achieved a similar and statistically significant reduction in nonfatal MI/coronary events, mimicking the trend we observed when pooling trials of all doses. Additionally, when the trials using doses of 100 mg/day are pooled, a statistically significant reduction in nonfatal and total stroke is observed that is not apparent when trials with all doses are pooled. No conclusions can be made regarding treatment duration and formulation, however, which reflects the heterogeneity of the trials’ populations and designs. Based on time-to-event data, any CVD-related benefit likely begins within the first 5 years of treatment, without any consistent data to support that benefit diminishes over time.

### Dose

Seven trials administered aspirin at a dosage of 100 mg or less daily or every other day;43-45,54,56,58,59 one trial used 325 mg every other day,53 one used 500 mg daily,57 and one used 650 mg daily.55 The largest trials, WHS and PHS, used every other day dosing.

After stratifying forest plots by effect size (not shown), we examined whether any of our four primary outcomes of interest appeared to show an effect size difference for trials with the highest or lowest aspirin doses. Compared to our primary analysis using all trials, we found similar results when we pooled studies using doses of less than 325 mg daily for the outcomes of fatal CVD events, nonfatal stroke, and nonfatal MI/coronary events, which confirms the primary finding that nonfatal MI/coronary events is the only outcome for which there was a statistically significant reduction with aspirin (Table 17). For the outcome of all-cause mortality, despite a similar point estimate, results became nonsignificant when we pooled only the trials using doses of less than 325 mg/day. We found similar results to our primary analysis using all doses when we pooled only trials using 100 mg or less daily, except nonfatal stroke, which became statistically significantly beneficial in the aspirin group (RR, 0.82 [95% CI, 0.71 to 0.95]; I^2^=0%). Again, all-cause mortality became nonsignificant after pooling only trials using doses of 100 mg or less (Table 18).

Table 17 Sensitivity Analysis Results: All Included Trials^*^ and Trials With Doses <325 mg^†^

Primary Outcome | k | Mantel-Haenszel Fixed Effects RR (95% CI) | I^2^ (%) | Peto OR (95% CI) | I^2^ (%)
Death from MI/coronary events, stroke, other CVD | 10 | 0.94 (0.85 to 1.03) | 16.4 | 0.93 (0.84 to 1.03) | 31.3
Death from MI/coronary events, stroke, other CVD | 8 | 0.96 (0.84 to 1.09) | 30.0 | 0.94 (0.83 to 1.07) | 43.1
Nonfatal stroke | 9 | 0.94 (0.84 to 1.06) | 32.3 | 0.94 (0.84 to 1.06) | 31.8
Nonfatal stroke | 7 | 0.89 (0.78 to 1.01) | 23.2 | 0.89 (0.78 to 1.02) | 23.1
Nonfatal MI/coronary events | 9 | 0.80 (0.72 to 0.88) | 62.8 | 0.79 (0.71 to 0.88) | 61.4
Nonfatal MI/coronary events | 8 | 0.78 (0.70 to 0.87) | 65.5 | 0.78 (0.70 to 0.86) | 64.0
All-cause mortality | 10 | 0.94 (0.88 to 0.99) | 0 | 0.93 (0.88 to 0.99) | 0
All-cause mortality | 8 | 0.94 (0.88 to 1.01) | 0 | 0.94 (0.88 to 1.01) | 0

* Top row for each of the primary outcomes.

† Bottom row for each of the primary outcomes.

Abbreviations: CI = confidence interval; CVD = cardiovascular disease; MI = myocardial infarction; OR = odds ratio; RR = relative risk.

Table 18 Sensitivity Analysis Results: All Included Trials^*^ and Trials With Doses ≤100 mg^†^

Primary Outcome | k | Mantel-Haenszel Fixed Effects RR (95% CI) | I^2^ (%) | Peto OR (95% CI) | I^2^ (%)
Death from MI/coronary events, stroke, other CVD | 10 | 0.94 (0.85 to 1.03) | 16.4 | 0.93 (0.84 to 1.03) | 31.3
Death from MI/coronary events, stroke, other CVD | 7 | 0.96 (0.84 to 1.11) | 39.5 | 0.95 (0.83 to 1.09) | 51.1
Nonfatal stroke | 9 | 0.94 (0.84 to 1.06) | 32.3 | 0.94 (0.84 to 1.06) | 31.8
Nonfatal stroke | 6 | 0.82 (0.71 to 0.95) | 0 | 0.82 (0.71 to 0.95) | 0
Nonfatal MI/coronary events | 9 | 0.80 (0.72 to 0.88) | 62.8 | 0.79 (0.71 to 0.88) | 61.4
Nonfatal MI/coronary events | 7 | 0.85 (0.75 to 0.97) | 52.1 | 0.85 (0.74 to 0.96) | 52.5
All-cause mortality | 10 | 0.94 (0.88 to 0.99) | 0 | 0.93 (0.88 to 0.99) | 0
All-cause mortality | 7 | 0.94 (0.88 to 1.01) | 0 | 0.94 (0.87 to 1.01) | 0

* Top row for each of the primary outcomes.

† Bottom row for each of the primary outcomes.

Abbreviations: CI = confidence interval; CVD = cardiovascular disease; MI = myocardial infarction; OR = odds ratio; RR = relative risk.

We performed other sensitivity analyses for the outcome of total stroke (Table 7). Pooling studies with aspirin doses of 100 mg or less daily revealed a statistically significant reduction in total stroke events (k=7; RR, 0.85 [95% CI, 0.76 to 0.96]; I^2^=0%) that was not apparent when we combined high-dose trials (k=3; RR, 1.19 [95% CI, 1.00 to 1.42]; I^2^=0%). These results were similar in a sensitivity analysis using the Peto OR equation. While this may reflect a lower risk of hemorrhagic stroke with lower doses of aspirin, hemorrhagic stroke events were rare in the seven trials reporting this outcome (Table 19). As such, we could not confirm this hypothesis.

Table 19 Harms of Aspirin for the Primary Prevention of Cardiovascular Events in Included Trials

| | BMD, 1988^57^ | PHS I, 1989^53^ | HOT, 1998^56^ | TPT, 1998^54^ | PPP, 2001^59^ | WHS, 2005^58^ | JPAD, 2008^43^ | POPADAD, 2008^44^ | AAA, 2010^45^
Quality | | Fair | Good | Fair | Fair | Fair | Good | Fair | Fair | Fair
Mean Followup | | 6 years | 5 years | 3.8 years | 6.8 years^*^ | 3.6 years | 10.1 years | 4.4 years^*^ | 6.7 years^*^ | 8.2 years
Major GI Bleeding^†^ | IG events/n (%) | 3/3,429 (0.1%)^‡^ | 49/11,037 (0.4%)^‡^ | 77/9,399 (0.8%)^‡^ | 6/1,268 (0.5%)^‡^ | NR | 129/19,934 (0.6%)^‡^ | 4/1,262 (0.3)^‡^ | NR | 9/1,675 (0.5%)^‡^
Major GI Bleeding^†^ | CG events/n (%) | 3/1,710 (0.2%)^‡^ | 28/11,034 (0.3%)^‡^ | 37/9,391 (0.4%)^‡^ | 2/1,272 (0.2%)^‡^ | NR | 94/19,942 (0.5%)^‡^ | 0/1,277 (0.0)^‡^ | NR | 8/1,675 (0.5%)^‡^
Major GI Bleeding^†^ | IG vs. CG | RR (95% CI): 0.50 (0.10 to 2.47)^‡^ | RR (95% CI): 1.75 (1.10 to 2.78)^‡^ | RR (95% CI): 2.08 (1.41 to 3.07)^‡^ | RR (95% CI): 3.01 (0.61 to 14.88)^‡^ | NR | RR (95% CI): 1.37 (1.05 to 1.79)^‡^ | RR (95% CI): 8.10 (0.43 to 152.96)^‡^ | NR | RR (95% CI): 1.13 (0.44 to 2.91)^‡^
Fatal GI Bleeding | IG events/n (%) | 3/3,429 (0.1%)^‡^ | 1/11,037 (0.01%) | 5/9,399 (0.05%) | 0/1,286 (0%) | NR | 2/19,934 (0.01%) | NR | NR | NR
Fatal GI Bleeding | CG events/n (%) | 3/1,710 (0.2%)^‡^ | 0/11,034 (0.0%) | 3/9,391 (0.03%) | 1/1,272 (0.08%) | NR | 3/19,942 (0.02%) | NR | NR | NR
Fatal GI Bleeding | IG vs. CG | NR | NR | NR | NR | NR | NR | NR | NR | NR
Total Hemorrhagic Stroke | IG events/n (%) | NR | 23/11,037 (0.2%) | 14/9,399 (0.1%)^‡^ | 2/1,268 (0.2%) | 2/2,226 (0.1%) | 51/19,934 (0.2%) | 6/1,262 (0.5%)^‡^ | NR | 5/1,675 (0.3%)^‡^
Total Hemorrhagic Stroke | CG events/n (%) | NR | 12/11,034 (0.1%) | 15/9,391 (0.2%)^‡^ | 0/1,272 (0.0%) | 3/2,269 (0.1%) | 41/19,942 (0.2%) | 7/1,277 (0.5%)^‡^ | NR | 4/1,675 (0.2%)^‡^
Total Hemorrhagic Stroke | IG vs. CG | NR | AdjRR^§^ (95% CI): 2.14 (0.96 to 4.77), p=0.06 | RR (95% CI): 0.93 (0.45 to 1.93)^‡^ | RR (95% CI): 4.01 (0.18 to 88.90)^‡^ | RR (95% CI): 0.68 (0.11 to 4.06)^‡^ | AdjRR║ (95% CI): 1.24 (0.82 to 1.87), p=0.31 | RR (95% CI): 0.87 (0.29 to 2.57)^‡^ | NR | RR (95% CI): 1.25 (0.34 to 4.65)^‡^
Fatal Hemorrhagic Stroke | IG events/n (%) | 10/3,429 (0.3%) | 7/11,037 (0.1%)^‡^ | 2/9,399 (0.02%) | NR | NR | NR | 1/1,262 (0.1%) | 2/638 (0.3%) | 3/1,675 (0.2%)
Fatal Hemorrhagic Stroke | CG events/n (%) | 4/1,710 (0.2%) | 2/11,034 (0.0%)^‡^ | 3/9,391 (0.03%) | NR | NR | NR | 4/1,277 (0.3%) | 3/638 (0.5%) | 3/1,675 (0.2%)
Fatal Hemorrhagic Stroke | IG vs. CG | RR (95% CI): 1.25 (0.39 to 3.97)^‡^ | RR (95% CI): 3.50 (0.73 to 16.84)^‡^, p=NS | RR (95% CI): 0.67 (0.11 to 3.99)^‡^ | NR | NR | NR | RR (95% CI): 0.25 (0.03 to 2.26)^‡^ | RR (95% CI): 0.67 (0.11 to 3.98)^‡^ | RR (95% CI): 1.00 (0.20 to 4.95)^‡^
Nonfatal Hemorrhagic Stroke | IG events/n (%) | 3/3,429 (0.1%) | 16/11,037 (0.1%)^‡^ | 12/9,399 (0.1%) | NR | NR | NR | 5/1,262 (0.4%) | NR | 2/1,675 (0.1%)
Nonfatal Hemorrhagic Stroke | CG events/n (%) | 2/1,710 (0.1%) | 10/11,034 (0.1%)^‡^ | 12/9,391 (0.1%) | NR | NR | NR | 3/1,277 (0.2%) | NR | 1/1,675 (0.1%)
Nonfatal Hemorrhagic Stroke | IG vs. CG | RR (95% CI): 0.75 (0.13 to 4.47)^‡^, p=NS | RR (95% CI): 1.60 (0.73 to 3.52)^‡^ | RR (95% CI): 1.00 (0.45 to 2.22)^‡^ | NR | NR | NR | HR (95% CI): 1.68 (0.40 to 7.04), p=0.48 | NR | RR (95% CI): 2.00 (0.18 to 22.04)^‡^
Intracranial Bleeding | IG events/n (%) | NR | NR | NR | 1/1,268 (0.1%)^‡,¶^ | 2/2,226 (0.1%)^#^ | NR | 2/1,262 (0.2%)^‡,**^ | NR | 6/1,675 (0.4%)^‡,††^
Intracranial Bleeding | CG events/n (%) | NR | NR | NR | 2/1,272 (0.2%)^‡,¶^ | 0/2,269 (0.0%)^#^ | NR | 0/1,277 (0.0%)^‡,**^ | NR | 3/1,675 (0.2%)^‡,††^
Intracranial Bleeding | IG vs. CG | NR | NR | NR | RR (95% CI): 0.50 (0.05 to 5.52)^‡,¶^ | RR (95% CI): 4.08 (0.18 to 90.37)^‡,#^ | NR | RR (95% CI): 4.05 (0.18 to 89.67)^‡^ | NR | RR (95% CI): 2.00 (0.50 to 7.98)^‡^

* Median.

† Major GI bleeding defined as GI bleeding requiring transfusion, hospitalization, or leading to death. If a trial reported transfusions and death from GI bleeding separately, we added these events together. If a trial only reported deaths from GI bleeding, we used that number for major GI bleeding. If a trial reported GI bleeding without any mention of severity, we did not include it.

‡ Calculated.

§ RR adjusted for age and assignment to beta carotene.

║ RR adjusted for age and assignment to vitamin E.

¶ Defined as subarachnoid stroke/subdural hemorrhage.

# Defined as intracranial (not parenchymal).

** Defined as chronic subdural hematoma.

†† Defined as fatal or nonfatal subarachanoid/subdural hemorrhage.

Abbreviations: AAA = Aspiring for Asymptomatic Atherosclerosis Trial; Adj = adjusted; BMD = British Medical Doctor's Study; CG = control group; CI = confidence interval; HOT = Hypertension Optimal Treatment Study; HR = hazard ratio; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes Study; n = population; NR = not reported; NS = not significant; PHS = Physician's Health Study; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; PPP = Primary Prevention Project; RR = relative risk; TPT = Thrombosis Prevention Trial; WHS = Women's Health Study.

### Formulation

Half of the studies specified tablet formulation; two trials used enteric coated45,59 and three trials used other or unspecified formulations.43,44,56 Qualitatively, there does not appear to be any association between formulation and aspirin effect for any outcome analyzed.

### Duration

Time-to-event data were available from eight trials that reported varying conclusions regarding minimum time-to-benefit and benefit duration with aspirin use for various select outcomes. Overall, available data suggest that any CVD benefit from aspirin begins within the first 1 to 5 years, without a clear upper time limit to benefit due to inconsistent results and relatively short trial durations; half of these eight trials had durations of 5 years or less.43-45,54,55,58,60,61

Four trials reported statistically significant HRs for varying CVD outcomes, with divergence of Kaplan-Meier curves beginning at 1 to 2 years.54,56,58,59 In WHS, the effect appeared to continue through years 4 to 5, with the slope of the curves then remaining constant and parallel through trial end at 10 years.58 Three trials showed an increasing beneficial effect over time through trial end: HOT (4 years), PPP (4 years), and TPT (8 years). Four trials43-45,55 showed no statistically significant differences in HRs in their time-to-event analyses and two trials53,57 did not report time-to-event data.

HOT published Kaplan-Meier curves for total MI showing a statistically significant divergence of aspirin and control curves for men (p=0.001), patients younger than age 65 years (p=0.02), and patients age 65 years or older (p=0.04). These results suggest that benefit begins with treatment of 1 year or less and continues until study end at approximately 4 years.60 PPP reported Kaplan-Meier curves for the trial's composite CVD outcome, showing a statistically significant benefit for patients without diabetes in the aspirin group compared to the nonaspirin group (p=0.03), with separation in the curves beginning between 1 and 2 years, with no suggestion that the benefit diminishes over time.59 TPT showed cumulative incidence curves for all IHD, fatal IHD, and nonfatal IHD in the aspirin and placebo groups, with total and nonfatal IHD curves showing divergence after 1 year.54 WHS showed cumulative incidence curves for ischemic and total stroke, with statistically significant divergence for ischemic stroke (p=0.009) and total stroke (p=0.04) starting at approximately 2 years of this 10-year trial, while the curves for MI and the primary CVD composite showed no difference in the aspirin and control groups.58

AAA provided Kaplan-Meier curves for its primary composite CVD outcome showing similar aspirin and control curves (HR, 1.03 [95% CI, 0.84 to 1.27]).45 JPAD's time-to-event data for its composite CVD outcome showed no statistically significant difference in the aspirin and control groups (HR, 0.80 [95% CI, 0.58 to 1.10]).43 POPADAD provided Kaplan-Meier curves for the outcomes of CVD death, all-cause mortality, and the trials’ composite CVD outcome and showed very similar curves for the aspirin and control groups, with nonstatistically significant HRs confirming no difference over 8 years.44 ETDRS reported that its time-dependent analysis suggested that the HR for MI benefit with aspirin declined with time; however, data were not shown for adjusted HRs, although this appears to be true for unadjusted RRs reported for MI, composite CVD events, and total mortality beyond 5 years. The authors postulated that this could be attributed to declines in adherence over time, delay rather than prevention of events, or random chance.55

Qualitatively, stratifying forest plots for our primary outcomes by followup time (equivalent to treatment duration in the trials) does not appear to suggest an association between treatment duration and aspirin effect.

## KQ 2 Does Regular Aspirin Use Increase GI Bleeding, Hemorrhagic Stroke, or Other Serious Harms?

### Summary of Results

The nine RCTs addressing the harms of aspirin in primary prevention populations reported harms variably and reported different outcomes. Additionally, some trials did not define bleeding type or severity and no trial reported ascertainment methods.43-45,53,54,56-59 Qualitatively, it appears that aspirin was associated with an increased risk of total hemorrhagic stroke in the seven trials reporting this outcome, with RRs ranging from 0.68 to 4.01 (Table 19). The incidence of this outcome was so rare (≤0.5%), however, that precise estimates are not possible. Major GI bleeding reported in the seven trials was rare (≤0.8%), and RRs were greater than 1 in all but one trial, ranging from 1.13 to 8.10. The ATT IPD meta-analysis showed a 50 percent increase in major GI and other extracranial bleeding in patients taking aspirin (RR, 1.54 [95% CI, 1.30 to 1.82]).33

### Study Characteristics

Nine of the 10 trials that addressed the effectiveness of aspirin in primary prevention also addressed the harms of aspirin in primary prevention populations.43-45,53,54,56-59 These nine trials (two good-quality and seven fair-quality) are discussed at length in KQ 1. Assessing harms in many trials was difficult as they did not define bleeding events or bleeding severity, and none of the trials reported ascertainment methods for these bleeding harms, although they were presumably gathered by participant questionnaire and/or medical records.

### Results by Outcome

#### Hemorrhagic Stroke

Total hemorrhagic stroke events were far less common than ischemic strokes. Seven trials reported this outcome, with incidence rates ranging from 0 over 6.8 years in TPT to 0.5% over 4.4 years in JPAD in the control groups (Table 19).45,53,54,56-59 With these rare events, all studies showed nonstatistically significant results and mixed results, with RR point estimates ranging from 0.68 in PPP to 5.02 in TPT and wide CIs (Figure 16, Table 19).54,59 Similarly, fatal hemorrhagic stroke events were rare, and the six trials reported mixed results, with RRs ranging from 0.25 to 3.5, wide CIs, and no statistical significance (Figure 17, Table 19).43-45,53,56,57 Five RCTs reported nonfatal hemorrhagic stroke.43,45,53,56,57 Four out of the five trials reported a rare event rate of approximately 0.1 percent in both the aspirin and the control groups. RRs of nonfatal hemorrhagic stroke ranged from 0.75 to 2.00, with wide CIs (Figure 18, Table 19). The ATT IPD meta-analysis showed a nonstatistically significant trend of a higher incidence of hemorrhagic stroke in the aspirin group compared to the control group (RR, 1.32 [95% CI, 0.91 to 1.91]).33

Figure 16 Forest Plot of Total Hemorrhagic Stroke Events (Fatal and Nonfatal), Sorted by Length of Followup

Figure 16 displays a forest plot of studies reporting the Peto odds ratio for the intervention group versus the control group for total hemorrhagic stroke events. This figure is described further under KQ2 of the review.

Figure 17 Forest Plot of Fatal Hemorrhagic Stroke Events, Sorted by Length of Followup

Figure 17 displays a forest plot of studies reporting the Peto odds ratio for the intervention group versus the control group for fatal hemorrhagic stroke events. This figure is described further under KQ2 of the review.

Figure 18 Forest Plot of Nonfatal Hemorrhagic Stroke Events, Sorted by Length of Followup

Figure 18 displays a forest plot of studies reporting the Peto odds ratio for the intervention group versus the control group for nonfatal hemorrhagic stroke events. This figure is described further under KQ2 of the review.

#### Major GI Bleeding

For the purposes of this review, major GI bleeding was defined as any GI bleeding requiring hospitalization or blood transfusion or resulting in death. Seven trials reported major GI bleeding events, and these events were rare (<1%) in both the aspirin and control groups (Table 19).43,45,53,54,56-58 Three trials reported statistically significant increases in major GI bleeding events, with RRs ranging from 1.37 to 2.08,^53,56,58^ and three trials showed nonsignificant trends in the same direction (Figure 19).43,45,54 Only one trial showed a nonstatistically significant RR of less than 1, reporting more frequent major GI bleeding in the control group compared with the aspirin group (0.1% vs. 0.2%); this finding is likely due to the rarity of events rather than a true finding, as this was the trial with a higher aspirin dose (500 mg/day).57 The ATT IPD meta-analysis showed a 50 percent increase in major GI and other extracranial bleeding (RR, 1.54 [95% CI, 1.30 to 1.82]).33

Figure 19 Forest Plot of Major GI Bleeding, Sorted by Length of Followup

Figure 19 displays a forest plot of studies reporting the Peto odds ratio for the intervention group versus the control group for major GI bleeding. This figure is described further under KQ2 of the review.

#### Intracranial Bleeding

Four trials reported intracranial bleeding, which included subdural and/or subarachnoid bleeding, and again the events were rare (≤0.4% in aspirin and control groups) (Figure 20, Table 19).43,45,54,59 Three of four trials reported RRs greater than 1, ranging from 2.00 to 4.08;^43,45,59^ only one trial54 reported an RR of less than 1. The RRs reported in all four trials were nonsignificant.43,45,54,56,59

Figure 20 Forest Plot of Intracranial Bleeding, Sorted by Length of Followup

Figure 20 displays a forest plot of studies reporting the Peto odds ratio for the intervention group versus the control group for intracranial bleeding. This figure is described further under KQ2 of the review.

#### ARMD

Two trials reported ARMD as ascertained from participant self-report, confirmed by medical records after randomization.58,70 WHS reported two secondary endpoints of advanced ARMD (exudative neovascular ARMD combined with geographic atrophy) and ARMD with or without vision loss. Visually significant ARMD after adjustment for age and beta carotene use was similar in the aspirin and placebo groups (adjRR, 0.82 [95% CI, 0.64 to 1.06]). Advanced ARMD and ARMD with or without vision loss were similar in both groups (advanced ARMD: adjRR, 0.90 [95% CI, 0.53 to 1.52]; ARMD with or without vision loss: RR, 1.03 [95% CI, 0.88 to 1.21]). PHS reported no statistically significant difference in ARMD with or without visual loss in the aspirin versus placebo group (RR, 0.77 [95% CI, 0.54 to 1.11]) or with visual loss (RR, 0.78 [95% CI, 0.46 to 1.32]).70

## KQ 2a Does the Effect Vary Between a Priori Subgroups: Age, Sex, Smoking Status, Race/Ethnicity, 10-Year Cardiovascular Risk, Related Risk Conditions, GI Bleeding or Hemorrhagic Stroke Risk Factors, or Concomitant Medication Use?

### Summary of Results

Few trials reported GI bleeding or hemorrhagic stroke by subgroup. Because of the rare harm events in the entire populations studied, it is not possible to make conclusions regarding a possible differential harms profile among subpopulations. Only two trials reported ARMD, with subgroup analyses limiting any generalizable conclusions.

### Major GI Bleeding by Subgroup

#### Age

One trial reported major GI bleeding events by age subgroup (<65 or ≥65 years) without reporting statistical significance testing.60 For fatal bleeding events (GI combined with cerebral), the events were identical in the aspirin and control groups for patients younger than age 65 years (0.2 cases per 1,000 person-years). Events were similar in the aspirin and control groups for patients age 65 years or older (0.3 vs. 0.4 cases per 1,000 person-years). For nonfatal major bleeding requiring hospitalization (including GI, cerebral, and nasal sources), the trial reported more events in the aspirin group compared to the placebo group, and these results were similar in both age groups (3.0 vs. 1.7 cases per 1,000 person-years in patients younger than age 65 years; 4.3 vs. 2.6case per 1,000 person-years in patients age 65 years or older) (Table 8).60

#### Sex

Four trials conducted either exclusively in men or women53,57,58,66 and two trials including both men and women59,60 performed sex subgroup analyses for bleeding harms (Table 11). HOT reported fatal bleeding events (GI combined with cerebral) by sex, showing that fatal bleeding was similarly rare in men and women in the aspirin and control groups (men: 0.3 vs. 0.2 cases per 1,000 person-years, respectively; p=NS; women: 0.1 vs. 0.2 cases per 1,000 person-years, respectively; p=NS). Nonfatal major bleeding requiring hospitalization (including GI, cerebral, and nasal bleeding) was higher in the aspirin group compared to the control group in both men and women. These events were more frequent in men than women, although no statistical testing for sex-specific interaction was performed (men: 4.1 vs. 2.5 cases per 1,000 person-years in aspirin and control groups, respectively; p=0.010; women: 2.7 vs. 1.3 cases per 1,000 person-years in aspirin and control groups, respectively; p=0.006).60 PPP showed the same trend with major bleeding (not defined in the trial but reported to be predominantly GI bleeding) and reported that these events occurred more frequently in men than women. The authors, however, did not perform statistical testing for sex-specific interaction (men: OR, 3.85 [95% CI, 1.27 to 11.64]; women: OR, 4.63 [95% CI, 1.00 to 21.46]).59

The three trials that were conducted exclusively in men all reported that major GI bleeding events were rare (<1%), and TPT and PHS reported a higher bleeding risk in the aspirin group, although only PHS reached statistical significance (Table 11).53,57,66 BMD showed rare major GI bleeding events, with only three events in the aspirin and control groups, making these numbers unstable for conclusions (aspirin: 0.09%; control: 0.2%; RR, 0.50 [95% CI, 0.10 to 2.47]). TPT also showed more frequent, but rare, major GI bleeding events in the aspirin group compared to the control group (aspirin: 0.5%; control: 0.2%; RR, 3.01 [95% CI, 0.61 to 14.88]).66 PHS reported death from GI hemorrhage combined with bleeding requiring transfusion, with relatively rare events, but reaching statistical significance (aspirin: 0.4%; control: 0.2%; RR, 1.75 [95% CI, 1.10 to 2.78]).53 Similarly, the trial conducted in exclusively women reported slightly more deaths from GI hemorrhage and bleeding requiring transfusion in those taking aspirin, but with relatively rare events (aspirin: 0.6%; control: 0.5%; RR, 1.37 [95% CI, 1.05 to 1.79]).58

#### Diabetes

GI bleeding in patients with diabetes was variably reported in two trials that exclusively recruited this population.43,44 There were no subgroup analyses of GI bleeding in diabetes patients in other trials. JPAD reported severe bleeding requiring transfusion more commonly in the aspirin group compared with the control group, with wide CIs (0.3% vs. 0%; RR, 8.10 [95% CI, 0.43 to 152.96]) (Table 14).43 Conversely, POPADAD reported more GI bleeding without specifying severity in the control group, but the results were not significant (4.4% vs. 4.9%; OR, 0.90 [95% CI, 0.53 to 1.52]).44

#### Hypertension

Only HOT reported bleeding events relating to hypertensive subgroups based on SBP and DBP levels (SBP ≥180, 160 to <180, or <160 mm Hg; DBP ≥107, 104 to <107, or <104 mm Hg).64 This trial defined a “fatal and nonfatal major bleeding” composite outcome as fatal, life-threatening, disabling, or requiring hospitalization, but did not specify the source of the bleeding (GI, cerebral, nasal, or other). These fatal and nonfatal major bleeding events occurred in 1.0 to 1.8 percent of the aspirin group in all blood pressure levels, and there was no clear trend in RR related to degree of hypertension (range, 1.38 to 2.10).64

#### 10-Year CVD Risk

HOT reported its fatal and nonfatal major bleeding composite by 10-year CVD risk, based on a Framingham risk calculator from the 1999 WHO/ISH guidelines. Major bleeding events occurred in 1.1 percent of the 15 to 20 percent risk group taking aspirin and in 1.6 percent of the 20 percent or greater risk group taking aspirin (RR, 2.08 [95% CI, 1.29 to 3.35] vs. 1.45 [95% CI, 1.01 to 2.06], respectively).64 JPAD reported GI bleeding stratified by high- and low-risk groups, which were defined by age and the presence of risk factors in addition to diabetes; the severity of bleeding was not defined.71 There was no statistically significant difference in bleeding in the aspirin and no aspirin groups at either risk level; however, there were few events. GI bleeding occurred in 0.4 percent of the high-risk group taking aspirin and 0.3 percent of the low-risk group taking aspirin (RRs not reported).

#### Other Subgroups

No trials reported GI bleeding or other bleeding by smoking status, race/ethnicity, lipid status, or ABI.

### Hemorrhagic Stroke by Subgroup

#### Age

None of the trials reported hemorrhagic stroke events by age.

#### Sex

Three trials conducted exclusively in men reported hemorrhagic stroke, 53,54,57 as did one trial conducted in women;58 PPP performed a subanalysis of men and women, but the specification of the analysis is not reported (Table 20).61 All trials reported rare total hemorrhagic stroke events ranging from 0 to 0.2 percent in the aspirin groups. Because of rare events, all results were nonstatistically significant. The total hemorrhagic stroke OR/RR reported in men were 2.03, 2.14, and 4.01 in the PPP, PHS, and TPT trials, respectively.53,54,57 In women, the PPP subanalysis showed a total hemorrhagic stroke OR of 0.20 (95% CI, 0.01 to 4.26). In WHS, the adjRR was 1.24 (95% CI, 0.82 to 1.87).58

Table 20 Sex Subgroup: Total, Fatal, and Nonfatal Stroke by Stroke Type

Study Reference Quality Rating Mean Followup | Type of Analysis | Outcome | Men Events/Participants (%) RR (95% CI) | Women Events/Participants (%) RR (95% CI) | P-Value for Interaction
PPP Berger, 2006^58^ Fair 3.6 years | Specification unclear | All Ischemic Stroke | IG: 8/949 (0.8%) CG: 7/963 (0.7%) 1.16 (0.42 to 3.18)^**^ | IG: 6/1,277 (0.5%) CG: 9/1,306 (0.7%) 0.68 (0.24 to1.91)^**^ | NR
PPP Berger, 2006^58^ Fair 3.6 years | Specification unclear | Fatal Ischemic Stroke | NR | NR | NR
PPP Berger, 2006^58^ Fair 3.6 years | Specification unclear | Nonfatal Ischemic Stroke | NR | NR | NR
PPP Berger, 2006^58^ Fair 3.6 years | Specification unclear | All Hemorrhagic Stroke | IG: 2/949 (0.2%) CG: 1/963 (0.1%) 2.03 (0.18 to 22.34)^**^ | IG: 0/1,277 (0%) CG: 2/1,306 (0.2%) 0.20 (0.01 to 4.26)^**^ | NR
PPP Berger, 2006^58^ Fair 3.6 years | Specification unclear | Fatal Hemorrhagic Stroke | NR | NR | NR
PPP Berger, 2006^58^ Fair 3.6 years | Specification unclear | Nonfatal Hemorrhagic Stroke | NR | NR | NR
PPP Berger, 2006^58^ Fair 3.6 years | Specification unclear | Total Stroke of Unknown Type | NR | NR | NR
PPP Berger, 2006^58^ Fair 3.6 years | Specification unclear | Fatal Stroke of Unknown Type | NR | NR | NR
PPP Berger, 2006^58^ Fair 3.6 years | Specification unclear | Nonfatal Stroke of Unknown Type | NR | NR | NR
BMD Peto, 1988^57^ Fair 6 years | NA; trial in males only | All Ischemic Stroke | NR^*^ | NA | NA
BMD Peto, 1988^57^ Fair 6 years | NA; trial in males only | Fatal Ischemic Stroke | IG: 8/3,429 (0.2%) CG: 3/1,710 (0.2%) 1.33 (0.35 to 5.01)^**^ | NA | NA
BMD Peto, 1988^57^ Fair 6 years | NA; trial in males only | Nonfatal Ischemic Stroke | IG: 13/3,429 (0.4%)^†^ CG: 4/1,710 (0.2%)^†^ 1.62 (0.53 to 4.96)^**^ | NA | NA
BMD Peto, 1988^57^ Fair 6 years | NA; trial in males only | All Hemorrhagic Stroke | NR^†^ | NA | NA
BMD Peto, 1988^57^ Fair 6 years | NA; trial in males only | Fatal Hemorrhagic Stroke | IG: 10/3,429 (0.3%) CG: 4/1,710 (0.2%) 1.25 (0.39 to 3.97) | NA | NA
BMD Peto, 1988^57^ Fair 6 years | NA; trial in males only | Nonfatal Hemorrhagic Stroke | IG: 3/3,429 (0.1%)^‡^ CG: 2/1,710 (0.1%)^‡^ 0.75 (0.13 to 4.47) [c] | NA | NA
BMD Peto, 1988^57^ Fair 6 years | NA; trial in males only | Total Stroke of Unknown Type | IG: 57/3,429 (1.7%)^**^ CG: 26/1,710 (1.5%)^**^ 1.09 (0.69 to 1.73)^**^ | NA | NA
BMD Peto, 1988^57^ Fair 6 years | NA; trial in males only | Fatal Stroke of Unknown Type | IG: 12/3,429 (0.4%) CG: 5/1,710 (0.3%) 1.20 (0.42 to 3.39)^**^ | NA | NA
BMD Peto, 1988^57^ Fair 6 years | NA; trial in males only | Nonfatal Stroke of Unknown Type | IG: 45/3,429 (1.3%) CG: 21/1,710 (1.2%) 1.07 (0.64 to 1.79)^**^ | NA | NA
PHS I Physician's Health Study, 1989^53^ Good 5 years | NA; trial in males only | All Ischemic Stroke | IG: 91/11,037 (0.8%) CG: 82/11,034 (0.7%) 1.11 (0.82 to 1.50)^§^ | NA | NA
PHS I Physician's Health Study, 1989^53^ Good 5 years | NA; trial in males only | Fatal Ischemic Stroke | IG: 3/11,037 (0.03%) CG: 3/11,034 (0.03%) 1.00 (0.20 to 4.95)^**^ | NA | NA
PHS I Physician's Health Study, 1989^53^ Good 5 years | NA; trial in males only | Nonfatal Ischemic Stroke | IG: 88/11,037 (0.8%)^**^ CG: 79/11,034 (0.7%)^**^ 1.11 (0.82 to 1.51)^**^ | NA | NA
PHS I Physician's Health Study, 1989^53^ Good 5 years | NA; trial in males only | All Hemorrhagic Stroke | IG: 23/11,037 (0.2%) CG: 12/11,034 (0.1%) 2.14 (0.96 to 4.77)^§^ | NA | NA
PHS I Physician's Health Study, 1989^53^ Good 5 years | NA; trial in males only | Fatal Hemorrhagic Stroke | IG: 7/11,037 (0.06%) CG: 2/11,034 (0.02%) 3.50 (0.73 to 16.84)^**^ | NA | NA
PHS I Physician's Health Study, 1989^53^ Good 5 years | NA; trial in males only | Nonfatal Hemorrhagic Stroke | IG: 16/11,037 (0.1%) CG: 10/11,034 (0.1%) 1.60 (0.73 to 3.52)^**^ | NA | NA
PHS I Physician's Health Study, 1989^53^ Good 5 years | NA; trial in males only | Total Stroke of Unknown Type | IG: 5/11,037 (0.04%) CG: 4/11,034 (0.04%) 1.25 (0.34 to 4.65)^**^ | NA | NA
PHS I Physician's Health Study, 1989^53^ Good 5 years | NA; trial in males only | Fatal Stroke of Unknown Type | IG: 0/11,037 (0%) CG: 2/11,034 (0.02%) 0.20 (0.01 to 4.16)^**^ | NA | NA
PHS I Physician's Health Study, 1989^53^ Good 5 years | NA; trial in males only | Nonfatal Stroke of Unknown Type | IG: 5/11,037 (0.04%)^**^ CG: 2/11,034 (0.02%)^**^ 2.50 (0.48 to 12.88)^**^ | NA | NA
TPT TPT Authors, 1998^54^ Fair 6.8 years║ | NA; trial in males only | All Ischemic Stroke | IG: 10/1,268 (0.8%) CG: 18/1,272 (1.4%) 0.56 (0.26 to 1.20)^**^ | NA | NA
TPT TPT Authors, 1998^54^ Fair 6.8 years║ | NA; trial in males only | Fatal Ischemic Stroke | NR | NA | NA
TPT TPT Authors, 1998^54^ Fair 6.8 years║ | NA; trial in males only | Nonfatal Ischemic Stroke | NR | NA | NA
TPT TPT Authors, 1998^54^ Fair 6.8 years║ | NA; trial in males only | All Hemorrhagic Stroke | IG: 2/1,268 (0.2%)^¶^ CG: 0/1,272 (0%)^¶^ 4.01 (0.18 to 88.90)^**^ | NA | NA
TPT TPT Authors, 1998^54^ Fair 6.8 years║ | NA; trial in males only | Fatal Hemorrhagic Stroke | NR | NA | NA
TPT TPT Authors, 1998^54^ Fair 6.8 years║ | NA; trial in males only | Nonfatal Hemorrhagic Stroke | NR | NA
TPT TPT Authors, 1998^54^ Fair 6.8 years║ | NA; trial in males only | Total Stroke of Unknown Type | IG: 5/1,268 (0.4%) CG: 6/1,272 (0.5%) 0.84 (0.26 to 2.73)^**^ | NA | NA
TPT TPT Authors, 1998^54^ Fair 6.8 years║ | NA; trial in males only | Fatal Stroke of Unknown Type | NR | NA | NA
TPT TPT Authors, 1998^54^ Fair 6.8 years║ | NA; trial in males only | Nonfatal Stroke of Unknown Type | NR | NA | NA
WHS Ridker, 2005^58^ Good 10.1 years | NA; trial in females only | All Ischemic Stroke | NA | IG: 170/19,934 (0.8%) CG: 221/19,942 (1.1%) 0.76 (0.63 to 0.93)^#^ | NA
WHS Ridker, 2005^58^ Good 10.1 years | NA; trial in females only | Fatal Ischemic Stroke | NA | NR | NA
WHS Ridker, 2005^58^ Good 10.1 years | NA; trial in females only | Nonfatal Ischemic Stroke | NA | NR | NA
WHS Ridker, 2005^58^ Good 10.1 years | NA; trial in females only | All Hemorrhagic Stroke | NA | IG: 51/19,934 (0.2%) CG: 41/19,942 (0.2%) 1.24 (0.82 to 1.87)^#^ | NA
WHS Ridker, 2005^58^ Good 10.1 years | NA; trial in females only | Fatal Hemorrhagic Stroke | NA | NR | NA
WHS Ridker, 2005^58^ Good 10.1 years | NA; trial in females only | Nonfatal Hemorrhagic Stroke | NA | NR | NA
WHS Ridker, 2005^58^ Good 10.1 years | NA; trial in females only | Total Stroke of Unknown Type | NA | NR | NA
WHS Ridker, 2005^58^ Good 10.1 years | NA; trial in females only | Fatal Stroke of Unknown Type | NA | NR | NA
WHS Ridker, 2005^58^ Good 10.1 years | NA; trial in females only | Nonfatal Stroke of Unknown Type | NA | NR | NA

Within study comparisons listed first.

* Not calculated from fatal plus nonfatal due to a large proportion of strokes of unknown type.

† Classified as probably ischemic.

‡ Classified as probably hemorrhagic.

§ Adjusted for age and assignment to beta carotene.

║ Median.

¶ There were additional cases of subarachnoid stroke; 1 in the IG and 2 in the CG.

# Adjusted for age and treatment assignment to vitamin E and beta carotene.

** Calculated.

Abbreviations: BMD = British Medical Doctor's Study; CG = control group; CI = confidence interval; ETDRS = Early Treatment Diabetic Retinopathy Study; HOT = Hypertension Optimal Treatment Study; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes Study; NA = not applicable; NR = not reported; NS = not significant; PHS = Physician's Health Study; PPP = Primary Prevention Project; RR = relative risk; TPT = Thrombosis Prevention Trial; WHS = Women's Health Study.

#### Diabetes

Two trials conducted exclusively in diabetes patients reported hemorrhagic stroke (Table 21).44,43 JPAD reported that the risk of hemorrhagic stroke was similar in both groups (RR, 0.87 [95% CI, 0.29 to 2.57]), with an additional two subdural hematomas reported in the aspirin group and none in the control group.43 In POPADAD, there were rare fatal hemorrhagic strokes in both groups (0.31 vs. 0.47%; RR, 0.67 [95% CI, 0.11 to 3.98]).44

Table 21 Diabetes Subgroup: Total, Fatal, and Nonfatal Stroke by Stroke Type

Study Reference Quality Rating Mean Followup | Type of Analysis Diabetes Diagnostic Criteria | Outcome | Diabetes Events/Participants (%) RR (95% CI) | No Diabetes Events/Participants (%) RR (95% CI) | P-Value for Interaction
WHS Ridker, 2005^58^ Rexrode, 2000^69^ Good 10.1 years | A priori Diagnostic criteria: assumed self-reported history of diabetes from the enrollment questionnaire | All Ischemic Stroke | IG: 13/528^*^ (2.5%) CG: 29/499^*^ (5.8%) 0.42 (0.22 to 0.82)^†^ | IG: 157/19,406^*^ (0.8%) CG: 192/19,443^*^ (1.0%) 0.81 (0.66 to 1.00)^†^ | NR
WHS Ridker, 2005^58^ Rexrode, 2000^69^ Good 10.1 years | A priori Diagnostic criteria: assumed self-reported history of diabetes from the enrollment questionnaire | Fatal Ischemic Stroke | NR | NR | NR
WHS Ridker, 2005^58^ Rexrode, 2000^69^ Good 10.1 years | A priori Diagnostic criteria: assumed self-reported history of diabetes from the enrollment questionnaire | Nonfatal Ischemic Stroke | NR | NR | NR
WHS Ridker, 2005^58^ Rexrode, 2000^69^ Good 10.1 years | A priori Diagnostic criteria: assumed self-reported history of diabetes from the enrollment questionnaire | All Hemorrhagic Stroke | NR^‡^ | NR^‡^ | NR
WHS Ridker, 2005^58^ Rexrode, 2000^69^ Good 10.1 years | A priori Diagnostic criteria: assumed self-reported history of diabetes from the enrollment questionnaire | Fatal Hemorrhagic Stroke | NR | NR | NR
WHS Ridker, 2005^58^ Rexrode, 2000^69^ Good 10.1 years | A priori Diagnostic criteria: assumed self-reported history of diabetes from the enrollment questionnaire | Nonfatal Hemorrhagic Stroke | NR | NR | NR
WHS Ridker, 2005^58^ Rexrode, 2000^69^ Good 10.1 years | A priori Diagnostic criteria: assumed self-reported history of diabetes from the enrollment questionnaire | Total Stroke of Unknown Type | NR | NR | NR
WHS Ridker, 2005^58^ Rexrode, 2000^69^ Good 10.1 years | A priori Diagnostic criteria: assumed self-reported history of diabetes from the enrollment questionnaire | Fatal Stroke of Unknown Type | NR | NR | NR
WHS Ridker, 2005^58^ Rexrode, 2000^69^ Good 10.1 years | A priori Diagnostic criteria: assumed self-reported history of diabetes from the enrollment questionnaire | Nonfatal Stroke of Unknown Type | NR | NR | NR
JPAD Ogawa, 2008^43^ Fair 4.4 years^§^ | NA (trial in DM only) Diagnostic criteria: diagnosis of type 2 DM, not further specified | All Ischemic Stroke | NR | NA | NA
JPAD Ogawa, 2008^43^ Fair 4.4 years^§^ | NA (trial in DM only) Diagnostic criteria: diagnosis of type 2 DM, not further specified | Fatal Ischemic Stroke | NR | NA | NA
JPAD Ogawa, 2008^43^ Fair 4.4 years^§^ | NA (trial in DM only) Diagnostic criteria: diagnosis of type 2 DM, not further specified | Nonfatal Ischemic Stroke | IG: 22/1,262 (1.7%) CG: 24/1,277 (1.9%) 0.93 (0.52 to 1.65)^¶^ | NA | NA
JPAD Ogawa, 2008^43^ Fair 4.4 years^§^ | NA (trial in DM only) Diagnostic criteria: diagnosis of type 2 DM, not further specified | All Hemorrhagic Stroke | IG: 6/1,262 (0.5%)║ CG: 7/1,277(0.5%)║ 0.87 (0.29 to 2.57)^¶^ | NA | NA
JPAD Ogawa, 2008^43^ Fair 4.4 years^§^ | NA (trial in DM only) Diagnostic criteria: diagnosis of type 2 DM, not further specified | Fatal Hemorrhagic Stroke | IG: 1/1,262 (0.1%) CG: 4/1,277 (0.3%) 0.25 (0.03 to 2.26)^¶^ | NA | NA
JPAD Ogawa, 2008^43^ Fair 4.4 years^§^ | NA (trial in DM only) Diagnostic criteria: diagnosis of type 2 DM, not further specified | Nonfatal Hemorrhagic Stroke | IG: 5/1,262 (0.4%) CG: 3/1,277 (0.2%) 1.69 (0.40 to 7.04)^¶^ | NA | NA
JPAD Ogawa, 2008^43^ Fair 4.4 years^§^ | NA (trial in DM only) Diagnostic criteria: diagnosis of type 2 DM, not further specified | Total Stroke of Unknown Type | NR | NA | NA
JPAD Ogawa, 2008^43^ Fair 4.4 years^§^ | NA (trial in DM only) Diagnostic criteria: diagnosis of type 2 DM, not further specified | Fatal Stroke of Unknown Type | NR | NA | NA
JPAD Ogawa, 2008^43^ Fair 4.4 years^§^ | NA (trial in DM only) Diagnostic criteria: diagnosis of type 2 DM, not further specified | Nonfatal Stroke of Unknown Type | NR | NA | NA
POPADAD Belch, 2008^44^ Fair 6.7 years^§^ | NA (trial in DM only) Diagnostic criteria: type 1 or 2 diabetes, not further specified | All Ischemic Stroke | NR | NA | NA
POPADAD Belch, 2008^44^ Fair 6.7 years^§^ | NA (trial in DM only) Diagnostic criteria: type 1 or 2 diabetes, not further specified | Fatal Ischemic Stroke | IG: 3/638 (0.5%) CG: 5/638 (0.8%) 0.60 (0.14 to 2.50)^¶^ | NA | NA
POPADAD Belch, 2008^44^ Fair 6.7 years^§^ | NA (trial in DM only) Diagnostic criteria: type 1 or 2 diabetes, not further specified | Nonfatal Ischemic Stroke | NR | NA | NA
POPADAD Belch, 2008^44^ Fair 6.7 years^§^ | NA (trial in DM only) Diagnostic criteria: type 1 or 2 diabetes, not further specified | All Hemorrhagic Stroke | NR | NA | NA
POPADAD Belch, 2008^44^ Fair 6.7 years^§^ | NA (trial in DM only) Diagnostic criteria: type 1 or 2 diabetes, not further specified | Fatal Hemorrhagic Stroke | IG: 2/638 (0.3%) CG: 3/638 (0.5%) 0.67 (0.11 to 3.98)^¶^ | NA | NA
POPADAD Belch, 2008^44^ Fair 6.7 years^§^ | NA (trial in DM only) Diagnostic criteria: type 1 or 2 diabetes, not further specified | Nonfatal Hemorrhagic Stroke | NR | NA | NA
POPADAD Belch, 2008^44^ Fair 6.7 years^§^ | NA (trial in DM only) Diagnostic criteria: type 1 or 2 diabetes, not further specified | Total Stroke of Unknown Type | NR | NA | NA
POPADAD Belch, 2008^44^ Fair 6.7 years^§^ | NA (trial in DM only) Diagnostic criteria: type 1 or 2 diabetes, not further specified | Fatal Stroke of Unknown Type | NR | NA | NA
POPADAD Belch, 2008^44^ Fair 6.7 years^§^ | NA (trial in DM only) Diagnostic criteria: type 1 or 2 diabetes, not further specified | Nonfatal Stroke of Unknown Type | NR | NA | NA

Within study comparisons listed first.

* All denominator Ns in each group back-calculated from Table 3 in Rexrode 2000 (Ns for IG and CG for those with and without DM not reported). Back-calculation results in a discrepancy of 24 participants, likely due to rounding.

† Adjusted for age and treatment assignment to vitamin E and beta carotene.

‡ Cannot calculate based on number of ischemic strokes because there were 4 strokes of unknown type in the placebo group (not clear whether occurring in participants with or without DM).

§ Median.

║ There were an additional 2 cases of chronic subdural hematoma in the aspirin group (0 in the placebo group).

¶ Calculated.

Abbreviations: CG = control group; CI = confidence interval; DM = diabetes mellitus; IG = intervention group; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes Study; NA = not applicable; NR = not reported; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; RR = relative risk; WHS = Women's Health Study.

#### Other Subgroups

No trials reported hemorrhagic stroke by hypertensive status or blood pressure level, lipid status, abnormal ABI, smoking status, or race/ethnicity. No trial reported hemorrhagic stroke by 10-year CVD risk, but JPAD did report a stratified analysis of intracerebral hemorrhage stratified by high- and low-risk groups, which were defined by age and the presence of risk factors in addition to diabetes.71 There was no statistically significant difference in intracerebral hemorrhage between the aspirin and no aspirin groups at either risk level. There were few events in those taking aspirin in the high- and low-risk groups (six in the high-risk group [0.6%] and 0 in the low-risk group; RRs not reported). About 70% of the high-risk group had hypertension.

### ARMD by Subgroup

WHS reported ARMD for the following subgroups: age (45 to 54, 55 to 64, or ≥65 years), smoking status, alcohol use (<1 or ≥1 drink per week), BMI, hypertension status, hyperlipidemia status, diabetes status, menopausal status, parental history of premature MI, multivitamin use, and patients having an eye examination in the past 2 years. While it was unclear if these subgroup analyses were a priori, the analyses were explored using interaction terms with trend testing. Among nonusers of multivitamins, those in the aspirin group had a 32 percent reduction in ARMD (RR, 0.68 [95% CI, 0.49 to 0.95]). Among current multivitamin users, however, there was a nonsignificant 14 percent increase in risk of ARMD in the aspirin group (RR, 1.14 [95% CI, 0.76 to 1.70]; p=0.53 for interaction).58

PHS reported stratified analyses and tests of interactions to evaluate the possible effect modification by the following risk factors: cigarette smoking (ever or never), hypertension status, hypercholesterolemia, and alcohol use (daily, weekly, or rarely). Additionally, PHS reported ARMD events stratified by age group. Of these risk factors, only hypertension status altered the treatment effect, with hypertensive men having a statistically significant 65 percent reduction in ARMD (RR, 0.35 [95% CI, 0.15 to 0.83]; p=0.04).53

## KQ 2b Does the Effect Vary by Dose, Formulation, or Duration Of Aspirin Use?

### Summary of Results

Bleeding events were rare in all trials, making it difficult to draw generalizable conclusions regarding the relationship between aspirin dose, duration, and formulation and bleeding events.

### Dose

In the seven primary prevention trials reporting hemorrhagic stroke or major GI bleeding, there appears to be no qualitative association between these outcomes and aspirin dose (Figures 16–19, Table 19). This result is likely due to such few events being reported (four out of seven trials reported <10 events in the aspirin group), making the numbers unstable. This is illustrated by BMD, which had the highest dose (500 mg/day), but showed a trend toward reduced major GI bleeding (RR, 0.5 [95% CI, 0.10 to 2.47]). Again, this is likely due to small numbers of events being reported and the point estimate being unstable.57

### Formulation

Half of the studies specified tablet formulation—two trials used enteric coated formulations45,59 and three trials used other or unspecified formulations.43,44,56 Qualitatively, there is no apparent association of formulation and aspirin effect for major GI bleeding or hemorrhagic stroke.

### Duration

For the 10 trials included in this KQ, mean trial duration ranged from 3.6 to 10 years, which coincides with aspirin treatment. No trials reported time-to-event data for major GI bleeding outcomes. Only one trial, WHS, provided cumulative incidence data for hemorrhagic stroke, showing a nonsignificant 24 percent increase with aspirin treatment over the 10-year trial duration (p=0.31).58

Qualitatively, stratifying trials' results by duration showed no apparent association between treatment duration and hemorrhagic stroke or major GI bleeding.