# Methods

## Scope and Purpose

This systematic review will provide updated evidence regarding the benefits and harms of aspirin for the primary prevention of cardiovascular events. The USPSTF will use this review to update its 2009 recommendation on this topic.35 This review included all trials from the previous review that met current inclusion and exclusion criteria as well as newly identified studies.

## Key Questions and Analytic Framework

Using the USPSTF's methods (detailed in Appendix B),46 we developed an analytic framework (Figure 1) and two key questions (KQs) in consultation with the Agency for Healthcare Research and Quality (AHRQ) Medical Officer and three members of the USPSTF. These KQs were adapted from questions addressed in the previous review.35

Figure 1 Analytic Framework

Abbreviations: CVD = cardiovacular disease; MI = myocardial infarction.

Figure 1 is the analytic framework that depicts the two Key Questions to be addressed in the systematic review. The figure illustrates how regular aspirin use in patients without known cardiovascular disease may result in a decrease in myocardial infarction, ischemic stroke, and mortality related to all causes and cardiovascular disease (KQ1). The figure also depicts whether intervention with aspirin is associated with any potential harms (KQ2).

### KQs

1. Does regular aspirin use in patients without known CVD reduce MI, stroke, death from MI or stroke, or all-cause mortality?
  a. Does the effect vary between a priori subgroups: age, sex, smoking status, race/ethnicity, 10-year cardiovascular risk, or related risk conditions (e.g., diabetes mellitus, decreased ankle brachial index [ABI], or elevated blood pressure)?
  b. Does the effect vary by dose, formulation (i.e., enteric coated), or duration of aspirin use?
2. Does regular aspirin use increase GI bleeding, hemorrhagic stroke, or other serious harms (e.g., age-related macular degeneration [ARMD])?
  a. Does the effect vary between a priori subgroups: age, sex, smoking status, race/ethnicity, 10-year cardiovascular risk, related risk conditions (e.g., diabetes mellitus, decreased ABI, or elevated blood pressure), GI bleeding or hemorrhagic stroke risk factors (including history of GI bleeding, ulcers, or NSAID use), or concomitant medication use (NSAIDs, selective serotonin reuptake inhibitors, or proton pump inhibitors [PPIs])?
  b. Does the effect vary by dose, formulation, or duration of aspirin use?

## Data Sources and Searches

In addition to considering all studies from the previous review for inclusion in the current review, we performed a comprehensive search of MEDLINE, PubMed, and the Cochrane Collaboration Registry of Controlled Trials for studies published between January 2008 and June 3, 2014. We worked with a medical librarian to develop our search strategy (Appendix B). All searches were limited to articles published in the English language. We managed literature search results using version 12.0 of Reference Manager® (Thomson Reuters, New York, NY), a bibliographic management software database.

To ensure comprehensiveness of our retrieval strategy, we reviewed the reference lists of included studies and relevant systematic reviews and meta-analyses to identify relevant articles that were published before the timeframe of, or not identified in, our literature searches. We also obtained references from outside experts. In addition, we searched federal agency trial registries for ongoing trials (Appendix D).

## Study Selection

Two reviewers independently reviewed the title and abstracts of all identified articles to determine if the study met the inclusion and exclusion criteria for design, population, intervention, and outcomes (Appendix B Table 1). Two reviewers then independently evaluated the full-text article(s) of all potentially relevant studies against the complete inclusion and exclusion criteria. Disagreements in the abstract and/or full-text review were resolved by discussion and consultation with a third reviewer if necessary. Excluded studies and reasons for exclusion are listed in Appendix C.

We developed an a priori set of criteria for inclusion and exclusion of studies based on criteria from the previous review and our understanding of the literature (Appendix B Table 1). For both KQs we considered studies examining the primary prevention of CVD (i.e., MI or stroke) in adults age 40 years or older. We excluded studies that included adult populations with an existing CVD diagnosis (heart failure, previous stroke, previous MI, TIA, angina, or previous bypass or angioplasty), atrial fibrillation, or hypercoagulable disorders. In addition, we did not consider studies in patients with familial hypercholesterolemia and other selected nongeneralizable populations. We included studies examining regular oral aspirin use (minimum of 75 mg every other day) compared to no treatment or a placebo. We excluded interventions including nonaspirin antithrombotic medications, aspirin as a cotreatment to another active intervention, and nonoral or nontablet forms of aspirin. In addition, we excluded studies that did not provide information on the dose of aspirin used or if limited to irregular or occasional aspirin use only. For KQ 1 (effectiveness of aspirin), we considered RCTs or controlled clinical trials reporting MI/coronary events (fatal and nonfatal), stroke (fatal and nonfatal), all-cause mortality, and quality of life. For KQ 2 (harms of aspirin), we considered RCTs, controlled clinical trials, or observational studies (i.e., cohort or case-control studies) reporting GI bleeding, hemorrhagic stroke (fatal and nonfatal), or other serious harms (e.g., ARMD).

Individual patient data (IPD) meta-analyses provide unique data that complement existing trial data, particularly for subpopulations. IPD meta-analyses were not pooled with primary trials due to double counting, but were discussed in relevant results sections when they provided data on subpopulations not available elsewhere.

For both KQs, we required a minimum of 1 year duration of aspirin treatment and study followup. We limited our included studies to those published in English and rated as good or fair quality using USPSTF quality rating standards.47 We excluded studies that were rated as poor quality and those that did not publish results in English. The outcomes that were reviewed are fully listed in Appendix B Table 1.

## Quality Assessment

Two reviewers independently assessed the methodological quality of each study using predefined criteria developed by the USPSTF47 and supplemented with the National Institute for Health and Care Excellence methodology checklists for observational studies.48 Disagreements in quality were resolved by discussion. Each study was given a final quality rating of good, fair, or poor.

Good-quality RCTs had adequate randomization procedures and allocation concealment, blinded outcome assessment, reliable outcome measures, similar groups at baseline (i.e., little to no statistically significant differences between groups in baseline characteristics), low attrition (≥90% of participants had followup data with <10 percentage point difference in loss to followup between groups), used intention-to-treat analysis, and reported diagnostic criteria for outcome ascertainment. Trials were downgraded to fair quality if they were unable to meet the majority of the good quality criteria. We rated trials as poor quality if attrition was greater than 40 percent or differed between groups by 20 percentage points, or if there were any other “fatal” flaws that seriously affected internal validity, as agreed upon by two independent investigators. We did not rate any trials as poor, however, based on these criteria.

## Data Extraction

One reviewer extracted data from all included studies rated as fair or good quality into a standard evidence table (Microsoft Excel®; Microsoft Corporation, Redmond, WA) and a second reviewer checked data for accuracy. Elements abstracted included: population characteristics (e.g., baseline demographics, including CVD risk factors, concurrent conditions and medication use [i.e., antihypertension medications, lipid-lowering agents, selective serotonin reuptake inhibitors, PPIs, H2 blockers, or NSAIDs]); history of GI ulcers or treatment for Helicobacter pylori; study design (e.g., recruitment procedures, inclusion/exclusion criteria, followup, and adherence), intervention characteristics (i.e., aspirin dose, duration, formulation, and administration time), and outcomes as specified in the inclusion and exclusion criteria.

Health outcomes included the number and rate of participants experiencing an event and measures of association where reported; adjustments for confounders were noted as appropriate. For KQ 1 (effectiveness of aspirin), we abstracted the reported primary composite CVD outcomes from each included trial, describing in detail what elements composed each composite outcome. In addition, we abstracted fatal and nonfatal MI, coronary, and stroke events, separating by stroke type where reported. Furthermore, CVD-related and all-cause mortality data were abstracted for each included trial. For KQ 2 (harms of aspirin), we abstracted bleeding events with a focus on GI bleeding, intracranial bleeding, and hemorrhagic stroke.

## Data Synthesis and Analysis

After the abstraction of data into evidence tables, we audited the outcomes reported across trials to assess heterogeneity of reporting. We identified 24 eligible outcomes (including variations for fatal, nonfatal, and total events per category) that we prioritized into four primary outcomes based on a priori decisions from the criteria and the availability/consistency of outcome reporting across trials: 1) composite of death from MI/coronary events, stroke, and CVD, 2) nonfatal stroke, 3) nonfatal MI/coronary events, and 4) all-cause mortality. Seven secondary outcomes were also identified: 1) total stroke, 2) total MI/coronary events, 3) fatal MI/coronary events, 4) composite of fatal MI/coronary events and fatal stroke, 5) composite of nonfatal MI/coronary events and nonfatal stroke, 6) composite of MI/coronary events and stroke (fatal and nonfatal) combined with CVD mortality, and 7) CVD composites identified by the trial.

Because of substantial heterogeneity in the definition of trials' primary composite outcomes, and the fact that these composites included outcomes that were not eligible for our review (i.e., angina, revascularization) or not related to the aspirin pathway (i.e., abdominal aortic aneurysm, heart failure, pulmonary embolism), we constructed our own primary composite outcome of fatal MI/coronary events, fatal stroke, and cardiovascular death. When this outcome was not reported in primary studies, we combined fatal stroke, fatal MI/coronary events, and cardiovascular death. We also analyzed these outcomes individually. We defined fatal MI/fatal coronary events as fatal acute MI, sudden death (International Classification of Disease [ICD]-9 code 798: sudden death cause unknown), and all death attributable to ischemic heart disease (IHD) (ICD-9 codes 410–414). Where possible, we excluded abdominal aortic aneurysm, heart failure, and pulmonary embolism from the cardiovascular death composite. In some cases, however, these events were not reported separately and, as a result, it was possible that such events contributed to a trial's reported cardiovascular death composite. We assumed that these other causes of CVD-related mortality would represent few contributing events; this approach was preferable to excluding such trials in the analysis for the composite CVD mortality outcome.

When not reported, we calculated nonfatal (fatal) events by subtracting fatal (nonfatal) events from total events for an outcome category. Stroke type was not calculated from total stroke and another stroke type (i.e., calculate ischemic by subtracting hemorrhagic from total) unless the study reported that all strokes were ascertained or reported stroke of unknown type. If a combination of outcomes were not reported in a trial (i.e., total stroke), we added together its components where possible (i.e., fatal and nonfatal stroke).

For multifactorial trials with additional randomization to vitamins/antioxidants or placebo, we combined groups, as there was no evidence of interaction and evidence from systematic reviews supports that vitamins do not reduce the incidence of CVD.49 In a trial with additional randomization to warfarin or placebo, we did not include these arms, as we considered warfarin a “cotreatment” that we excluded per inclusion criteria.

We limited our analysis of bleeding to major GI bleeding, defined as GI bleeding requiring transfusion or hospitalization or leading to death. If a trial reported transfusions and death from GI bleeding separately, we added these events together. If a trial only reported deaths from GI bleeding, we used that number for major GI bleeding (we recognize that these event rates will appear low compared to other studies also reporting nonfatal major GI bleeding). If a trial reported GI bleeding without any mention of severity, we did not include it in our analysis. While we considered minor GI bleeding, bleeding from other sites, and other serious harms, they are discussed in an accompanying systematic review.50

Because these studies were conducted in relatively healthy primary prevention populations, most outcomes were rare (i.e., generally <10% of participants experienced any given event, and <1% to 2% for some outcomes). Because of rare events, the Mantel-Haenszel fixed effects model was chosen as the primary statistical analysis method.51 Sensitivity analyses were conducted using the Peto odds ratio (OR) method.52 We assessed statistical heterogeneity using the I^2^ statistic. We assessed small study bias using funnel plots and Peters test of bias for the four primary outcomes. None of these outcomes demonstrated a statistically significant relationship between effect size and study precision. The power was limited for these tests, however, because only nine to 10 studies were included for these outcomes.

Forest plots show adjusted values for relative risks (RRs) when primary studies adjusted for confounders, along with the Mantel-Haenszel pooled estimate. When measures of association were not reported, we calculated these measures using the number of individuals and the numbers of events in each randomized group. We used unadjusted values for sensitivity analyses using Peto ORs because of software/programming limitations. When events were reported as per unit of patient-years and the number of patient-years in each group was reported, we calculated the number of events in each group.

Given the small number of included trials, we chose not to pool several outcomes because of very small absolute numbers of events, which we believed could result in unstable and potentially misleading effect estimates. Although the outcomes we pooled were also rare events, large samples ensured that trials found at least 10 or more events in each treatment arm for most pooled outcomes. We did not pool outcomes, however, when a substantial number of trials reported fewer than 10 events in one or both treatment arms. We did not pool fatal stroke, for example, because of small numbers of events—six of nine contributing studies had fewer than 10 events in one or both groups. In contrast, we pooled the fatal MI/coronary event outcome, which had 10 contributing trials with only two having fewer than 10 events in each group. We did include the forest plots of outcomes we did not pool in a visual display of the data.

We used first-event analyses when trials reported both first and total event analyses. We chose this more conservative approach because after a first event, patients are more likely to have a second event in the same category. These patients are likely being treated for secondary prevention with other potentially confounding medical management, such as lipid therapy and administration of beta blockers or angiotensin-converting enzyme inhibitors. We identified both heterogeneity and a lack of reporting across trials regarding whether analyses were first event only or whether multiple events were allowed within or across outcome categories.

In order to explore the impact of heterogeneity in population characteristics and aspirin dose, we conducted sensitivity analyses to exclude four trials of special populations with diabetes, abnormal ABI, or both and aspirin doses of 325 mg or greater and greater than 100 mg. Forest plots were created that show daily aspirin dose. For trials using alternate day dosing, we divided the alternate day dose by two to generate the daily dose. Additionally, funnel plots were created to explore publication bias.

We did not pool the results of IPD meta-analyses with primary trials to avoid double counting. We discuss the results of these analyses separately. When results from long-term observational followup were reported, these were not pooled, as followup was not randomized for the entire period. We addressed the results from these analyses qualitatively.

## Subpopulation Methods

We prespecified subpopulations of interest in the KQs. These populations were selected based on analysis of subpopulation considerations in the previous review and recommendation, established characteristics associated with cardiovascular and/or bleeding risk, and subpopulations addressed in authoritative existing systematic reviews. During the data abstraction phase, we catalogued the availability and characteristics of subgroup analyses (i.e., whether analyses were a priori, post hoc, or unclear) for each subpopulation of interest for each trial and subsequently audited these results (Appendix E Table 2). Using this audit, formal subgroup analyses were prioritized based on the number of contributing studies and the credibility of subgroup analyses, with subpopulation-specific trials and a priori analyses given more weight.

We then entered data from subgroup analyses into evidence tables and further into summary tables for the prioritized analyses of sex, age, and diabetes. In addition to outcomes, subgroup summary tables included information relevant to the credibility of each trial's subgroup analyses, including timing of the analysis, interaction testing for heterogeneity of treatment effect, and if relevant, diagnostic criteria for the subgroup of interest. Direct evidence from within-study comparisons was emphasized over across-study comparisons, which can be confounded by differences in populations and their risk factors.

Based on a limited number of contributing studies for subgroup analyses, we did not pool results and instead analyzed them qualitatively.

## Expert Review and Public Comment

A draft of the analytic framework, KQs, and inclusion/exclusion criteria was posted on the USPSTF Web site for public comment from July 11, 2013 to August 7, 2013. We received comments from 11 individuals or organizations. All comments were reviewed and addressed as appropriate. The final research plan was posted on the USPSTF Web site on October 3, 2013.

## USPSTF Involvement

This research was funded by AHRQ under a contract to support the work of the USPSTF. The authors worked with three USPSTF liaisons at key points throughout the review process to develop and refine the scope, analytic framework, and KQs; to resolve issues around the review process; and to finalize the evidence synthesis. AHRQ had no role in study selection, quality assessment, or synthesis. AHRQ staff provided project oversight, reviewed the draft evidence synthesis, and distributed the initial evidence report for external review of content by outside experts, including representatives of professional societies and federal agencies. We revised the final published systematic evidence review based on comments from these external reviewers.