# Additional Tables

Appendix E Table 1 Recommendations of Other Organizations

| | UK CKS-NICE, 2013^38^ | UK JBS3, 2014^39^ | SIGN, 2013^40^ | Europe ESC, 2012^41^ | USPSTF, 2009^35^ | AHA, 2011^36^ | ADA, 2010^37^ | Canada, 2008 and 2010^131,132^ | WHO, 2007^133^
Subjects without Diabetes | Age (years) | -- | -- | -- | -- | Men 45-79, Women 55-79 | -- | -- | <70 | --
Subjects without Diabetes | 10-year Risk | Weak evidence for aspirin in hypertensives over 50 years with >20% CVD risk or with reduced renal function | | -- | -- | (CHD Risk) Men: 45-59 if ≥4%, 60-69 if ≥9%, 70-79 if ≥12% (Stroke Risk) Women: 55-59 if ≥3%, 60-69 if ≥8%, 70-79 if ≥11% | (CVD Risk) ≥6-10% | -- | (CHD Risk) ≥20% | (CVD Risk) ≥30%
Subjects without Diabetes | Aspirin regimen | Not recommended | Not stated | Not recommended | Not justified | 75 mg/d | 81 mg/d or 100 mg every other day | -- | 81 mg/d | 75-100 mg/d
Subjects with Diabetes | Age (years) | -- | -- | -- | -- | -- | -- | -- | -- | --
Subjects with Diabetes | 10-year Risk | -- | -- | -- | -- | Diabetes a risk factor in risk assessment models | -- | (CVD Risk) >10%; those at highest risk include most men ≥50, women ≥60 years with additional risk factors | Decision to prescribe should be based on individual clinical judgment | Specific 10-year risk tables
Subjects with Diabetes | Aspirin regimen | -- | Not recommended | -- | Not recommended | -- | Not useful in absence of other CVD | 75 to 162 mg | -- | --

* Adapted from Matthys, 2014^95^

Abbreviations: ADA= American Diabetes Association; AHA= American Heart Association; CKS-NICE= Clinical Knowledge Summaries-National Institute for Health and Care Excellence; ESC= European Society of Cardiology; JBS= Joint British Societies; SIGN= Scottish Intercollegiate Guidelines Network; USPSTF= United States Preventive Services Task Force; WHO= World Health Organization

Appendix E Table 2 Audit of Subgroup Analyses in Included Trials

A priori subpopulations from Work Plan | Study is subpopulation- specific | Study reports a priori subgroup analysis | Study reports post hoc subgroup analysis | Study reports subgroup analysis and the specification of the analysis is unclear
Age | | JPAD43 (<65, ≥65) AAA45 (<62, ≥62) WHS58 (45-54, 55-64, ≥ 65) | | PHS53 (40-49, 50-59, 60-69, 70-84) POPADAD44 (<60, ≥60) HOT60 (<65, ≥65) TPT66- 45-49, 50-54, 55-59, 60-64, 65-69
Sex | BMD57 – Men PHS53 – Men TPT54 - Men WHS58 - Women | JPAD43 AAA45 | | POPADAD44 ETDRS55 HOT60 PPP61
Smoking Status | | JPAD43 (current or past, nonsmoker) WHS58 (current, past or never) | | PHS (never, past, current)
Race/ Ethnicity | JPAD43 - Japan
10-yr CVD Risk | TPT54 – Top 20% risk (by Northwick Park Heart Study algorithm) | WHS58 (<5%, 5%-9.9%, >=10%) | WHS58 | HOT64 (15-20%, >20%) JPAD71 (age plus presence of risk factors)
Diabetes | JPAD43 POPADAD44 ETDRS55 | WHS58 | PPP63 AAA45 (without DM only) | PHS53 HOT62
ABI | POPADAD44 (ABI ≤0.99) AAA45 (ABI ≤0.95) | | AAA45 (≤0.95, ≤0.90, ≤0.85, ≤0.80) | POPADAD44 (≤.90, 0.91-0.99)
Elevated BP | HOT64 | JPAD65 (HTN, no HTN for composite) WHS58 (by HTN status and BP level; <120/75, 120-129/75-89, 130-139/85-89, ≥140/90) | | HOT64 (SBP ≥180, 160 to <180, <160; DBP ≥107, 104 to <107, <104) JPAD65 (attained/unattained BP goal, for stroke) PHS53 (SBP <109, 110-129, 130-149, ≥150; DBP ≤69, 70-79, 80-89, ≥90) TPT66 (SBP <130, 130-145, >145)
Risk related conditions: Lipid status | | JPAD43 WHS58 | | PHS53 TPT54 (<5.9, 5.9-6.7, >6.7 mmol/L)
Risk related conditions: Kidney function | | | JPAD43 HOT64
Risk related conditions: Number of risk factors | | WHS58

Abbreviations: AAA = Aspiring for Asymptomatic Atherosclerosis Trial; ABI= Ankle Brachial Index; BMD = British Medical Doctor's Study; BP= Blood Pressure; CVD= Cardiovascular Disease; ETDRS = Early Treatment Diabetic Retinopathy Study; HOT = Hypertension Optimal Treatment Study; JPAD = Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes Study; PHS = Physician's Health Study; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; PPP = Primary Prevention Project; TPT = Thrombosis Prevention Trial; WHS = Women's Health Study

Appendix E Table 3 Results of Other Recent Meta-Analyses

Author, Year, k | Statistic and Model | Major CV Events | Total MI | Total Stroke | All-cause Mortality | Major Bleeding
Berger, 2011^75^, k=9 | Risk Ratio (95% CI) Random effects, model not specified | 0.90 (0.85, 0.96) | 0.86 (0.74, 1.00) | 0.94 (0.84, 1.06) | 0.94 (0.89, 1.00) p=0.07 | 1.62 (1.31, 2.00)^†^
Seshasai, 2012^72^, k=9 | Odds Ratio (95% CI) Random effects, model not specified, fixed effects were conducted for comparison | 0.90 (0.85, 0.96) | 0.86 (0.74, 1.01) | 0.94 (0.84, 1.06) | 0.94 (0.88, 1.00) | 1.70 (1.17, 2.46)^‡^
Raju, 2011 73 k=9 | Relative Risk (95% CI) DerSimonian-Laird Random effects | 0.88 (0.83, 0.94) | 0.83 (0.69, 1.00) | 0.93 (0.82, 1.05) | 0.94 (0.88, 1.00) | 1.66 (1.41, 1.95)^†^
Bartolucci, 2011 74 k=9 | Odds Ratio (95% CI) Mantel-Haenszel chi-square | 0.865 (0.804, 0.930) | 0.854 (0.688, 1.061) | 0.919 (0.828, 1.021) | 0.945 (0.881, 1.014), p=0.115 | NR
ATT Collaboration,2009 33 * k=6 | Rate Ratio (95% CI) IPD meta-analysis | 0.82 (0.75, 0.90) p=0.00002 | NR | 0.95 (0.85, 1.06) p=0.4 | 0.95 (0.88, 1.02) | 1.54 (1.300, 1.82)^§^

* Individual patient-level meta-analysis

† ”Major bleeding” as defined by trial authors, GI bleeding reported separately

‡ “Nontrivial bleeding” defined as “fatal bleeding from any site; cerebrovascular or retinal bleeding; bleeding from hollow viscous; bleeding requiring hospitalization and/or transfusion; or study-defined major bleeding regardless of source”

§ Major extra-cranial bleeding, not defined

Abbreviations: ATT = Antithrombotic Trialists; CI = confidence interval; CV = cardiovascular; IPD = individual participant data; MI = myocardial infarction;

Appendix E Table 4 Timeline of Publications of Aspirin for CVD Prevention With a Focus on Sex-Specific Conclusions

Document | Journal and Date Published | Summary/Conclusions
Evidence Synthesis for the USPSTF, 2002^134^ SR of five trials; three of which were in men only | Annals, January 15, 2002 | Sex-specific data reported for only one of two studies (HOT), showing a smaller and non-significant effect for MI in women (unadj RR=0.81 [0.49-1.31]) compared with men (unadj RR=0.58 [0.41-0.81]). Pre-specification of sex subgroups is unclear and no interaction tests were performed. PPP investigators noted that women derive the same level of benefit for CHD reduction as men, but data not reported. No sex differences seen for stroke or all-cause mortality. Authors' conclusions: unclear whether sex modifies the effect of aspirin.
USPSTF Recommendation, 2002 42 | Annals, January 15, 2002 | The USPSTF made an A recommendation that clinicians should discuss aspirin chemoprevention in patients at high risk for heart disease. The balance of benefits and harms is most favorable in patients with a 5-year risk ≥ 3% for CHD. Sex-specific recommendations were not made.
WHS, 2005 58 | NEJM, March 31, 2005 | In this large primary prevention trial of women (N=39,876) with a mean follow-up of 10.1 years, aspirin did not reduce the risk of the primary outcome of composite cardiovascular events (adj RR=0.91 [0.80-1.03]); or the secondary outcomes of total MI, fatal or nonfatal MI, fatal stroke, hemorrhagic stroke, or all-cause mortality. Aspirin did reduce secondary outcomes of nonfatal stroke (adj RR=0.81 [0.67-0.97]) and ischemic stroke (adj RR=0.76 [0.63-0.93]). Pre-specified subgroup analysis with interaction testing showed that in women age ≥65 years, MI was reduced (adj RR=0.66 [0.44-0.97]) as well as composite CVD events (adj RR=0.74 [0.59-0.92]).
Berger, 2006^61^ MA of six trials, and includes some unpublished sex-specific outcomes from PPP Sex-specific findings driven by WHS, due to sample sizes. | JAMA, January 18, 2006 | In men and women aspirin reduced the risk of a composite of cardiovascular events (men:k=5;n=44,114; OR=0.86 [0.78-0.94]; women:k=3;N=51,342; OR=0.88 [0.79-0.99]) in trials with mean followup of 3.7-10 years. The effect of aspirin was judged to be different men and women. Interaction tests and multivariate adjustment for other risk factors were not performed. In women, aspirin reduced the risk of total strokes (k=3; N=51,342; OR=0.83 [0.70-0.97]) and ischemic stroke (k=2; N=42,459; OR=0.76 [0.63-0.93]). In men, it reduced the risk of total MI (k=5;N=44,114; OR 0.68 [0.54-0.86]). Aspirin significantly increased the risk of bleeding to a similar degree in men and women. Authors' conclusions: aspirin reduces the risk of a composite of cardiovascular events in men and women; however, this works through different outcomes - a reduction of ischemic stroke in women and MI in men.
Evidence Synthesis for the USPSTF (AHRQ in-house review), 2009^135^ WHS and Berger, 2006 MA | Annals, March 17, 2009 | Authors' conclusions based on findings from WHS and the Berger, 2006 meta-analysis: aspirin reduces the risk of CVD events in men and women without a history of CVD. Men have reduced risk for MI, and women have reduced risk for ischemic strokes. Aspirin does not seem to affect CVD mortality or all-cause mortality.
USPSTF Recommendation, 2009 135 | Annals, March 17, 2009 | The USPSTF made the following recommendations:; - Encourage men age 45 to 79 years to use aspirin when the potential benefit of a reduction in myocardial infarctions outweighs the potential harm of an increase in gastrointestinal hemorrhage. (A recommendation); - Encourage women age 55 to 79 years to use aspirin when the potential benefit of a reduction in ischemic strokes outweighs the potential harm of an increase in gastrointestinal hemorrhage. (A recommendation); - Evidence is insufficient to assess the balance of benefits and harms of aspirin for cardiovascular disease prevention in men and women 80 years or older. (I statement); - Do not encourage aspirin use for cardiovascular disease prevention in women younger than 55 years and in men younger than 45 years. (D recommendation)
ATT, 2009^33^ Individual patient-level data MA of six primary prevention trials (BMD, TPT, WHS, HOT, PPP, PHS) | Lancet, May 30, 2009 | This patient level MA of the same 6 studies included in Berger, 2006 showed similar statistical trends by sex as assessed by interaction tests (although slightly different outcomes; for men, major coronary event ratio of annual event rates=0.77 [0.67-0.89] and for women, ischemic stroke annual event rates= 0.77[0.59-0.99]); however interactions tests were not statistically significant after adjustment for multiple comparisons. Multivariate adjustment for other risk factors was not performed. Authors' conclusions: in primary prevention, aspirin is of uncertain net value as the reduction in occlusive events needs to be weighed against an increase in major bleeds.
USPSTF Response to the ATT Collaboration Meta-Analysis, 2009 136 | USPSTF Website May 30, 2009 | The Task Force responded that combining data on men and women obscures gender-specific benefits, noting that a gender-specific analysis is most appropriate in this case, given the differing epidemiology of cardiovascular disease in men and women. The Task Force cited the heterogeneity of treatment effect, suggesting that a gender-combined analysis is not appropriate for drawing an overall conclusion. The Task Force also noted that the ATT authors use of a combined outcome of “serious vascular event,” defined as myocardial infarction (MI), stroke, or death from a vascular cause (including sudden death, pulmonary embolism, and hemorrhage), further obscures interpretation of findings since it combines widely varying entities across a wide spectrum of severity. Such a combined outcome diluted the observed effects of the reduction of MIs in men and reduction of stroke in women. Finally, the USPSTF disagreed with the suitability of subgroup analysis by CHD risk because CHD risk stratification would not capture the potential benefit of reduction in stroke in women.
POPADAD, 2008 44 JPAD, 2008 43 AAA, 2010 45 | BMJ, October 16, 2008 JAMA, November, 2008 JAMA, March 3, 2010 | Three new trials published since the previous recommendation were all were conducted in special populations (individuals with diabetes, abnormal ABI, or both). JPAD and AAA included pre-specified subgroup analyses for sex subgroups; interaction testing was not performed but these 2 trials reported no significant sex differences for the primary endpoint of all atherosclerotic events (value of p for interaction only reported as not significant). For JPAD, composite of all atherosclerotic events was reported in men as HR 0.74(0.49-1.12) and in women as HR 0.88(0.53-1.44). For AAA, composite endpoint of fatal/nonfatal MI, fatal/nonfatal stroke+ revascularization was reported in men as HR 1.15 (0.86-1.54) and in women as HR 0.92(0.68-1.23).The pre-specification of sex subgroup analyses in POPADAD is unclear and authors performed interaction testing and reported a p of 0.54 for the heterogeneity of treatment effect; there were no sex specific differences for the outcome of CVD composite or CVD mortality.
Berger, 2011^75^ MA, nine trials included (all of the same as our review minus ETDRS, thus 6 primary prevention trials, JPAD, POPAD, AAA) | American Heart Journal, July, 2011 | This MA of nine trials with mean followup ranging from 3.7 to 10 years showed that aspirin primary prevention reduced the composite of major cardiovascular events (nonfatal MI+nonfatal stroke+CVD death) (k=9; N=102,621; RR=0.90 [0.85-0.96]) but did not reduce total MI, total stroke, ischemic stroke, hemorrhagic stroke or ACM. In a meta-regression, there was no relationship between sex and the effect of aspirin. Authors' conclusions: benefit of aspirin chemoprevention is offset by risk.

Abbreviations: AAA= Aspiring for Asymptomatic Atherosclerosis Trial; ABI= Ankle Brachial Index; ACM= All-Cause Mortality; adj= adjusted; AHRQ= Agency for Healthcare Research and Quality; ATT= Antithrombotic Trialists; BMD= British Medical Doctors Trial; BMJ= British Medical Journal; CHD= Coronary Heart Disease; CVD= Cardiovascular Disease; ETDRS= Early Treatment for Diabetic Retinopathy Study; HOT= Hypertension Optimal Treatment Trial; HR= Hazard Ratio; JAMA= Journal of the American Medical Association; JPAD= Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes Study; k= number of trials; MA= Meta-Analysis; MI= Myocardial Infarction; N= population; n= trial population; NEJM= New England Journal of Medicine; OR= Odds Ratio; PHS= Physician's Health Study; POPADAD= Prevention of Progression of Arterial Disease and Diabetes; PPP= Primary Prevention Project; RR= Relative Risk; SR= Systematic Review; TPT= Thrombosis Prevention Trial; unadj= Unadjusted; USPSTF= United States Preventive Services Task Force; WHS= Women's Health Study

Appendix E Table 5 Availability of Risk Assessment Calculators

Outcome | US-based derivation cohort | Major CVD/CHD/Stroke Risk Assessment Tools^*^ | Externally Validated | Externally Validated in US Population
CVD | Yes | Framingham-Anderson, 1991^16,25^ Reynolds – Women, 2007^19^ Framingham-D'Agostino, 2008^6^ Reynolds – Men, 2008^20^ ACC/AHA Pooled Cohort Equation, 2013^14^ | Framingham-Anderson, 1991^16,25^ ACC/AHA Pooled Cohort Equation, 2013^14^ | Framingham-Anderson, 1991^16,25,†^ ACC/AHA Pooled Cohort Equation, 2013^14^
CVD | No | SCORE, 2003^18^ ASSIGN, 2007^124^ | SCORE, 2003^18^ ASSIGN, 2007^124^
CHD | Yes | Framingham-Anderson, 1991^16,25^ Framingham-Wilson, 1998^‡,8^ Framingham-ATP III, 2002^15^ ARIC, 2003^17^ | Framingham-Anderson, 1991^16,25^ Framingham-Wilson, 1998^‡,8^ Framingham-ATP III, 2002^15^ | Framingham-Anderson, 1991^16,25^ Framingham-Wilson, 1998^‡,8^ Framingham-ATP III, 2002^15^
CHD | No | PROCAM, 2002^22^ QRISK2, 2008^21^ | PROCAM, 2002^22^
Stroke | Yes | Framingham-Anderson, 1991^16,25^ Framingham-Wolf, 1991^†,126,127^ | Framingham-Anderson, 1991^16,25^ Framingham-Wolf, 1991^†,126,127^
Stroke | No

* As identified by SRs of risk assessment tools23,101-103; does not include tools exclusive to patients with diabetes (DARTS, UKPDS, ARIC-Diabetes, Cardiff, Royal College of Physicians of Edinburgh)

† Included US participants from LIFE study but available only as poster presentation; data not published

‡ Cited in 2009 USPSTF aspirin recommendation35

Abbreviations: ACC/AHA= American College of Cardiology/American Heart Association; ARIC= Atherosclerosis Risk in Communities; ASCVD= Atherosclerotic Cardiovascular Disease; CHD= Coronary Heart Disease; CVD= Cardiovascular Disease; SCORE= Systematic Coronary Risk Evaluation