# Ongoing Studies

Ongoing Trial | ASPREE94 | ACCEPT-D92 | ASCEND91 | JPPP129 | ARRIVE130
Location | US and Australia | Italy | UK | Japan | US and Europe
Sample | Healthy men and women age 70 or older | Men and women age 50 or older with diabetes and on a statin or candidate to start statin treatment | Men and women age 40 or older with diabetes | Men and women age 60-85 years with one or more of the following: HTN, hyperlipidemia, or DM | Men and women age 55 or older (males 55 or older with 2 to 4 risk factors; females 60 or older with 3 or more risk factors)
Estimated enrollment | 19,000 | 5,170 | 15,000 | 10,000 | NR
Aspirin dose | 100 mg (enteric-coated), daily | 100 mg daily | 100 mg daily | 100 mg (enteric-coated), daily | 100 mg (enteric-coated), daily
Primary endpoint | Death from any cause or incident dementia or persistent physical disability | Composite of CV death, non-fatal MI, non-fatal stroke, and hospital admission for CV causes | Composite of non-fatal MI, non-fatal stroke or vascular death, excluding confirmed cerebral hemorrhage | Composite of CV death, nonfatal cerebral stroke and nonfatal MI | Time to first occurrence of the composite outcome of MI, stroke or cardiovascular death
Length of Followup (Yrs) | 5 | 5 | 5-7 | 4 | 5
Estimated completion date | August 2016 | December 2013^*^ | December 2016 | Unknown. Enrollment completed June 2007 with 4 years planned F/U^*^. | May 2015

* Trial authors were contacted regarding preliminary data for these trials, no response was received.

Abbreviations: ACCEPT-D= Aspirin and Simvistatin Combination for Cardiovascular Events Prevention in Trials in Diabetes; ASCEND= A Study of Cardiovascular Events in Diabetes; ASPREE= Aspirin in Reducing Events in the Elderly; ARRIVE= Aspirin to Reduce Risk of Initial Vascular Events; CV= Cardiovascular; DM= Diabetes Mellitus; F/U= Followup; HTN= Hypertension; JPPP= Japanese Primary Prevention Project; mg= milligram; NR= Not Reported; UK= United Kingdom; US= United States