# Excluded Studies

Exclusion Code | Definition
E1 | Setting – not in a high GDI country
E2 | Population
E2a | Patients with existing CVD diagnosis or history
E2b | Patients with a-fib, familial hypercholesterolemia, or hypercoaguable disorders
E2c | Children or adults <40 years of age
E3 | Study quality
E4 | Study design – not an RCT or CCT(KQ1) or observational(KQ2)
E5 | Intervention
E5a | Duration <1 year
E5b | Dose – aspirin dose <75mg QOD, dose NR, or irregular or occasional use
E5c | Non-oral or non-tablet forms of aspirin
E5d | Aspirin as a co-treatment
E6 | Comparisons – Any active substance or intervention
E7 | Outcomes
E7a | Composite outcome includes non-eligible endpoints (e.g., angina or revascularization) and there is no separate reporting of individual outcomes
E8 | Precedes search period
E9 | Non-English

1 Berger JS. Aspirin as preventive therapy in patients with asymptomatic vascular disease. JAMA. Mar. 3. 2010;303(9):880-2. KQ1E4. [pmid: 20197537].
2 Buring JE, Hennekens CH. The Women00027;s Health Study: summary of the study design. J Myocardial Ischemia. 1992;(4):27-9. PMID: None. KQ1E7, KQ2E7.
3 Bytzer P, Pratt S, Elkin E, et al. Burden of upper gastrointestinal symptoms in patients receiving low-dose acetylsalicylic acid for cardiovascular risk management: a prospective observational study. American Journal of Cardiovascular Drugs. Feb. 2013;13(1):27-35. KQ2E5a. [pmid: 23315343].
4 Cook NR, Hebert PR, Manson JE, et al. Self-selected posttrial aspirin use and subsequent cardiovascular disease and mortality in the physicians00027;s health study. Archives of Internal Medicine. Apr. 10. 2000;160(7):921-8. KQ1E7, KQ2E7. [pmid: 10761956].
5 Cook NR, Cole SR, Hennekens CH. Use of a Marginal Structural Model to Determine the Effect of Aspirin on Cardiovascular Mortality in the Physicians00027; Health Study. American Journal of Epidemiology. Jun. 1. 2002;155(11):1045-53. KQ1E7, KQ2E7. [pmid: 12034583].
6 Critical Leg Ischaemia Prevention Study (CLIPS) Group. Prevention of serious vascular events by aspirin amongst patients with peripheral arterial disease: randomized, double-blind trial. Journal of Internal Medicine. 2007;261:276-84. PMID: None. KQ1E2a, KQ2E2a. [pmid: 17305650].
7 de Jong PT. Aspirin and age-related macular degeneration. Ophthalmology. 2010;117(6):1279-80. KQ2E4. [pmid: 20522343].
8 de Jong PT, Chakravarthy U, Rahu M, et al. Associations between aspirin use and aging macula disorder: the European Eye Study. Ophthalmology. Jan. 2012;119(1):112-8. KQ2E5. [pmid: 21920607].
9 Dorresteijn JA, Visseren FL, Ridker PM, et al. Aspirin for primary prevention of vascular events in women: individualized prediction of treatment effects. European Heart Journal. Dec. 2011;32(23):2962-9. KQ1E7, KQ2E7. [pmid: 22090661].
10 ETDRS Investigators. Early Treatment Diabetic Retinopathy Study design and baseline patient characteristics. ETDRS report number 7. Ophthalmology. May. 1991;98(5 Suppl):741-56. KQ2E7. [pmid: 2062510].
11 ETDRS Investigators. Aspirin effects on mortality and morbidity in patients with diabetes mellitus. Early Treatment Diabetic Retinopathy Study report 14. ETDRS Investigators. JAMA. Sep. 9. 1992;268(10):1292-300. KQ2E7. [pmid: 1507375].
12 Fasey N, BRENNAN PJ, Meade TW. Thrombosis prevention trial: follow-up study of practical implications. Br J Gen Pract. Mar. 2002;52(476):208-9. KQ1E7, KQ2E7. [pmid: 12030663].
13 Hansson L, Zanchetti A. The Hypertension Optimal Treatment (HOT) Study: 12-month data on blood pressure and tolerability. With special reference to age and gender. Blood Press. Sep. 1995;4(5):313-9. KQ1E7, KQ2E7. [pmid: 8535554].
14 Hansson L, Zanchetti A. The Hypertension Optimal Treatment (HOT) Study: 24-month data on blood pressure and tolerability. Blood Press. Sep. 1997;6(5):313-7. KQ1E7, KQ2E7. [pmid: 9360003].
15 Huang ES, Strate LL, Ho WW, et al. A prospective study of aspirin use and the risk of gastrointestinal bleeding in men. PLoS One. 2010;5. KQ2E2a. [pmid: 21209949].
16 Kurth T, Glynn RJ, Walker AM, et al. Inhibition of Clinical Benefits of Aspirin on First Myocardial Infarction by Nonsteroidal Antiinflammatory Drugs. Circulation. Sep. 9. 2003;108(10):1191-5. KQ1E7, KQ2E7. [pmid: 12939216].
17 Meade TW, WILKES HC, STIRLING Y, et al. Randomized controlled trial of low dose warfarin in the primary prevention of ischaemic heart disease in men at high risk: design and pilot study. European Heart Journal. Aug. 1. 1988;9(8):836-43. KQ1E7, KQ2E7. [pmid: 3053176].
18 Okada S, Morimoto T, Ogawa H, et al. Differential effect of low-dose aspirin for primary prevention of atherosclerotic events in diabetes management: a subanalysis of the JPAD trial. Diabetes Care. Jun. 2011;34(6):1277-83. KQ1E7, KQ2E7. [pmid: 21515838].
19 Rose PW, Watson EK, Jenkins LS. Aspirin for prevention of cancer and cardiovascular disease. British Journal of General Practice. Jun. 2011;61(587):412-5. KQ1E4. [pmid: 21801534].
20 RUDNICKA AR, MT-ISA S, Meade TW. Associations of plasma fibrinogen and factor VII clotting activity with coronary heart disease and stroke: prospective cohort study from the screening phase of the Thrombosis Prevention Trial. Journal of Thrombosis and Haemostasis. Nov. 1. 2006;4(11):2405-10. KQ1E7, KQ2E7. [pmid: 17002654].
21 Saito Y, Morimoto T, Ogawa H, et al. Low-dose aspirin therapy in patients with type 2 diabetes and reduced glomerular filtration rate: subanalysis from the JPAD trial. Diabetes Care. Feb. 2011;34(2):280-5. KQ1E7, KQ2E7. [pmid: 21270185].
22 Scheiman JM, Devereaux PJ, Herlitz J, et al. Prevention of peptic ulcers with esomeprazole in patients at risk of ulcer development treated with low-dose acetylsalicylic acid: a randomised, controlled trial (OBERON). Heart. May. 2011;97(10):797-802. KQ2E2a. [pmid: 21415072].
23 Scheiman JM, Herlitz J, Veldhuyzen van Zanten SJ, et al. Esomeprazole for prevention and resolution of upper gastrointestinal symptoms in patients treated with low-dose acetylsalicylic acid for cardiovascular protection: the OBERON trial. Journal of Cardiovascular Pharmacology. Mar. 2013;61(3):250-7. KQ2E2a. [pmid: 23188121].
24 Shiotani A, Haruma K, Nishi R, et al. Randomized, double-blind, pilot study of geranylgeranylacetone versus placebo in patients taking low-dose enteric-coated aspirin. Low-dose aspirin-induced small bowel damage. Scandinavian Journal of Gastroenterology. Mar. 2010;45(3):292-8. KQ2E5a. [pmid: 19968611].
25 Sirois C, Moisan J, Poirier P, et al. Myocardial infarction and gastro-intestinal bleeding risks associated with aspirin use among elderly individuals with type 2 diabetes. Ann Med. 2014. May. 2. KQ2E4. [pmid: 24785356].
26 Soejima H, Ogawa H. Investigation of the effects of low dose aspirin therapy on primary and secondary prevention of cardiovascular disease. Nihon rinsho Japanese journal of clinical medicine. 2010;68:882-6. KQ1E9. [pmid: 20446587].
27 Steinhubl SR, Bhatt DL, Brennan DM, et al. Aspirin to prevent cardiovascular disease: the association of aspirin dose and clopidogrel with thrombosis and bleeding. [Summary for patients in Ann Intern Med. 2009 Mar 17;150(6):I-22; PMID: 19293067]. Annals of Internal Medicine. Mar. 17. 2009;150(6):379-86. KQ2E5d. [pmid: 19293071].
28 Sugano K, Matsumoto Y, Itabashi T, et al. Lansoprazole for secondary prevention of gastric or duodenal ulcers associated with long-term low-dose aspirin therapy: results of a prospective, multicenter, double-blind, randomized, double-dummy, active-controlled trial. Journal of Gastroenterology. Jun. 2011;46(6):724-35. KQ2E2a. [pmid: 21499703].
29 Tagliabue L, Dipaola F, Perego F, et al. Aspirin for the primary prevention of cardiovascular diseases. Intern Emerg Med. Aug. 2012;7(4):375-9. KQ1E4, KQ2E4. [pmid: 22669555].
30 Taha AS, McCloskey C, Prasad R, et al. Famotidine for the prevention of peptic ulcers and oesophagitis in patients taking low-dose aspirin (FAMOUS): a phase III, randomised, double-blind, placebo-controlled trial. Lancet. Jul. 11. 2009;374(9684):119-25. KQ2E2a. [pmid: 19577798].
31 Uemura N, Sugano K, Hiraishi H, et al. Risk factor profiles, drug usage, and prevalence of aspirin-associated gastroduodenal injuries among high-risk cardiovascular Japanese patients: the results from the MAGIC study. J Gastroenterol. 2013. Jun. 12. KQ2E2a. [pmid: 23754512].
32 Welin L, Wilhelmsen L, Bjornberg A, et al. Aspirin increases mortality in diabetic patients without cardiovascular disease: a Swedish record linkage study. Pharmacoepidemiology & Drug Safety. Dec. 2009;18(12):1143-9. KQ1E3, KQ2E3. [pmid: 19672841].
33 Zanchetti A, Hansson L, Dahlof B. Effects of individual risk factors on the incidence of cardiovascular events in the treated hypertensive patients of the Hypertension Optimal Treatment Study. HOT Study Group. J Hypertens. Jun. 2001;19(6):1149-59. KQ1E7, KQ2E7. [pmid: 11403365].
34 Zanchetti A, Hansson L, Menard J, et al. Risk assessment and treatment benefit in intensively treated hypertensive patients of the hypertension Optimal Treatment (HOT) study. J Hypertens. Apr. 2001;19(4):819-25. KQ1E7, KQ2E7. [pmid: 11330886].