# Detailed Methods

## Systematic Reviews Literature Search Strategy

### BMJ Clinical Evidence - searched on 4/26/2013

Most specific results found when search limited to “aspirin” and filtered by “systematic reviews”. Large set of results retrieved; all were secondary prevention references.

### Cochrane Database of Systematic Reviews search strategy- searched on 4/29/13

#1 Aspirin or “acetylsalicylic acid” or Salicylate*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews (Reviews and Protocols)
#2 coronary or angina or “cardiac arrest” or “cardiac death” or myocardial or heart near attack* or “heart arrest”:ti,ab,kw from 2008 to 2013, in Cochrane Reviews (Reviews and Protocols)
#3 Cardiovascular next Disease* or Heart next Disease*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews (Reviews and Protocols)
#4 vascular next disease* or stroke or brain next infarction* or “brain stem” near infarction*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews (Reviews and Protocols)
#5 “Lateral Medullary Syndrome” or Cerebral near infarction* or Dementia near Multi-Infarct*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews (Reviews and Protocols)
#6 Cerebrovascular next disease* or Cerebrovascular next disorder*:ti,ab,kw from 2008 to 2013, in Cochrane Reviews (Reviews and Protocols)
#7 #2 or #3 or #4 or #5 or #6 from 2008 to 2013, in Cochrane Reviews
#8 #1 and #7 from 2008 to 2013, in Cochrane Reviews

### Database of Abstracts of Reviews of Effects search strategy- searched on 4/29/13

1. (aspirin ) OR (acetylsalicylic ADJ acid) OR (salicylate*) IN DARE FROM 2008 TO 2013
2. (coronary) OR (angina ) OR (cardiac adj arrest) OR (cardiac adj death) OR (myocardial ) IN DARE FROM 2008 TO 2013
3. (heart adj attack*) OR (heart adj arrest) OR (Cardiovascular adj Disease*) OR (Heart adj Disease*) OR (vascular adj disease*) IN DARE FROM 2008 TO 2013
4. (stroke) OR (brain adj infarction* ) OR ( brain near infarction*) OR (Lateral adj Medullary ) OR (Cerebral near infarction*) IN DARE FROM 2008 TO 2013
5. (Dementia next Multi-Infarct*) OR (Cerebrovascular adj disease*) OR (Cerebrovascular adj disorder*) IN DARE FROM 2008 TO 2013
6. #2 OR #3 OR #4 OR #5
7. #1 AND #6

### National Institute for Health and Clinical Excellence search strategy for “Guidance” Reports - searched on 4/26/2013

53 results for “aspirin” limited to “Guidance reports”. Results retrieved all were secondary prevention references.

### PubMed search strategy - searched on 4/29/13

#24 #14 OR #23 Filters: Publication date from 2008/01/01; English
#23 #19 AND prevent*[tiab] AND (publisher[sb] OR in process[sb] OR pubmednotmedline[sb]) Filters: Publication date from 2008/01/01; English
#22 #19 AND prevent*[tiab] AND (publisher[sb] OR in process[sb] OR pubmednotmedline[sb]) Filters: English
#21 #19 AND prevent*[tiab] AND (publisher[sb] OR in process[sb] OR pubmednotmedline[sb])
#20 #19 AND prevent*[tiab]
#19 #17 AND #18 AND systematic[sb]
#18 Aspirin[tiab] OR “acetylsalicylic acid”[tiab] OR Salicylate*[tiab]
#17 #15 OR #16
#16 stroke[tiab] OR cerebrovascular disease*[tiab] OR cerebrovascular disorder*[tiab]
#15 cardiovascular disease*[tiab] OR heart disease*[tiab] OR “myocardial infarction”[tiab] OR “heart arrest”[tiab] OR “myocardial ischemia”[tiab] OR “myocardial ischaemia”[tiab] OR “coronary artery disease”[tiab] OR heart attack*[tiab]
#14 #10 AND #11 AND systematic[sb] Filters: Publication date from 2008/01/01; English
#13 #10 AND #11 AND systematic[sb] Filters: English
#12 #10 AND #11
#11 “prevention and control” [Subheading] OR prevent*[tiab]
#10 #8 AND #9
#9 “Aspirin”[Mesh] OR “Salicylates”[Mesh:NoExp]
#8 #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7
#7 “Dementia, Multi-Infarct”[Mesh] OR “Infarction, Anterior Cerebral Artery”[Mesh] OR “Infarction, Middle Cerebral Artery”[Mesh] OR “Infarction, Posterior Cerebral Artery”[Mesh] OR “Stroke, Lacunar”[Mesh]
#6 “Vascular Diseases”[Mesh:NoExp] OR “Stroke”[Mesh:NoExp] OR “Brain Infarction”[Mesh:NoExp] OR “Brain Stem Infarctions”[Mesh:NoExp] OR “Lateral Medullary Syndrome”[Mesh] OR “Cerebral Infarction”[Mesh:NoExp]
#5 “No-Reflow Phenomenon”[Mesh] OR “Shock, Cardiogenic”[Mesh] OR “Myocardial Reperfusion Injury”[Mesh] OR “Myocardial Stunning”[Mesh]
#4 “Coronary Thrombosis”[Mesh] OR “Myocardial Infarction”[Mesh:NoExp] OR “Anterior Wall Myocardial Infarction”[Mesh] OR “Inferior Wall Myocardial Infarction”[Mesh] OR “Myocardial Stunning”[Mesh]
#3 “Coronary Disease”[Mesh:NoExp] OR “Coronary Artery Disease”[Mesh] OR “Coronary Occlusion”[Mesh] OR “Coronary Stenosis”[Mesh:NoExp] OR “Coronary Restenosis”[Mesh]
#2 “Myocardial Ischemia”[Mesh:NoExp] OR “Acute Coronary Syndrome”[Mesh:NoExp] OR “Angina Pectoris”[Mesh:NoExp] OR “Angina, Stable”[Mesh] OR “Angina, Unstable”[Mesh:NoExp] OR “Angina Pectoris, Variant”[Mesh] OR “Microvascular Angina”[Mesh]
#1 “Cardiovascular Diseases”[Mesh:NoExp] OR “Heart Diseases”[Mesh:NoExp] OR “Heart Arrest”[Mesh:NoExp]OR “Death, Sudden, Cardiac”[Mesh] OR “Out-of-Hospital Cardiac Arrest”[Mesh]

## Search Strategies to Identify Relevant Literature for Key Questions 1 and 2

Key
- / = MeSH subject heading
- $ = truncation
- * = truncation
- ti = word in title
- ab = word in abstract

### PUBMED- [publisher supplied references only]

#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #3 AND #4 AND publisher[sb] Filters: Publication date from 2008/01/01 to 2013/12/31
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search Aspirin[tiab] OR “acetylsalicylic acid”[tiab] OR Salicylate*[tiab]
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #1 OR #2
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search stroke[tiab] OR cerebrovascular disease*[tiab] OR cerebrovascular disorder*[tiab] OR brain infarction*[tiab] OR cerebral infarction*[tiab] OR artery infarction*[tiab] OR “coronary thrombosis”[tiab] OR “coronary occlusion”[tiab] OR “cardiogenic shock”[tiab] OR “myocardial reperfusion”[tiab] OR “myocardial stunning”[tiab] OR “lateral medullary syndrome”[tiab]
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search cardiovascular disease*[tiab] OR heart disease*[tiab] OR coronary disease*[tiab] OR vascular disease*[tiab] OR “myocardial infarction”[tiab] OR “cardiac arrest”[tiab] OR “heart arrest”[tiab] OR heart attack*[tiab] OR “myocardial ischemia”[tiab] OR “myocardial ischaemia”[tiab] OR “coronary artery disease”[tiab] OR “acute coronary syndrome”[tiab] OR angina[tiab] OR “coronary restenosis”[tiab] OR “coronary stenosis”[tiab]

### MEDLINE

Database: Ovid MEDLINE(R) without Revisions <1996 to August Week 4 2013>, Ovid MEDLINE(R) Daily Update <September 04, 2013>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <September 04, 2013>

Search Strategy:

----------------------------------------------------------------------------------------

1. Cardiovascular Diseases/ (69908)
2. Heart Diseases/ (22607)
3. Heart Arrest/ (11085)
4. Death, Sudden, Cardiac/ (9037)
5. Out-of-Hospital Cardiac Arrest/ (636)
6. Myocardial Ischemia/ (25293)
7. Acute Coronary Syndrome/ (6366)
8. Angina Pectoris/ (8885)
9. Angina, Stable/ (251)
10. Angina, Unstable/ (5786)
11. Angina Pectoris, Variant/ (442)
12. Microvascular Angina/ (681)
13. Coronary Disease/ (43610)
14. Coronary Artery Disease/ (31368)
15. Coronary Occlusion/ (1006)
16. Coronary Stenosis/ (7518)
17. Coronary Restenosis/ (5975)
18. Coronary Thrombosis/ (4237)
19. Myocardial Infarction/ (65360)
20. Anterior Wall Myocardial Infarction/ (160)
21. Inferior Wall Myocardial Infarction/ (96)
22. No-Reflow Phenomenon/ (197)
23. Shock, Cardiogenic/ (2740)
24. Myocardial Reperfusion Injury/ (7999)
25. Myocardial Stunning/ (1700)
26. Vascular Diseases/ (9327)
27. Stroke/ (52363)
28. Brain Infarction/ (2974)
29. Brain Stem Infarctions/ (515)
30. Lateral Medullary Syndrome/ (255)
31. Cerebral Infarction/ (10099)
32. Infarction, Anterior Cerebral Artery/ (161)
33. Infarction, Middle Cerebral Artery/ (4996)
34. Infarction, Posterior Cerebral Artery/ (198)
35. Stroke, Lacunar/ (108)
36. cardiovascular disease$.ti,ab. (77289)
37. heart disease$.ti,ab. (71714)
38. myocardial infarction.ti,ab. (79396)
39. heart arrest.ti,ab. (170)
40. myocardial ischemia.ti,ab. (11761)
41. myocardial ischaemia.ti,ab. (2176)
42. coronary artery disease.ti,ab. (40330)
43. heart attack$.ti,ab. (2841)
44. stroke.ti,ab. (105225)
45. cerebrovascular disease$.ti,ab. (8757)
46. cerebrovascular disorder$.ti,ab. (698)
47. cardiac arrest.ti,ab. (12605)
48. acute coronary syndrome.ti,ab. (9561)
49. angina pectoris.ti,ab. (6476)
50. stable angina.ti,ab. (3827)
51. unstable angina.ti,ab. (7250)
52. microvascular angina.ti,ab. (111)
53. coronary occlusion.ti,ab. (2109)
54. coronary disease.ti,ab. (6101)
55. coronary thrombosis.ti,ab. (668)
56. coronary stenosis.ti,ab. (2187)
57. coronary restenosis.ti,ab. (335)
58. myocardial stunning.ti,ab. (752)
59. no-reflow phenomenon.ti,ab. (504)
60. cardiogenic shock.ti,ab. (4318)
61. myocardial reperfusion.ti,ab. (971)
62. vascular disease$.ti,ab. (20623)
63. brain infarction$.ti,ab. (1306)
64. brain stem infarction$.ti,ab. (100)
65. artery infarction$.ti,ab. (413)
66. cerebral infarction$.ti,ab. (6165)
67. lateral medullary syndrome.ti,ab. (76)
68. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56 or 57 or 58 or 59 or 60 or 61 or 62 or 63 or 64 or 65 or 66 or 67 (512035)
69. Aspirin/ (17711)
70. Salicylates/ (2783)
71. aspirin.ti,ab. (22553)
72. acetylsalicylic acid.ti,ab. (3367)
73. salicylate$.ti,ab. (3850)
74. 69 or 70 or 71 or 72 or 73 (34949)
75. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ (161447)
76. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt. (466852)
77. Random$.ti,ab. (528273)
78. control groups/ or double-blind method/ or single-blind method/ (91598)
79. clinical trial$.ti,ab. (162642)
80. controlled trial$.ti,ab. (93370)
81. 75 or 76 or 77 or 78 or 79 or 80 (966067)
82. 68 and 74 and 81 (5025)
83. limit 82 to (english language and yr=“2008 -Current”) (1603)
84. remove duplicates from 83 (1603)

### Cochrane Central Register of Controlled Clinical Trials (CENTRAL) Issue 8 of 12, August 2013

#1 Aspirin:ti,ab,kw from 2008 to 2013, in Trials
#2 “acetylsalicylic acid”:ti,ab,kw from 2008 to 2013, in Trials
#3 Salicylate*:ti,ab,kw from 2008 to 2013, in Trials
#4 #1 or #2 or #3 from 2008 to 2013, in Trials
#5 (coronary or angina or myocardial or “cardiac arrest” or “cardiac death” or “heart arrest”):ti,ab,kw from 2008 to 2013, in Trials
#6 (heart near attack*):ti,ab,kw from 2008 to 2013, in Trials
#7 (Cardiovascular next Disease*):ti,ab,kw from 2008 to 2013, in Trials
#8 (Heart next Disease*):ti,ab,kw from 2008 to 2013, in Trials
#9 (vascular next disease*):ti,ab,kw from 2008 to 2013, in Trials
#10 stroke:ti,ab,kw from 2008 to 2013, in Trials
#11 (brain next infarction*):ti,ab,kw from 2008 to 2013, in Trials
#12 (“brain stem” near infarction*):ti,ab,kw from 2008 to 2013, in Trials
#13 “Lateral Medullary Syndrome”:ti,ab,kw from 2008 to 2013, in Trials
#14 (Cerebral near infarction*):ti,ab,kw from 2008 to 2013, in Trials
#15 (Cerebrovascular next disease*):ti,ab,kw from 2008 to 2013, in Trials
#16 (Cerebrovascular next disorder*):ti,ab,kw from 2008 to 2013, in Trials
#17 #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 from 2008 to 2013, in Trials
#18 #4 and #17 from 2008 to 2013, in Trials

Appendix B Figure 1 Literature Flow Diagram

Appendix B Figure 1 displays the literature search results and article flow for the review. A total of 4,589 articles were identified through database searching and 34 articles were identified through other sources. 2,853 articles were screened after duplicates were removed. 61 full-text articles were assessed for eligibility. 27 articles (10 trials) were included for KQ1. 26 articles (9 trials) were included for KQ2.

Appendix B Table 1 Inclusion and Exclusion Criteria

| Inclusion | Exclusion
Aim | Primary prevention of cardiovascular disease: MI, stroke, death from MI or stroke, or all-cause mortality | Secondary and tertiary prevention of MI, stroke, death from MI or stroke, or all-cause mortality
Populations | Adults (age ≥40 years) without known CVD | Non-human populations; other selected non-generalizable populations; patients with existing CVD diagnosis or history (heart failure, previous stroke, previous MI, transient ischemic attack, angina, or previous bypass or angioplasty); patients with atrial fibrillation; patients with familial hypercholesterolemia; patients with hypercoagulable disorders; children and young adults (age <40 years)
Interventions | Regular oral aspirin use (minimum of 75 mg every other day) | Non-aspirin anti-thrombotic medications; Studies where there is no information on dose; Interventions limited to irregular or occasional use only; Studies in which aspirin is a co-treatment; Nonoral, nontablet forms of aspirin
Comparisons | Placebo or no treatment | Any active substance or intervention (e.g., non-aspirin medication, dietary supplements, dietary change, weight loss)
Outcomes | KQ1: MI (coronary events, sudden death), stroke, death from MI or stroke, all-cause mortality, or quality of life KQ2: Gastrointestinal bleeding, hemorrhagic stroke, or other serious harms (e.g. age-related macular degeneration) | KQ1: intermediate markers of CVD (e.g. calcium scores, intimal thickness, asymptomatic electrocardiography findings); intermediate markers of platelet function or clotting (e.g. in vitro clotting time, platelet aggregation) KQ2: intermediate markers of platelet function or clotting
Study Designs | KQ 1: RCTs, CCT KQ 2: RCTs, CCTs, observational studies (cohort, case-control) | KQ1: Observational studies (case control, case studies, or case series) KQ 2: Case-control, case studies, or case series
Duration | ≥1 year exposure to intervention, ≥1 year followup | < 1 year exposure, <1 year followup
Setting | Trials conducted in countries listed as “high” human development on Human Development Index (over .90): Andorra, Argentina, Australia, Austria, Barbados, Belgium, Brunei Darussalam, Canada, Chile, Croatia, Cyprus, Czech Republic, Denmark, Estonia, Finland, France, Germany, Greece, Hong Kong, Hungary, Iceland, Ireland, Israel, Italy, Japan, Korea, Latvia, Liechtenstein, Lithuania, Luxembourg, Malta, Netherlands, New Zealand, Norway, Poland, Portugal, Qatar, Seychelles, Singapore, Slovakia, Slovenia, Spain, Sweden, Switzerland, United Arab Emirates, United Kingdom, United States
Study Quality | Good & fair quality according to USPSTF criteria | Poor quality according to USPSTF criteria
Language | English | Non-English studies

Abbreviations: CCT = controlled clinical trial; CVD = cardiovascular disease; KQ = Key Question; MI = myocardial infarction; RCT = randomized controlled trial; USPSTF = US Preventive Services Task Force

Appendix B Table 2 Quality Assessment Criteria

Design | USPSTF quality rating criteria47 | NICE methodology checklists48
Randomized controlled trials (RCTs) | - Initial assembly of comparable groups employs adequate randomization, including first concealment and whether potential confounders were distributed equally among groups; - Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination); - Important differential loss to followup or overall high loss to followup; - Measurements: equal, reliable, and valid (includes masking of outcome assessment); - Clear definition of the interventions; - All important outcomes considered | - The study addresses an appropriate and clearly focused question; - The assignment of subjects to treatment groups is randomized; - An adequate concealment method is used; - Subjects and investigators are kept ‘blind’ about treatment allocation; - The treatment and control groups are similar at the start of the trial; - The only difference between groups is the treatment under investigation; - All relevant outcomes are measured in a standard, valid and reliable way; - What percentage of the individuals or clusters recruited into each treatment arm of the study dropped out before the study was completed?; - All the subjects are analyzed in the groups to which they were randomly allocated (often referred to as intention-to-treat analysis); - Where the study is carried out at more than one site, results are comparable for all sites