# References

1 American Thoracic Society, European Respiratory Society. Standards for the Diagnosis and Management of Patients with COPD. 2004. PMID: None.
2 Celli BR, Macnee W. Standards for the diagnosis and treatment of patients with COPD: a summary of the ATS/ERS position paper. Eur Respir J. Jun. 2004;23(6):932-46. [pmid: 15219010].
3 National Institute for Health and Clinical Excellence. Chronic obstructive pulmonary disease: management of chronic obstructive pulmonary disease in adults in primary and secondary care. 2010. PMID: None.
4 Qaseem A, Wilt TJ, Weinberger SE, et al. Diagnosis and management of stable chronic obstructive pulmonary disease: a clinical practice guideline update from the American College of Physicians, American College of Chest Physicians, American Thoracic Society, and European Respiratory Society. Ann Intern Med. Aug. 2. 2011;155(3):179-91. [pmid: 21810710].
5 Wilt TJ, Niewoehner D, MacDonald R, et al. Management of stable chronic obstructive pulmonary disease: a systematic review for a clinical practice guideline. Ann Intern Med. Nov. 6. 2007;147(9):639-53. [pmid: 17975187].
6 Global Initiative for Chronic Obstructive Lung Disease. Global Strategy for the Diagnosis, Management, and Prevention of Chronic Obstructive Pulmonary Disease. 2015. PMID: None.
7 Pellegrino R, Viegi G, Brusasco V, et al. Interpretative strategies for lung function tests. Eur Respir J. Nov. 2005;26(5):948-68. [pmid: 16264058].
8 Cerveri I, Corsico AG, Accordini S, et al. Underestimation of airflow obstruction among young adults using FEV1/FVC <70% as a fixed cut-off: a longitudinal evaluation of clinical and functional outcomes. Thorax. Dec. 2008;63(12):1040-5. [pmid: 18492741].
9 van Dijk WD, Gupta N, Tan WC, et al. Clinical Relevance of Diagnosing COPD by Fixed Ratio or Lower Limit of Normal: A Systematic Review. COPD. 2013. Jul. 17. [pmid: 23862613].
10 Runarsdottir SB, Gudmundsson G, Aspelund T, et al. Prevalence of airflow obstruction in nonsmoking older individuals using different spirometric criteria: the AGES Reykjavik Study. Copd: Journal of Chronic Obstructive Pulmonary Disease. Aug. 2013;10(4):493-9. [pmid: 23875743].
11 Bhatt SP, Sieren JC, Dransfield MT, et al. Comparison of spirometric thresholds in diagnosing smoking-related airflow obstruction. Thorax. May. 2014;69(5):410-5. [pmid: 23525095].
12 Swanney MP, Ruppel G, Enright PL, et al. Using the lower limit of normal for the FEV1/FVC ratio reduces the misclassification of airway obstruction. Thorax. Dec. 2008;63(12):1046-51. [pmid: 18786983].
13 Miller MR, Quanjer PH, Swanney MP, et al. Interpreting lung function data using 80% predicted and fixed thresholds misclassifies more than 20% of patients. [Erratum appears in Chest. 2011 Mar;139(3):733]. Chest. Jan. 2011;139(1):52-9. [pmid: 20522571].
14 Aggarwal AN, Gupta D, Agarwal R, et al. Comparison of the lower confidence limit to the fixed-percentage method for assessing airway obstruction in routine clinical practice. Respiratory Care. Nov. 2011;56(11):1778-84. [pmid: 21605485].
15 Culver BH. How should the lower limit of the normal range be defined?. Respiratory Care. Jan. 2012;57(1):136-45. [pmid: 22222132].
16 Mannino DM, Sonia BA, Vollmer WM. Chronic obstructive pulmonary disease in the older adult: what defines abnormal lung function?. Thorax. Mar. 2007;62(3):237-41. [pmid: 17090573].
17 Celli BR, Halbert RJ, Isonaka S, et al. Population impact of different definitions of airway obstruction. Eur Respir J. Aug. 2003;22(2):268-73. [pmid: 12952259].
18 Ford ES, Croft JB, Mannino DM, et al. COPD surveillance--United States, 1999–2011. Chest. Jul. 2013;144(1):284-305. [pmid: 23619732].
19 Kochanek KD, Murphy SL, Xu J, et al. Mortality in the United States, 2013. NCHS Data Brief. Dec. 2014;(178):1-8. [pmid: 25549183].
20 Mannino DM. Counting Costs in COPD: What Do the Numbers Mean?. Chest. Jan. 1. 2015;147(1):3-5. [pmid: 25560850].
21 Mannino DM, Gagnon RC, Petty TL, et al. Obstructive lung disease and low lung function in adults in the United States: data from the National Health and Nutrition Examination Survey, 1988–1994. Arch Intern Med. Jun. 12. 2000;160(11):1683-9. [pmid: 10847262].
22 Mannino DM, Ford ES, Redd SC. Obstructive and restrictive lung disease and markers of inflammation: data from the Third National Health and Nutrition Examination. Am J Med. Jun. 15. 2003;114(9):758-62. [pmid: 12829203].
23 Centers for Disease Control and Prevention. COPD Data and Statistics. 2013.
24 Tilert T, Paulose-Ram R, Brody DJ. Lung obstruction among adults aged 40–79: United States, 2007–2012. NCHS Data Brief. Jan. 2015;(180):1-8. [pmid: 25569190].
25 Tilert T, Dillon C, Paulose-Ram R, et al. Estimating the U.S. prevalence of chronic obstructive pulmonary disease using pre- and post-bronchodilator spirometry: the National Health and Nutrition Examination Survey (NHANES) 2007–2010. Respir Res. 2013;14:103. [pmid: 24107140].
26 Centers for Disease Control and Prevention. Chronic Obstructive Pulmonary Disease Among Adults - United States, 2011. 2012;61(46). PMID: None.
27 American Lung Association. Chronic Obstructive Pulmonary Disease (COPD) Fact Sheet. 2013. Accessed January 3, 2014. PMID: None.
28 Anto JM, Vermeire P, Vestbo J, et al. Epidemiology of chronic obstructive pulmonary disease. Eur Respir J. May. 2001;17(5):982-94. [pmid: 11488336].
29 Bentsen SB, Miaskowski C, Rustoen T. Demographic and clinical characteristics associated with quality of life in patients with chronic obstructive pulmonary disease. Qual Life Res. Apr. 2014;23(3):991-8. [pmid: 23999743].
30 Hynninen MJ, Pallesen S, Nordhus IH. Factors affecting health status in COPD patients with co-morbid anxiety or depression. Int J Chron Obstruct Pulmon Dis. 2007;2(3):323-8. [pmid: 18229570].
31 Ferrer M, Alonso J, Morera J, et al. Chronic obstructive pulmonary disease stage and health-related quality of life. The Quality of Life of Chronic Obstructive Pulmonary Disease Study Group. Ann Intern Med. Dec. 15. 1997;127(12):1072-9. [pmid: 9412309].
32 Osman IM, Godden DJ, Friend JA, et al. Quality of life and hospital re-admission in patients with chronic obstructive pulmonary disease. Thorax. Jan. 1997;52(1):67-71. [pmid: 9039248].
33 Jones PW, Quirk FH, Baveystock CM. The St George’s Respiratory Questionnaire. Respir Med. Sep. 1991;85(Suppl B):25-31. [pmid: 1759018].
34 American Thoracic Society. St George’s Respiratory Questionnaire (SGRQ). New York, New York. American Thoracic Society. 2014.
35 Jones PW. Interpreting thresholds for a clinically significant change in health status in asthma and COPD. European Respiratory Journal. Mar. 2002;19(3):398-404. [pmid: 11936514].
36 Sichletidis L, Spyratos D, Papaioannou M, et al. A combination of the IPAG questionnaire and PiKo-6 flow meter is a valuable screening tool for COPD in the primary care setting. Primary Care Respiratory Journal. Jun. 2011;20(2):184-9. [pmid: 21597666].
37 Buffels J, Degryse J, Heyrman J, et al. Office spirometry significantly improves early detection of COPD in general practice: the DIDASCO Study. Chest. Apr. 2004;125(4):1394-9. [pmid: 15078751].
38 Tinkelman DG, Price D, Nordyke RJ, et al. COPD screening efforts in primary care: what is the yield?. Prim Care Respir J. Feb. 2007;16(1):41-8. [pmid: 17297526].
39 Frith P, Crockett A, Beilby J, et al. Simplified COPD screening: validation of the PiKo-6 in primary care. Primary Care Respiratory Journal. Jun. 2011;20(2):190-8. [pmid: 21597667].
40 Mannino DM, Watt G, Hole D, et al. The natural history of chronic obstructive pulmonary disease. Eur Respir J. Mar. 2006;27(3):627-43. [pmid: 16507865].
41 Ferdinands JM, Mannino DM. Obstructive lung disease models: what is valid?. COPD. Dec. 2008;5(6):382-93. [pmid: 19353353].
42 Stratelis G, Jakobsson P, Molstad S, et al. Early detection of COPD in primary care: screening by invitation of smokers aged 40 to 55 years. Br J Gen Pract. Mar. 2004;54(500):201-6. [pmid: 15006126].
43 Cruz A. Diagnosis of COPD. 2014.
44 Petty TL, Mannino DM. Will recommendations against spirometry make chronic obstructive pulmonary disease harder to treat?. Ann Intern Med. Oct. 7. 2008;149(7):512-3. [pmid: 18838733].
45 Gegick S, Coore HA, Bowling MR. Chronic obstructive pulmonary disease: epidemiology, management, and impact on North Carolina. N C Med J. Sep. 2013;74(5):411-4. [pmid: 24165770].
46 Hooper R, Burney P, Vollmer WM, et al. Risk factors for COPD spirometrically defined from the lower limit of normal in the BOLD project. Eur Respir J. Jun. 2012;39(6):1343-53. [pmid: 22183479].
47 Lamprecht B, McBurnie MA, Vollmer WM, et al. COPD in never smokers: results from the population-based burden of obstructive lung disease study. Chest. Apr. 2011;139(4):752-63. [pmid: 20884729].
48 Lundback B, Lindberg A, Lindstrom M, et al. Not 15 but 50% of smokers develop COPD?--Report from the Obstructive Lung Disease in Northern Sweden Studies. Respiratory Medicine. Feb. 2003;97(2):115-22. [pmid: 12587960].
49 Thun MJ, Carter BD, Feskanich D, et al. 50-year trends in smoking-related mortality in the United States. N Engl J Med. Jan. 24. 2013;368(4):351-64. [pmid: 23343064].
50 Akinbami LJ, Liu X. Chronic obstructive pulmonary disease among adults aged 18 and over in the United States, 1998–2009. NCHS Data Brief. Jun. 2011;(63):1-8. [pmid: 22142836].
51 Diaz AA, Come CE, Mannino DM, et al. Obstructive lung disease in Mexican Americans and non-Hispanic whites: an analysis of diagnosis and survival in the National Health and Nutritional Examination Survey III Follow-up Study. Chest. Feb. 2014;145(2):282-9. [pmid: 24077252].
52 Diaz-Guzman E, Mannino DM. Epidemiology and prevalence of chronic obstructive pulmonary disease. Clin Chest Med. Mar. 2014;35(1):7-16. [pmid: 24507833].
53 Smoking-attributable mortality, years of potential life lost, and productivity losses--United States, 2000–2004. MMWR Morb Mortal Wkly Rep. Nov. 14. 2008;57(45):1226-8. [pmid: 19008791].
54 Ferguson GT, Enright PL, Buist AS, et al. Office spirometry for lung health assessment in adults: a consensus statement from the National Lung Health Education Program. Respir Care. May. 2000;45(5):513-30. [pmid: 10813228].
55 Hnizdo E, Sullivan PA, Bang KM, et al. Association between chronic obstructive pulmonary disease and employment by industry and occupation in the US population: a study of data from the Third National Health and Nutrition Examination Survey. Am J Epidemiol. Oct. 15. 2002;156(8):738-46. [pmid: 12370162].
56 Levy ML, Quanjer PH, Booker R, et al. Diagnostic spirometry in primary care: Proposed standards for general practice compliant with American Thoracic Society and European Respiratory Society recommendations: a General Practice Airways Group (GPIAG)1 document, in association with the Association for Respiratory Technology & Physiology (ARTP)2 and Education for Health3 1 www.gpiag.org 2 www.artp.org 3 www.educationforhealth.org.uk. Prim Care Respir J. Sep. 2009;18(3):130-47. [pmid: 19684995].
57 Schermer TR, Jacobs JE, Chavannes NH, et al. Validity of spirometric testing in a general practice population of patients with chronic obstructive pulmonary disease (COPD). Thorax. Oct. 2003;58(10):861-6. [pmid: 14514938].
58 Enright P, Vollmer WM, Lamprecht B, et al. Quality of spirometry tests performed by 9893 adults in 14 countries: the BOLD Study. Respir Med. Oct. 2011;105(10):1507-15. [pmid: 21549584].
59 White P, Wong W, Fleming T, et al. Primary care spirometry: test quality and the feasibility and usefulness of specialist reporting. Br J Gen Pract. Sep. 2007;57(542):701-5. [pmid: 17761057].
60 Minas M, Koukosias N, Zintzaras E, et al. Prevalence of chronic diseases and morbidity in primary health care in central Greece: an epidemiological study. BMC Health Serv Res. 2010;10:252. [pmid: 20799979].
61 Hansen JG, Pedersen L, Overvad K, et al. The Prevalence of chronic obstructive pulmonary disease among Danes aged 45–84 years: population-based study. COPD. Dec. 2008;5(6):347-52. [pmid: 19353348].
62 Hardie JA, Buist AS, Vollmer WM, et al. Risk of over-diagnosis of COPD in asymptomatic elderly never-smokers. Eur Respir J. Nov. 2002;20(5):1117-22. [pmid: 12449163].
63 Dales RE, Vandemheen KL, Clinch J, et al. Spirometry in the primary care setting: influence on clinical diagnosis and management of airflow obstruction. Chest. Oct. 2005;128(4):2443-7. [pmid: 16236907].
64 Seyedmehdi SM, Attarchi M, Yazdanparast T, et al. Quality of spirometry tests and pulmonary function changes among industrial company workers in Iran: a two-year before-and-after study following an intensive training intervention. Prim Care Respir J. Mar. 2013;22(1):86-91. [pmid: 23443228].
65 Wollmer P, Engstrom G. Fixed ratio or lower limit of normal as cut-off value for FEV1/VC: an outcome study. Respiratory Medicine. Sep. 2013;107(9):1460-2. [pmid: 23845882].
66 Enright RL, Connett JE, Bailey WC. The FEV1/FEV6 predicts lung function decline in adult smokers. Respiratory Medicine. 2002;96:444-9. [pmid: 12117045].
67 Jithoo A, Enright PL, Burney P, et al. Case-finding options for COPD: results from the Burden of Obstructive Lung Disease study. European Respiratory Journal. Mar. 2013;41(3):548-55. [pmid: 22743668].
68 Wilt T, Niewoehner D, Kim C, et al. Use of Spirometry for Case Finding, Diagnosis, and Management of Chronic obstructive Pulmonary Disease (COPD). 05-E017-2. Rockville, MD. Agency for Healthcare Research and Quality. 2005. PMID: None.
69 Patel JG, Nagar SP, Dalal AA. Indirect costs in chronic obstructive pulmonary disease: A review of the economic burden on employers and individuals in the United States. Int J Chron Obstruct Pulmon Dis. 2014;9:289-300. [pmid: 24672234].
70 Decramer M, Cooper CB. Treatment of COPD: the sooner the better?. Thorax. Sep. 2010;65(9):837-41. [pmid: 20805184].
71 Kotz D, Simpson CR, Viechtbauer W, et al. Development and validation of a model to predict the 10-year risk of general practitioner-recorded COPD. NPJ Prim Care Respir Med. 2014;24:14011. [pmid: 24841327].
72 Wagena EJ, van der Meer RM, Ostelo RJ, et al. The efficacy of smoking cessation strategies in people with chronic obstructive pulmonary disease: results from a systematic review. Respir Med. Sep. 2004;98(9):805-15. [pmid: 15338790].
73 Tonnesen P, Carrozzi L, Fagerstrom KO, et al. Smoking cessation in patients with respiratory diseases: a high priority, integral component of therapy. Eur Respir J. Feb. 2007;29(2):390-417. [pmid: 17264326].
74 Jimenez-Ruiz CA, Masa F, Miravitlles M, et al. Smoking characteristics: differences in attitudes and dependence between healthy smokers and smokers with COPD. Chest. May. 2001;119(5):1365-70. [pmid: 11348940].
75 Wagena EJ, Arrindell WA, Wouters EF, et al. Are patients with COPD psychologically distressed?. Eur Respir J. Aug. 2005;26(2):242-8. [pmid: 16055871].
76 Thabane M. Smoking cessation for patients with chronic obstructive pulmonary disease (COPD): an evidence-based analysis. Ont Health Technol Assess Ser. 2012;12(4):1-50.
77 Puhan M, Scharplatz M, Troosters T, et al. Pulmonary rehabilitation following exacerbations of chronic obstructive pulmonary disease. Cochrane Database Syst Rev. 2009;(1):CD005305. [pmid: 19160250].
78 Stoller JK, Panos RJ, Krachman S, et al. Oxygen therapy for patients with COPD: current evidence and the long-term oxygen treatment trial. Chest. Jul. 2010;138(1):179-87. [pmid: 20605816].
79 Fishman A, Martinez F, Naunheim K, et al. A randomized trial comparing lung-volume-reduction surgery with medical therapy for severe emphysema. N Engl J Med. May. 22. 2003;348(21):2059-73. [pmid: 12759479].
80 Lin K, Watkins B, Johnson T, et al. Screening for chronic obstructive pulmonary disease using spirometry: summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. Apr. 1. 2008;148(7):535-43. [pmid: 18316746].
81 Shahab L, Jarvis MJ, Britton J, et al. Prevalence, diagnosis and relation to tobacco dependence of chronic obstructive pulmonary disease in a nationally representative population sample. Thorax. Dec. 2006;61(12):1043-7. [pmid: 17040932].
82 Johnston KN, Young M, Grimmer-Somers KA, et al. Why are some evidence-based care recommendations in chronic obstructive pulmonary disease better implemented than others? Perspectives of medical practitioners. Int J Chron Obstruct Pulmon Dis. 2011;6:659-67. [pmid: 22259242].
83 UK National Screening Committee. The UK NSC policy on chronic obstructive pulmonary disease. 2013. Accessed January 10, 2014. PMID: None.
84 Vollmer WM, Gislason T, Burney P, et al. Comparison of spirometry criteria for the diagnosis of COPD: results from the BOLD study. Eur Respir J. Sep. 2009;34(3):588-97. [pmid: 19460786].
85 Akpinar-Elci M, Fedan KB, Enright PL. FEV6 as a surrogate for FVC in detecting airways obstruction and restriction in the workplace. Eur Respir J. Feb. 2006;27(2):374-7. [pmid: 16452595].
86 Yawn BP, Mapel DW, Mannino DM, et al. Development of the Lung Function Questionnaire (LFQ) to identify airflow obstruction. Int J Chron Obstruct Pulmon Dis. 2010;5:1-10. [pmid: 20368906].
87 Jones PW, Harding G, Berry P, et al. Development and first validation of the COPD Assessment Test. Eur Respir J. Sep. 2009;34(3):648-54. [pmid: 19720809].
88 Martinez FJ, Raczek AE, Seifer FD, et al. Development and initial validation of a self-scored COPD Population Screener Questionnaire (COPD-PS). COPD. Apr. 2008;5(2):85-95. [pmid: 18415807].
89 Kotz D, Nelemans P, van Schayck CP, et al. External validation of a COPD diagnostic questionnaire. Eur Respir J. Feb. 2008;31(2):298-303. [pmid: 17959636].
90 National Heart LaBI. A case-finding strategy for moderate-to-severe COPD in the United States: executive summary. 2012. PMID: None.
91 Perez-Padilla R, Vollmer WM, Vazquez-Garcia JC, et al. Can a normal peak expiratory flow exclude severe chronic obstructive pulmonary disease?. Int J Tuberc Lung Dis. Mar. 2009;13(3):387-93. [pmid: 19275802].
92 Nelson SB, LaVange LM, Nie Y, et al. Questionnaires and pocket spirometers provide an alternative approach for COPD screening in the general population. Chest. Aug. 2012;142(2):358-66. [pmid: 22194590].
93 Hanania NA, Mannino DM, Yawn BP, et al. Predicting risk of airflow obstruction in primary care: Validation of the lung function questionnaire (LFQ). Respiratory Medicine. Aug. 2010;104(8):1160-70. [pmid: 20226647].
94 Price DB, Tinkelman DG, Halbert RJ, et al. Symptom-based questionnaire for identifying COPD in smokers. Respiration. 2006;73(3):285-95. [pmid: 16330875].
95 Price DB, Tinkelman DG, Nordyke RJ, et al. Scoring system and clinical application of COPD diagnostic questionnaires. Chest. Jun. 2006;129(6):1531-9. [pmid: 16778271].
96 Screening for chronic obstructive pulmonary disease using spirometry: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. Apr. 1. 2008;148(7):529-34. [pmid: 18316747].
97 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. Apr. 2001;2043(3 Suppl):21-35. [pmid: 11306229].
98 Lin K, Watkins B, Johnson T, et al. Screening for Chronic Obstructive Pulmonary Disease Using Spirometry: Summary of the Evidence for the US Preventive Services Task. 08-05113-EF-1. Rockville, MD. Agency for Healthcare Research and Quality. 2008. NBK33976 [bookaccession]. [pmid: 20722155].
99 Pauwels RA, Buist AS, Ma P, et al. Global strategy for the diagnosis, management, and prevention of chronic obstructive pulmonary disease: National Heart, Lung, and Blood Institute and World Health Organization Global Initiative for Chronic Obstructive Lung Disease (GOLD): executive summary. Respir Care. Aug. 2001;46(8):798-825. [pmid: 11463370].
100 Bize R, Burnand B, Mueller Y, et al. Biomedical risk assessment as an aid for smoking cessation. Cochrane Database of Systematic Reviews. 2012. [pmid: 23235615].
101 Maltais F, Dennis N, Chan CK. Rationale for earlier treatment in COPD: a systematic review of published literature in mild-to-moderate COPD. COPD. Feb. 2013;10(1):79-103. [pmid: 23272663].
102 McIvor RA, Tunks M, Todd DC. Copd Clin Evid (Online). 2011;2011. [pmid: 21639960].
103 Wallace B, Small K, Brodley C. Deploying an interactive machine learning system in an evidence-based practice center: abstrackr. 2012. PMID: None.
104 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force procedure manual. AHRQ Publication No. 08-05118-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2008. PMID: None.
105 National Institute for Health and Clinical Excellence. The Guidelines Manual. London. National Institute for Health and Clinical Excellence. 2006. PMID: None.
106 Whiting P, Rutjes AW, Reitsma JB, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. Nov. 10. 2003;3:25. [pmid: 14606960].
107 Whiting PF, Rutjes AW, Westwood ME, et al. QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. Oct. 18. 2011;155(8):529-36. [pmid: 22007046].
108 Miller MR, Hankinson J, Brusasco V, et al. Standardisation of spirometry. Eur Respir J. Aug. 2005;26(2):319-38. [pmid: 16055882].
109 Miller MR, Crapo R, Hankinson J, et al. General considerations for lung function testing. Eur Respir J. Jul. 2005;26(1):153-61. [pmid: 15994402].
110 Dirven JA, Tange HJ, Muris JW, et al. Early detection of COPD in general practice: implementation, workload and socioeconomic status. A mixed methods observational study. Prim Care Respir J. Sep. 2013;22(3):338-43. [pmid: 23966213].
111 Mintz ML, Yawn BP, Mannino DM, et al. Prevalence of airway obstruction assessed by lung function questionnaire. Mayo Clinic Proceedings. May. 2011;86(5):375-81. [pmid: 21531880].
112 Tsukuya G, Matsumoto K, Fukuyama S, et al. Validation of a COPD screening questionnaire and establishment of diagnostic cut-points in a Japanese general population: The Hisayama study. Allergology International. Jan. 2015;64(1):49-53. [pmid: 25572558].
113 Raghavan N, Lam YM, Webb KA, et al. Components of the COPD Assessment Test (CAT) associated with a diagnosis of COPD in a random population sample. Copd: Journal of Chronic Obstructive Pulmonary Disease. Apr. 2012;9(2):175-83. [pmid: 22409441].
114 Hill K, Hodder R, Blouin M, et al. Identifying adults at risk of COPD who need confirmatory spirometry in primary care: Do symptom-based questions help?. Canadian Family Physician. Feb. 2011;57(2):e51-e57. [pmid: 21642706].
115 Stanley AJ, Hasan I, Crockett AJ, et al. Validation of the COPD Diagnostic Questionnaire in an Australian general practice cohort: a cross-sectional study. Primary Care Respiratory Journal. Mar. 2014;23(1):92-7. [pmid: 24570082].
116 Stanley AJ, Hasan I, Crockett AJ, et al. COPD Diagnostic Questionnaire (CDQ) for selecting at-risk patients for spirometry: a cross-sectional study in Australian general practice. NPJ Primary Care Respiratory Medicine. 2014;24:14024.
117 Yawn BP, Duvall K, Peabody J, et al. The Impact of Screening Tools on Diagnosis of Chronic Obstructive Pulmonary Disease in Primary Care. Am J Prev Med. 2014. Sep. 15. [pmid: 25241196].
118 Thorn J, Tilling B, Lisspers K, et al. Improved prediction of COPD in at-risk patients using lung function pre-screening in primary care: a real-life study and cost-effectiveness analysis. Primary Care Respiratory Journal. Jun. 2012;21(2):159-66. [pmid: 22270480].
119 Parkes G, Greenhalgh T, Griffin M, et al. Effect on smoking quit rate of telling patients their lung age: the Step2quit randomised controlled trial. BMJ. Mar. 15. 2008;336(7644):598-600. [pmid: 18326503].
120 Risser NL, Belcher DW. Adding spirometry, carbon monoxide, and pulmonary symptom results to smoking cessation counseling: a randomized trial. J Gen Intern Med. Jan. 1990;5(1):16-22. [pmid: 2405112].
121 Kotz D, Wesseling G, Huibers MJ, et al. Efficacy of confronting smokers with airflow limitation for smoking cessation. European Respiratory Journal. Apr. 2009;33(4):754-62. [pmid: 19129277].
122 Sippel JM, Osborne ML, Bjornson W, et al. Smoking cessation in primary care clinics. J Gen Intern Med. Nov. 1999;14(11):670-6. [pmid: 10571715].
123 McClure JB, Ludman EJ, Grothaus L, et al. Impact of a brief motivational smoking cessation intervention the Get PHIT randomized controlled trial. Am J Prev Med. Aug. 2009;37(2):116-23. [pmid: 19524389].
124 Kotz D, Vos R, Huibers MJ. Ethical analysis of the justifiability of labelling with COPD for smoking cessation. Journal of Medical Ethics. Sep. 2009;35(9):534-40. [pmid: 19717691].
125 Decramer M, Dahl R, Kornmann O, et al. Effects of long-acting bronchodilators in COPD patients according to COPD severity and ICS use. Respir Med. Feb. 2013;107(2):223-32. [pmid: 23219347].
126 Jenkins CR, Jones PW, Calverley PM, et al. Efficacy of salmeterol/fluticasone propionate by GOLD stage of chronic obstructive pulmonary disease: analysis from the randomised, placebo-controlled TORCH study. Respiratory Research. 2009;10:59. [pmid: 19566934].
127 Decramer M, Celli B, Kesten S, et al. Effect of tiotropium on outcomes in patients with moderate chronic obstructive pulmonary disease (UPLIFT): a prespecified subgroup analysis of a randomised controlled trial. Lancet. Oct. 3. 2009;374(9696):1171-8. [pmid: 19716598].
128 Niewoehner DE, Rice K, Cote C, et al. Prevention of exacerbations of chronic obstructive pulmonary disease with tiotropium, a once-daily inhaled anticholinergic bronchodilator: a randomized trial. Ann Intern Med. Sep. 6. 2005;143(5):317-26. [pmid: 16144890].
129 Tonnel AB, Perez T, Grosbois JM, et al. Effect of tiotropium on health-related quality of life as a primary efficacy endpoint in COPD. Int J Chron Obstruct Pulmon Dis. 2008;3(2):301-10. [pmid: 18686739].
130 Pauwels RA, Löfdahl CGr, Laitinen LA, et al. Long-Term Treatment with Inhaled Budesonide in Persons with Mild Chronic Obstructive Pulmonary Disease Who Continue Smoking. New England Journal of Medicine. Jun. 24. 1999;340(25):1948-53. [pmid: 10379018].
131 Vestbo J, Sorensen T, Lange P, et al. Long-term effect of inhaled budesonide in mild and moderate chronic obstructive pulmonary disease: a randomised controlled trial. Lancet. May. 29. 1999;353(9167):1819-23. [pmid: 10359405].
132 Lapperre TS, Snoeck-Stroband JB, Gosman MM, et al. Effect of fluticasone with and without salmeterol on pulmonary outcomes in chronic obstructive pulmonary disease: a randomized trial. Ann Intern Med. Oct. 20. 2009;151(8):517-27. [pmid: 19841453].
133 Calverley PM, Rennard S, Nelson HS, et al. One-year treatment with mometasone furoate in chronic obstructive pulmonary disease. Respir Res. 2008;9:73. [pmid: 19014549].
134 Lung Healthy Study Research Group. Effect of inhaled triamcinolone on the decline in pulmonary function in chronic obstructive pulmonary disease. N Engl J Med. Dec. 28. 2000;343(26):1902-9. [pmid: 11136260].
135 Dahl R, Chung KF, Buhl R, et al. Efficacy of a new once-daily long-acting inhaled beta2-agonist indacaterol versus twice-daily formoterol in COPD. Thorax. Jun. 2010;65(6):473-9. [pmid: 20522841].
136 Donohue JF, Fogarty C, Lotvall J, et al. Once-daily bronchodilators for chronic obstructive pulmonary disease: indacaterol versus tiotropium. American Journal of Respiratory & Critical Care Medicine. Jul. 15. 2010;182(2):155-62. [pmid: 20463178].
137 Kornmann O, Dahl R, Centanni S, et al. Once-daily indacaterol versus twice-daily salmeterol for COPD: a placebo-controlled comparison. European Respiratory Journal. Feb. 2011;37(2):273-9. [pmid: 20693243].
138 Calverley PM, Anderson JA, Celli B, et al. Salmeterol and fluticasone propionate and survival in chronic obstructive pulmonary disease. N Engl J Med. Feb. 22. 2007;356(8):775-89. [pmid: 17314337].
139 Troosters T, Sciurba FC, Decramer M, et al. Tiotropium in patients with moderate COPD naive to maintenance therapy: a randomised placebo-controlled trial. NPJ Primary Care Respiratory Medicine. 2014;24:14003. [pmid: 24841833].
140 Tashkin DP, Celli BR, Decramer M, et al. Efficacy of tiotropium in COPD patients with FEV1 >/= 60% participating in the UPLIFT(R) trial. COPD. Jun. 2012;9(3):289-96. PMID:. [doi: 10.3109/15412555.2012.656211]. [pmid: 22432932].
141 Tashkin DP, Celli B, Senn S, et al. A 4-year trial of tiotropium in chronic obstructive pulmonary disease. New England Journal of Medicine. Oct. 9. 2008;359(15):1543-54. [pmid: 18836213].
142 Lofdahl CG, Postma DS, Pride NB, et al. Possible protection by inhaled budesonide against ischaemic cardiac events in mild COPD. European Respiratory Journal. Jun. 2007;29(6):1115-9. [pmid: 17331963].
143 Bouwmeester W, Zuithoff NP, Mallett S, et al. Reporting and methods in clinical prediction research: a systematic review. PLoS Med. 2012;9(5):1-12. [pmid: 22629234].
144 Moons KG, Altman DG, Reitsma JB, et al. Transparent Reporting of a multivariable prediction model for Individual Prognosis Or Diagnosis (TRIPOD): Explanation and Elaboration. Ann Intern Med. Jan. 6. 2015;162(1):W1-W73. [pmid: 25560730].
145 Hoogendoorn M, Feenstra TL, Hoogenveen RT, et al. Association between lung function and exacerbation frequency in patients with COPD. Int J Chron Obstruct Pulmon Dis. 2010;5:435-44. [pmid: 21191438].
146 Buist AS, McBurnie MA, Vollmer WM, et al. International variation in the prevalence of COPD (the BOLD Study): a population-based prevalence study. [Erratum appears in Lancet. 2012 Sep 1;380(9844):806]. Lancet. Sep. 1. 2007;370(9589):741-50. [pmid: 17765523].
147 Suissa S, Patenaude V, Lapi F, et al. Inhaled corticosteroids in COPD and the risk of serious pneumonia. Thorax. Nov. 2013;68(11):1029-36. [pmid: 24130228].
148 Calverley PM, Stockley RA, Seemungal TA, et al. Reported pneumonia in patients with COPD: findings from the INSPIRE study. Chest. Mar. 2011;139(3):505-12. [pmid: 20576732].
149 Scanlon PD, Connett JE, Waller LA, et al. Smoking cessation and lung function in mild-to-moderate chronic obstructive pulmonary disease. The Lung Health Study. Am J Respir Crit Care Med. Feb. 2000;161(2 Pt 1):381-90. [pmid: 10673175].
150 Hoogendoorn M, Feenstra TL, Hoogenveen RT, et al. Long-term effectiveness and cost-effectiveness of smoking cessation interventions in patients with COPD. Thorax. Aug. 2010;65(8):711-8. [pmid: 20685746].
151 Strassmann R, Bausch B, Spaar A, et al. Smoking cessation interventions in COPD: a network meta-analysis of randomised trials. Eur Respir J. Sep. 2009;34(3):634-40. [pmid: 19357145].
152 Jimenez Ruiz CA, Ramos PA, Cicero GA, et al. Characteristics of COPD smokers and effectiveness and safety of smoking cessation medications. Nicotine & Tobacco Research. Sep. 2012;14(9):1035-9. [pmid: 22345320].
153 Clark MA, Hogan JW, Kviz FJ, et al. Age and the role of symptomatology in readiness to quit smoking. Addict Behav. Jan. 1999;24(1):1-16. [pmid: 10189969].
154 Walters N, Coleman T. Comparison of the smoking behaviour and attitudes of smokers who attribute respiratory symptoms to smoking with those who do not. Br J Gen Pract. Feb. 2002;52(475):132-4. [pmid: 11885822].
155 Morris JF, Temple W. Spirometric “lung age” estimation for motivating smoking cessation. Prev Med. Sep. 1985;14(5):655-62. [pmid: 4070195].
156 Wilt TJ, Niewoehner D, Kane RL, et al. Spirometry as a motivational tool to improve smoking cessation rates: a systematic review of the literature. Nicotine Tob Res. Jan. 2007;9(1):21-32. [pmid: 17365733].
157 Enright P. Patients are hurt by a false diagnosis of chronic obstructive pulmonary disease. Am J Respir Crit Care Med. Jan. 15. 2014;189(2):229. [pmid: 24428652].
158 Kaplan A, Freeman D, Cleland J, et al. Detecting mild COPD is not a waste of resources. Primary Care Respiratory Journal. 2011;20(3):238-9. [pmid: 21847505].
159 Jones R. Earlier detection of COPD. Primary Care Respiratory Journal. Jun. 2011;20(2):222. [pmid: 21597659].
160 Enright P, White P. Detecting mild COPD: don’t waste resources. Primary Care Respiratory Journal. Mar. 2011;20(1):6-8. [pmid: 21311843].
161 Enright P. Does screening for COPD by primary care physicians have the potential to cause more harm than good?. Chest. Apr. 2006;129(4):833-5. [pmid: 16608923].
162 Mannino DM, Buist AS. Global burden of COPD: risk factors, prevalence, and future trends. Lancet. Sep. 1. 2007;370(9589):765-73. [pmid: 17765526].
163 Agusti A, Calverley PM, Celli B, et al. Characterisation of COPD heterogeneity in the ECLIPSE cohort. Respiratory Research. 2010;11:122. [pmid: 20831787].
164 Vestbo J, Edwards LD, Scanlon PD, et al. Changes in forced expiratory volume in 1 second over time in COPD. New England Journal of Medicine. Sep. 29. 2011;365(13):1184-92. [pmid: 21991892].
165 Begg CB, Greenes RA. Assessment of diagnostic tests when disease verification is subject to selection bias. Biometrics. Mar. 1983;39(1):207-15. [pmid: 6871349].
166 Kotz D, Wesseling G, Huibers MJ, et al. Efficacy of confrontational counselling for smoking cessation in smokers with previously undiagnosed mild to moderate airflow limitation: study protocol of a randomized controlled trial. BMC Public Health. 2007;7:332. [pmid: 18005415].
167 Kotz D, Huibers MJ, West RJ, et al. What mediates the effect of confrontational counselling on smoking cessation in smokers with COPD?. Patient Education & Counseling. Jul. 2009;76(1):16-24. [pmid: 19150590].
168 McClure JB, Ludman E, Grothaus L, et al. Immediate and short-term impact of a brief motivational smoking intervention using a biomedical risk assessment: the Get PHIT trial. Nicotine Tob Res. Apr. 2009;11(4):394-403. [pmid: 19299409].
169 McClure JB, Ludman EJ, Grothaus L, et al. Impact of spirometry feedback and brief motivational counseling on long-term smoking outcomes: a comparison of smokers with and without lung impairment. Patient Educ Couns. Aug. 2010;80(2):280-3. [pmid: 20434863].
170 Troosters T, Weisman I, Dobbels F, et al. Assessing the Impact of Tiotropium on Lung Function and Physical Activity in GOLD Stage II COPD Patients who are Naive to Maintenance Respiratory Therapy: A Study Protocol. The Open Respiratory Medicine Journal. 2011;5:1-9. [pmid: 21503263].