# Discussion

We found no population-based screening trials that provided direct evidence on whether systematic screening for COPD in primary care improves health outcomes. The evidence for this screening is derived from an indirect pathway considering discrete bodies of evidence. We evaluated test performance of various screening approaches in populations that are representative of primary care and the benefits and harms of treating mild to moderate COPD, which are the stages of COPD that represent most screen-detected disease. We also considered whether identifying undiagnosed COPD might improve the effectiveness of other preventive services by enhancing service delivery or motivation to participate, including smoking cessation or immunizations. Table 33 provides a summary of evidence by KQ.

Table 33 Summary of Evidence

Key Question | Population | No. of Studies, Observations (n), Design | Summary of Findings | Consistency/Precision | Overall Study Quality | Body of Evidence Limitations | EPC Assessment of Overall Strength of Evidence | Applicability
Key Question 1 (Health Outcomes) | Asymptomatic adults | | We identified no trials examining the efficacy of COPD screening on health outcomes. | | | | Insufficient
Key Question 2: Questionnaires | Adults in the general population and primary care with and without smoking history | CDQ diagnostic accuracy observational studies: Development: K=1; N=572 Internal validation: K=1; N=246 External validation: K=5; N=3048 | CDQ: 3 out of 5 external validation studies were in ever smoking adults. Most external validation studies reported that a CDQ score of >16.5 had a sensitivity in the low 90% range and specificity in the high-30% to mid-40% range for diagnosing spirometrically-confirmed COPD. Choosing a higher cutpoint (19.5) reduced sensitivity and NPV but increased specificity and PPV. | Reasonably consistent; imprecise | Fair | Heterogeneous populations in external validation studies as reflected by wide variation in COPD prevalence in ever smokers (13% to 28%). | Moderate | Derivation population included U.S. site. None of the external validation studies performed in U.S.
Key Question 2: Questionnaires | Ever smoking adults in primary care | LFQ diagnostic accuracy observational studies: Development/validation of scoring: K=1; N=387 Internal validation: None External validation: K=1; n=849 | Based on 1 external validation study, the LFQ showed a sensitivity of 88% and specificity of 25%. | Unknown: 1 external validation study | Fair | Derived from NHANES III survey of self-reported, physician-diagnosed chronic bronchitis; spirometry used pre-BD FEV_1_/FVC. Single external validation study. | LOW | Single external validation study conducted in 36 U.S. primary care sites.
Key Question 2: Questionnaires | Adults in the general population and primary care with and without smoking history | COPD-PS diagnostic accuracy observational studies: Development: K=1; N=295 Internal validation: K=1; N=697 External validation: K=1; N=2357 | COPD-PS: Single external validation population-based study in Japanese rural town shows that for a cutpoint of 4, sensitivity is 67% and specificity is 73%. Choosing a higher cutpoint of 5 lowers the sensitivity to 35%, with a slightly higher specificity of 79%. | Unknown; 1 external validation study | Fair | External validation study in single Japanese rural community without exclusion of pre-existing COPD. | Very low | Development sample recruited participants from U.S. pulmonary and primary care clinics, but external validation study setting may not be generalizable to U.S. primary care screening population.
Key Question 2: Questionnaires | Adults in the general population and primary care with and without smoking history | Other (3) questionnaires not externally validated in diagnostic accuracy observational studies: k=4; n=4451 Buffels: k=1; n=2923 (development only) CAT: k=1; n=532 (same n for development and internal validation) CFQ: k=1; n=996 (development only) | Of the 3 questionnaires not externally validated, only 1 had internal validation (CAT). 1 study in ever smokers in primary care and the remainder in general population or primary care regardless of smoking history. Insufficient evidence to make conclusions regarding accuracy. | Unknown: 1 study | | Not externally validated | Insufficient | 2 studies from Canada. 1 study in ever smokers in primary care and the remainder in general population or primary care regardless of smoking history.
Key Question 3: Simple PFTs | Adults in the general population | PEF diagnostic accuracy observational studies: k=2; n=23,098 | 2 population-based studies with different index test thresholds; gold standard tests and definitions of COPD in low- and high-index countries without exclusion of known COPD do not provide sufficient information to make conclusions regarding accuracy. | Unknown: 2 existing studies use different PEF index test cutpoint units (L/s/m^2^ vs. % predicted) and different gold standard cutpoints (FEV_1_/FVC <0.7 vs. <LLN). 1 study defined mild COPD as disease negative. | Fair | BOLD and PLATINO population based samples do not exclude or report baseline known COPD, so enriched sample. | LOW | Serious concerns regarding applicability to U.S. population given that many countries in BOLD and PLATINO were low development index countries with different environmental and occupational exposures
Key Question 3: Simple PFTs | Pre-BD FEV_1_/FEV_6_: Ever smokers in primary care Post-BD FEV_1_/FEV_6_: Primary care with and without smoking history | Pre-BD FEV_1_/FEV_6_ diagnostic accuracy observational studies: k=2; n=509 Post-BD FEV_1_/FEV_6_ diagnostic accuracy observational studies: k=1; n=1078 | In 2 studies of pre-BD FEV_1_/FEV_6_ among ever smokers, sensitivities were similar (51.0% and 53.2%) at <0.70 cutpoint, as were specificities (89.5% and 93.0%). Cutpoint of 0.75 increased sensitivity to >80% and specificity remained relatively high (low 70%). Reported sensitivity in Sichletidis study that recruited about half ever smokers but utilized post-BD FEV_1_/FEV_6_ of <0.70 for screening was 80% and specificity was 95%. | Consistent | Fair | Only 2 studies (N=509) for pre-BD FEV_1_/FEV_6_ | Low | Conducted in Australia, Sweden for pre-BD studies; Greece for post-BD. Most likely reasonably applicable to U.S. primary care population, although environmental/occupational exposures might vary.
Key Question 3: Simple PFTs | Ever smokers in primary care | Staged approach (CDQ+FEV_1_/FEV_6_) diagnostic accuracy observational studies: K=1; n=1078) | In the analysis whereby the screening test was considered positive only if both CDQ and FEV_1_/FEV_6_ tests were positive, sensitivity and specificity were 72% and 97%, respectively in the entire population and similar in a subset of smokers only. The PPV was reported as 71% and the NPV was 97% in the entire population. | Unknown: 1 study | Fair to poor based on inadequate reporting of data for staged approach (and in ever smokers) | Single study, did not report raw data to create 2×2 tables for ever smoker subpopulation or for staged approach in general | Insufficient | Single Greek study; environmental and occupational exposures differ from U.S.
Key Question 4: Screening Harms | Adults in the general population and primary care with and without smoking history | CDQ diagnostic accuracy observational studies: K=4; N=3009 | [underlined: >16.5 threshold:] Missed cases (false-negative rate) ranged from 9% to 20%; in studies in which <20% of spirometries were invalid or incomplete (best estimate), the proportion of missed spirometry-diagnosed COPD cases was around 10%. False-positive rate varied, from 51% to 76% for >16.5; in studies with <20% spirometries invalid or incomplete, false-positive rate was similar. [underlined: >19.5 threshold:] Missed cases ranged from 11% to 37%; in studies in which <20% of spirometries were invalid or incomplete, missed cases ranged from 28% to 34%. False-positive rate varied, from 23% to 46%, with similar range for best estimate (<20% missed, incomplete spirometry). | Inconsistent | Fair | Heterogeneous populations with smokers vs. general population | Low | Derivation population included U.S. site. None of external validation studies performed in U.S.
Key Question 4: Screening Harms | Ever smoking adults in primary care | LFQ diagnostic accuracy observational studies: K=1; n=849 | Missed diagnosis and false-positive rate could not be reliably estimated for the LFQ because only a subset of screen-negative patients received diagnostic spirometry in the single external validation study of this questionnaire; however, the majority of those who screened positive on the questionnaire were determined to be false positive (74.2%). | Unknown: 1 study | Poor | Single external validation study | Insufficient | Validated in 36 U.S. primary care sites.
Key Question 4: Screening Harms | General population, including smokers and nonsmokers | COPD-PS: K=1; N=2357 | At a cutpoint of ≥4, false positives were 27% and false negatives were 33%. At a cutpoint of ≥5, false positives were 21% and false negatives were 65%. | Unknown; 1 external validation study | Fair | Single study set in Japanese rural town | Very low | May not be generalizable to U.S. primary care screening population.
Key Question 4: Screening Harms | | PEF diagnostic accuracy observational studies: k=1; n=9390 | False-negative rate reported in the 1 BOLD study reporting this outcome ranged from 16% to 69% depending on the threshold used. False-positive rate ranged from 0.5% to 16% depending on the threshold used. | Unknown: 1 study reporting false-negative and false-positive rate | Insufficient | BOLD population-based samples do not exclude or report baseline known COPD, so enriched sample. | Low | Serious concerns regarding applicability to U.S. population given that many countries in BOLD were low development index countries with different environmental and occupational exposures.
Key Question 4: Screening Harms | Pre-BD FEV_1_/FEV_6_: ever smokers in primary care Post-BD FEV_1_/FEV_6_: primary care with and without smoking history | Pre-BD FEV_1_/FEV_6_ diagnostic accuracy observational studies: k=2; n=509 Post-BD FEV_1_/FEV_6_ diagnostic accuracy observational studies: k=1; n=1078 | 2 pre-BD FEV_1_/FEV_6_ studies reported false-negative rates for threshold of <0.7 of 47% and 49% and false-positive rate of 8% and 10%. The 1 study using post-BD FEV_1_/FEV_6_ reported more favorable rates of 20% and 5%, respectively. | False-positive and false-negative rates reported in the 2 pre-BD FEV_1_/FEV_6_ studies were consistent. | Fair | Only 2 studies for pre-BD FEV_1_/FEV_6_ | Low | All 3 studies are outside U.S., with the 2 pre-BD FEV_1_/FEV_6_ studies in current or former smokers and the post-BD FEV_1_/FEV_6_ study in the general population.
Key Question 5a: Smoking Cessation | Adult smokers in the general population and primary care | RCTs: K=5; n=1620 | Of the 3 RCTs reporting biochemically confirmed abstinence, only 1 fair-quality RCT communicating lung age reported a statistically significant difference in the IG vs. CG; 1 underpowered VA trial120 showed a trend toward reduction and 1 trial of screen-detected patients with mild to moderate COPD who were motivated to quit showed almost identical rates of biochemically confirmed abstinence rates at 12 months in the intervention and active treatment CGs. | Inconsistent | Fair | Studies tested the incremental value of adding spirometry to counseling alone. | Low | Only 1 RCT recruited screen-detected patients who were motivated to quit. All other trials included patients with prior diagnoses of COPD (prevalence NR in 3 of the 5 RCTs).
Key Question 5b: Immunization Rates | Asymptomatic adults | | We identified no trials examining the effectiveness of screening in increasing vaccination rates. | | | | Insufficient
Key Question 6: Harms Screening on Preventive Services | Adult smokers in the general population and primary care | K=1 observational qualitative study; n=205 | No conclusions based on scant available data. 1 qualitative study of semistructured interviews reported that 8% of patients stated that routine PFTs in smokers would interfere with freedom of choice. | Unknown: 1 study | Insufficient | Scant data | Insufficient | Unknown
Key Question 7: Treatment Efficacy | Screen-detected COPD | | We identified no trials examining treatment effectiveness on health outcomes in patients with screen-detected COPD. | | | | Insufficient
Key Question 7: Treatment Efficacy | Moderate COPD | LABAs: k=2 (1 pooled subanalysis of RCTs plus 1 RCT); n=3174 | ACM (k=1; n=1057): TORCH trial subanalysis reports ACM of 9.2% vs. 11.4% without statistical testing. Exacerbations (k=1; n=1057): TORCH trial subanalysis reports annual exacerbation rate of 0.71 vs. 0.82 without statistical testing. Dyspnea score (k=1; n=2117): Post hoc pooled subanalysis of 3 RCTs showed a statistically significant short-term impact on dyspnea score after 6 months. QOL (k=2; n=3174): RCTs reported mixed results regarding LABAs’ effects on SGRQ scores. Exercise capacity: no trials. | Unknown: single subanalysis for ACM and exacerbation, single pooled analysis for dyspnea; mixed results for QOL | Fair to Poor | Subanalyses with several limitations: the primary trials were powered for entire population, not subgroup; both analyses were post hoc; neither performed interaction testing; and only 1 analysis controlled for confounders. | Insufficient for exercise capacity. Low for exacerbations, ACM, dyspnea, and QOL scores | Subgroup had moderate COPD disease and more severe range of moderate COPD (FEV_1_ % predicted 50% to 60%). No treatment naïve patients who could be considered similar to screen-detected, asymptomatic population.
Key Question 7: Treatment Efficacy | Moderate COPD | LABA-ICS: K=1; n=1097 | ACM (k=1 subanalysis RCT; n=1097): TORCH post hoc subanalysis of mild to moderate COPD reported a reduction in ACM (HR, 0.67 [95% CI, 0.45 to 0.98]) but interaction testing revealed no heterogeneity of effect by COPD severity and the main trial showed no ACM difference at 3 years. Exacerbations (k=1 post hoc subanalysis RCT; n=1097): The annual rate of moderate to severe exacerbations was lower in the ICS-LABA treatment combination group compared with those on placebo (0.57 in IG vs. 0.82 in CG; annual reduction rate in IG, 31% [95% CI, 19 to 40%]) Dyspnea score: no trials. QOL (k=1; n=1097): TORCH subanalysis showed that neither the LABA-ICS or control groups achieved clinically meaningful changes in SGRQ. Exercise capacity: no trials | Unknown consistency: single subanalysis | Poor | Single post hoc subanalysis not powered to detect outcomes in subgroup. | Insufficient for exercise capacity and dyspnea score. (Very) low for ACM, QOL. Low for exacerbations. | Subgroup had moderate COPD disease (FEV_1_ % predicted 50% to 60%). No treatment naïve patients who could be considered similar to screen-detected, asymptomatic population.
Key Question 7: Treatment Efficacy | Moderate COPD | Tiotropium: K=5; n=4592 | ACM (k=2; n=3196): UPLIFT subanalysis reports no difference in ACM: 9.2% vs. 10.8%; HR, 0.84 (95% CI, 0.66 to 1.07). Exacerbations (k=3; n=3483): 2 of 3 RCT subanalyses show reduction in mean number of exacerbations (RR, 0.80 [95% CI, 0.72 to 0.88]), and 4.6% vs. 11.0%; OR, 0.42 (95% CI, 0.21 to 0.84). VA subanalysis showed no difference in exacerbations without reporting statistics. Dyspnea score (k=1; n=911): 1 post hoc subanalysis of the INHANCE trial reported more patients achieved a meaningful clinical difference (≥1 point) in dyspnea score in the tiotropium vs. placebo group (64.6% vs. 49.3%; OR, 1.59 [95% CI, 1.07 to 2.37]). QOL (k=4; n=3282): 1 RCT in treatment-naïve moderate disease reports improvement in WPAI score but uncertain if clinically meaningful, and 3 subanalyses (1 prespecified; 1 post hoc; 1 NR timing) reported mixed results on SGRQ score: 2 showed no difference and 1 INHANCE subanalysis reported a statistically significant difference in patients achieving clinically meaningful change in tiotropium group (51.8% vs. 42.0%; OR, 1.46 [95% CI, 1.01 to 2.10]). For the additional UPLIFT subgroup analysis of COPD patients with FEV_1_ 60% to 70% predicted, the tiotropium group was more likely to experience a clinically meaningful change in QOL compared to the placebo group (52% vs. 44%; p<0.05). Exercise capacity (K=1; n=426): The 1 trial in treatment-naïve moderate COPD patients showed no difference in mean activity rate measured with activity monitors at 6 months but did report fewer inactive patients in the tiotropium group at 12 weeks (p=0.047). | ACM, dyspnea, exercise: unknown single study Exacerbation reasonably consistent | Fair | Most trials short (≤9 months). Single trial in moderate treatment-naïve COPD patients. Subanalyses all post hoc or unspecified timing except for one. 2 of 5 subanalyses performed interaction testing for the reported outcomes, showing no treatment effect heterogeneity by COPD severity. 3 of 5 subanalyses controlled for any confounders for at least 1 outcome. | Low to moderate for exacerbations. Low for QOL. Insufficient for dyspnea score, exercise capacity, and ACM. | Single RCT in moderate stage COPD naïve to maintenance medications, but otherwise patients were not treatment naïve and almost exclusively moderate COPD. Unclear if these results can be extrapolated to screen-detected patients.
Key Question 7: Treatment Efficacy | Mild to moderate COPD | ICS: K=6; n=3983 | ACM (k=4; n=3653): 4 trials report similar rates of ACM in the ICS and placebo groups (only 2 reported statistical significance testing, neither reports interaction testing; 1 reported no statistical testing). Exacerbations (k=4; n=2803): 3 trials with somewhat comparable definitions of exacerbations report similar trends of lower exacerbations in 2 trials but no statistical testing, and 1 trial (EUROSCOP), which specifically recruited mild to moderate COPD patients, reported a statistically significantly lower yearly rate of exacerbations requiring corticosteroids (0.05 vs. 0.07; RR, 0.63 [95% CI, 0.47 to 0.85]). Dyspnea score (k=2; n=1158): LHS showed that fewer patients experiencing dyspnea in the ICS group compared to placebo but unclear if clinically meaningful (p=0.02). 1 trial showed lower MRC dyspnea score in ICS group but neither the ICS nor placebo group had minimally important changes in MRC dyspnea score. QOL (k=2; n=1114): Both trials showed that neither the fluticasone nor the placebo group had changes reaching the threshold for a minimum clinically important difference (≥4 units) over the 30- to 36-month trial periods. Exercise capacity: no trials | Dyspnea: unknown QOL: reasonably consistent ACM: reasonably consistent Exacerbation: reasonably consistent | Fair | Only 1 trial exclusively recruited patients with mild to moderate COPD (EUROSCOP). Other evidence was derived from large and 1 smaller post hoc subanalysis of RCTs (both with limitations), and 2 RCTs with mean baseline FEV_1_ ≥60% predicted. Most trials had limitations due to variably defined ITT analyses, high withdrawal rates, and the exclusion of noncompliant patients during run-in periods, which may not reflect clinical practice. The 2 subanalyses had serious limitations, including the lack of baseline comparability reporting, lack of interaction testing, lack of control for confounders, and post hoc timing. | Insufficient for exercise capacity. Low for QOL, ACM, exacerbations, and dyspnea score. | Populations largely moderate in severity, although some mild COPD included in analyses. Unclear if these results can be extrapolated to screen-detected patients.
Key Question 8: Treatment Harms | Asymptomatic screen-detected patients | | We identified no trials examining treatment harms in screen detected patients.
Key Question 8: Treatment Harms | Mild to moderate COPD | LABAs: k=2 (1 pooled subanalysis of RCTs plus 1 RCT); n=3191 | Withdrawal rates (k=1; n=1074): TORCH subanalysis reported lower withdrawals in LABA compared to placebo group (27% vs. 35%; no statistical testing). Adverse events (k=2; n=3191): 1 pooled subgroup analysis of 3 RCTs reported mostly similar across each of the LABA and placebo groups. TORCH subanalysis reported mixed results with some adverse events slightly more common in the LABA and some slightly more common in the placebo group, but no statistical testing was provided so it is unclear if there is a meaningful difference. Pneumonia (K=1; n=1074): TORCH subanalysis reported higher probability of developing pneumonia among participants in the control vs. treatment group (10.6% vs. 9.4%; no statistical testing provided) | Withdrawal rates: unknown single study Adverse events: unknown Pneumonia: unknown single study | Poor | Subgroup analyses with serious limitations. No statistical testing. Reasons for withdrawals not consistently reported. | Insufficient | Uncertain if harms can be extrapolated to asymptomatic screen-detected patients.
Key Question 8: Treatment Harms | Mild to moderate COPD | LABA-ICS: K=2; n=1149 | Withdrawals (k=2; n=1149): 1 subanalysis reported fewer withdrawals in the LABA-ICS group compared to placebo (27% vs. 35%; no statistical testing). Laperre reported similar withdrawal rates in LABA-ICS and placebo group but only analyzed those with ≥70% adherence. Composite adverse events (k=1; n=1108): TORCH subanalysis reported similar adverse events in LABA-ICS and placebo group. Pneumonia (k=1; n=1108): TORCH subanalysis reported higher pneumonia in LABA-ICS group compared to placebo but no statistical testing (15.3% vs. 10.6%). | Withdrawals: unknown different methodology Adverse events: unknown single study Pneumonia: unknown single study | Poor | Single trial subanalysis reporting each outcome. Reasons for withdrawals not consistently reported. | Insufficient | Uncertain if harms can be extrapolated to asymptomatic screen-detected patients.
Key Question 8: Treatment Harms | Mild to moderate COPD | Tiotropium: K=3; n=4076 | Withdrawals (k=1; n=2739): UPLIFT subanalysis of moderate COPD reported similar withdrawals in the tiotropium and placebo groups. Composite adverse events (k=2; n=1337): Troosters trial of treatment-naïve moderate COPD patients reported similar rates of serious events in the tiotropium and placebo groups (4.1% vs. 4.4%; statistical testing not provided). The post hoc pooled analysis reported higher rates of any adverse event in patients treated with tiotropium compared to placebo; however, no statistical testing was performed (67% vs. 55.9%). Pneumonia: no trials | Withdrawal: unknown single study Composite adverse events: inconsistent | Poor | Most trials short (≤9 months). Single trial in treatment-naïve moderate COPD patients. Harms reported variably in trials. Reasons for withdrawals not consistently reported. | Low | Uncertain if harms can be extrapolated to asymptomatic screen-detected patients.
Key Question 8: Treatment Harms | Mild to moderate COPD | ICS: K=5; n=3732 | Withdrawals (k=4; n=2617): All trials report similar withdrawal rates ranging from 11% to 35% in ICS and placebo groups. Composite adverse events (k=3; n=2552): 2 of 3 trials show similar rates of composite adverse events; 1 trial reported more adverse events in the placebo group. Pneumonia (k=2; n=1377): 2 trials report mixed results: 1 reported higher pneumonia rates in the ICS group and 1 reported higher pneumonia rates in the placebo group. Bone density, femoral neck (k=1; n=359): LHS II subanalysis reported similar BMD at femoral neck in the ICS vs. placebo groups but greater percent change from baseline in the ICS group, unlikely to be clinically meaningful. Lumbar fracture (k=1; n=1175): EUROSCOP trial of moderate COPD patients reported similar rates of new lumbar fractures in the ICS and placebo groups. | Withdrawal: consistent Composite adverse events: inconsistent Pneumonia: inconsistent Bone density/fractures: unknown single study | Poor | Harms reported variably in trials. Reasons for withdrawals not consistently reported. | Low | Uncertain if harms can be extrapolated to asymptomatic screen-detected patients.

Abbreviations: ACM = all-cause mortality; BD = bronchodilator; BMD = bone mineral density; BOLD = Burden of Obstructive Lung Disease; CAT = COPD Assessment Test; CDQ = COPD Diagnostic Questionnaire; CFQ = Case Finding Questionnaire; CG = control group; CI = confidence interval; COPD = chronic obstructive pulmonary disease; COPD-PS = COPD Population Screener; EUROSCOP = European Respiratory Society study on Chronic Obstructive Pulmonary Disease; FEV_1_= forced expiratory volume in 1 second; FEV_6_= forced expiratory volume in 6 seconds; FN = false negative; FP = false positive; FVC = forced vital capacity; ICS = inhaled corticosteroids; IG = intervention group; INHANCE = INdacaterol to Help Achieve New COPD treatment Excellence; ITT= intention-to-treat analysis; LFQ = Lung Function Questionnaire; K = number of studies; LABA = long-acting β-agonist; LHS = Lung Health Study II; LLN = lower limit of normal; MRC = Medical Research Council; N = number; NHANES III = Third National Health and Nutrition Examination Survey; NPV = negative predictive value; NR = not reported; OR = odds ratio; PEF = peak expiratory flow; PFT = pulmonary function test; PLATINO = Proyecto Latinoamericano de Investigación en Obstrucción Pulmonar; PPV = positive predictive value; QOL = quality of life; RCT = randomized, controlled trial; RR = risk ratio; SGRQ = St. George’s Respiratory Questionnaire; TORCH = Towards a Revolution in COPD Health; UPLIFT = Understanding Potential Long-term Impacts on Function with Tiotropium; US = United States; VA = US Department of Veterans Affairs; WPAI = Work Productivity and Activity Impairment Questionnaire.

## Studies of Screening for COPD

We identified relatively scant data for any specific prescreening or screening approach using primary care–feasible questionnaires with or without pulmonary function measures. Additionally, because we identified no risk factor–only screening questionnaires, we used screening questionnaires that relied on a combination of risk factor– and symptom-based questions. The evidence was further complicated by the heterogeneity of screening approaches, involving various questionnaires and office pulmonary function measures, which were used alone or in combination. The populations selected for screening also varied across studies, and were generally selected based on age alone (at least 40 or 50 years) or age in addition to smoking history (usually ever smoking, sometimes with a minimal pack-years of exposure). Similarly, recruitment strategies, and in some cases diagnostic criteria, variously excluded persons with prior COPD or preexisting asthma, affecting applicability. Further, studies varied in their primary goal. Some studies, for example, assessed the utility of questionnaires to prescreen patients for more selected in-office pulmonary function screening measures, while others used questionnaires or pulmonary function measures (before or after bronchodilation) to identify candidates for diagnostic spirometry. Additionally, others studies primarily or secondarily evaluated various screening test cutpoints to optimize screening performance. Thus, the perspective and reporting of data varied substantially across studies. Nonetheless, we summarized available data as consistently as possible to examine the test performance of various primary care screening strategies using feasible questionnaires and/or handheld devices for identifying undiagnosed early-stage COPD.

The prevalence of COPD in studies applicable to a screening (undiagnosed) population ranged from approximately 10 percent in primary care patients age 40 years and older to 13 to 28 percent in ever smokers ages 40 to 50 years or older. Newly identified cases of COPD were predominantly (84% to 95%) in the mild to moderate stage.

Among several published questionnaires, only the CDQ, LFQ, and COPD-PS have been externally validated, which is a minimum requirement before they can be used in clinical practice.112,143,144 The eight-item risk factor– and symptom-based CDQ was the most extensively studied screening questionnaire, with external validation in five populations, all outside of the United States. This tool, however, has reasonably consistent test performance characteristics for detecting spirometrically-confirmed COPD in different languages and populations, which could strengthen its applicability. In general, the CDQ (also called the International Primary Care Airways Guideline questionnaire and the Respiratory Health Screening Questionnaire) had a sensitivity in the low 90 percent range and specificity in the high-30 to mid-40 percent range for scores greater than 16.5. Although this is a relatively low specificity for a screening test, the PPV was highest when applied to ever smokers (the derivation population for this tool). These false positives, however, would primarily be exposed to inconvenience and cost for diagnostic spirometry, a noninvasive test. NPV was greater than 90 percent in all populations (except for current smokers with a 10 pack-year history and at least one respiratory symptom), as would be desirable in case-finding. Although the LFQ was specifically developed in the NHANES population and studied in U.S. primary care practices, data for this questionnaire were limited to a single validation study. This study, however, had quality concerns (31% of spirometry was invalid or incomplete) and relatively poorer test performance than the CDQ. The LFQ had a very high test positive rate (77%) among ever smokers with a 10 pack-year history, but tended toward lower sensitivity, specificity, PPV, and NPV than the CDQ when used in similar populations. We could not assess the harms of screening (i.e., rate of false positives or proportion of missed cases) with the LFQ because only a subset of participants with scores less than 18 were selected for spirometry. Investigators examining the LFQ concluded that the questionnaire could be used as part of a staged approach to identify patients for prebronchodilator screening in primary care as an alternative to mass screening. Insufficient information on the missed cases and false positives, however, make it impossible to assess the tradeoffs of screening. While the COPD-PS was derived in an enriched sample of U.S. pulmonary and primary care clinics, its external validation in a single Japanese population-based study makes conclusions on generalizability of accuracy results limited. The COPD-PS has recently been applied in a multisite U.S.-based primary care, pragmatic COPD screening trial (n=8,770); however, this trial did not include gold standard reference spirometry for accuracy estimation.117

For primary care screening using handheld tools measuring various pulmonary functions, we identified studies examining PEF or FEV_1_/FEV_6_. PEF studies were conducted in large international populations that included individuals with preexisting COPD who had more prevalent environmental exposures. As such, test performance results are difficult to extrapolate to a U.S.-based primary care population. While we found three studies of FEV_1_/FEV_6_ screening in more than 1,500 persons, robust data for a specific screening approach were limited by variability in measures and populations. Two smaller studies, however, used prebronchodilator measurement in ever smokers, while one study of about 1,000 persons—about half of whom were ever smokers—used postbronchodilator FEV_1_/FEV_6_ for screening. One small study used prebronchodilator measurement, and this study also required minimal evidence of airway obstruction reversibility for spirometry-diagnosed COPD to eliminate persons with asthma. Nonetheless, only postbronchodilator FEV_1_/FEV_6_ had reasonable sensitivity (≥80%) at a FEV_1_/FEV_6_ cutpoint of less than 0.70. For prebronchodilator FEV_1_/FEV_6_ screening, a higher cutpoint (<0.75) was necessary to achieve this sensitivity. While these pulmonary function measures tended to have better specificity and PPV than questionnaires, they had similarly high NPV (>90%).

Three primary care screening strategies, or a combination of these strategies, have been proposed and tested: 1) targeted screening with spirometry in persons with risk factors (e.g., all ever smokers with smoking history of ≥10 pack-years); 2) prescreening questionnaires and/or handheld prebronchodilator measures of pulmonary function to identify persons who should undergo diagnostic spirometry; or 3) some sequential combination of these approaches. Rather than simply screening all smokers using full spirometry, the prescreening questionnaire approach provides a simple way to screen out those who do not need spirometry. This convenience, however, comes at the expense of some missed cases. Both prescreening questionnaires and handheld devices are relatively simple and inexpensive approaches, and the primary harms would stem from false positives or missed cases. We did not identify any other studies that reported on any other direct harms of this screening. While there is some uncertainty about the natural history of early COPD, we can assume that these missed early cases would eventually be identified at clinical presentation during later medical contacts. Any treatment benefits that could have occurred in the interim would theoretically be lost. As a result, we sought to quantify any potential benefits realized through increased preventive services uptake or early treatment initiation prior to clinical presentation in order to bound the incremental benefit from early COPD identification through screening.

We constructed simple tables to compare screening test performance using the CDQ or FEV_1_/FEV_6_ across a range of populations using the mean sensitivity and specificity of associated studies (excluding Kotz for the CDQ) (Tables 34 and 35). In a population of 1,000 persons screened with the CDQ (using a cutpoint of 16.5), assuming a COPD prevalence of 10 percent (as might be expected in adults age 40 years and older), sensitivity in the high 80s (87%), and specificity in the mid-40s (44%), approximately 591 patients would go on to spirometry. Only 87 of these 591 patients (15%) would actually have spirometrically-confirmed COPD. Using a prescreening questionnaire would save 409 patients from spirometric testing at the expense of 13 missed cases compared to screening the entire population. If the CDQ were applied to a higher prevalence population with 20 percent COPD (as might be expected in ever smokers ages 40 to 50 years or older) with the same sensitivity and specificity (87% and 44%, respectively), 622 patients would go on to spirometry, and 174 of these 622 patients (28%) would have spirometrically-confirmed COPD. Using the CDQ to target e patients who are more likely to screen positive on spirometry would reduce the number sent to spirometry by 378 patients at the expense of 26 missed cases (Table 34).

Table 34 Results of CDQ Screening in a Hypothetical Population^*^

COPD Prevalence | Screen Positives, N | False Positives, N | Missed Cases, N
10% | 591 | 504 | 13
20% | 622 | 448 | 26

* n=1000; cutpoint=16.5; sensitivity=87%; specificity=44%.

Abbreviations: CDQ = COPD Diagnostic Questionnaire; COPD = chronic obstructive pulmonary disease; N = number.

Table 35 Results of FEV_1_/FEV_6_ Screening in a Hypothetical Population^*^

Cutpoint | Test Performance | COPD Prevalence | Screen Positives, N | False Positives, N | Missed Cases, N
<0.7 (pre-BD) | Sensitivity: 52% | 10% | 124 | 72 | 48
| Specificity: 92% | 20% | 168 | 64 | 96
<0.75 (pre-BD) | Sensitivity: 84% | 10% | 336 | 252 | 16
| Specificity: 72% | 20% | 392 | 224 | 32
<0.7 (post-BD) | Sensitivity: 80% | 10% | 125 | 45 | 20
| Specificity: 95% | 20% | 200 | 40 | 40

* n=1000.

Abbreviations: BD = bronchodilator; COPD = chronic obstructive pulmonary disease; FEV_1_= forced expiratory volume in 1 second; FEV_6_= forced expiratory volume in 6 seconds; N = number.

In a population of 1,000 patients screened with prebronchodilator FEV_1_/FEV_6_ using a cutpoint of less than 0.70, we estimate that 124 patients would be sent on to spirometry, and 52 of these 124 patients (42%) would have spirometrically-confirmed COPD, assuming a COPD prevalence of 10 percent, sensitivity of 52 percent, and specificity of 92 percent. Therefore, using the prebronchodilator FEV_1_/FEV_6_ to target patients compared to screening the entire population with spirometry would save 876 patients from spirometry at the expense of 48 missed cases. Therefore, prebronchodilator FEV_1_/FEV_6_ screening alone with a cutpoint of 0.70 would result in diagnosing nearly the same number of patients as the missed cases (only half of COPD cases would be identified with this strategy), thereby limiting its use as a stand-alone screening test. Changing the threshold to less than 0.75 (sensitivity 84%, specificity 72%) would result in 336 patients being sent to spirometry, and 84 (25%) of these patients would have spirometrically-confirmed COPD at the expense of 16 missed cases. Further, postbronchodilator FEV_1_/FEV_6_ with a sensitivity of 80 percent and specificity of 95 percent would send 125 patients to spirometry, 80 (24%) of whom would have spirometrically-confirmed COPD at the expense of 20 missed cases. In a population with 20 percent prevalence, assuming the same sensitivity and specificity as the postbronchodilator FEV_1_/FEV_6_, 200 patients would be sent to spirometry and 160 (80%) of these patients would have spirometrically-confirmed COPD at the expense of 40 missed cases (Table 35).

The value assigned to results from various screening approaches, or to screening for COPD in general, is somewhat subjective, and depends on several judgments. First, there are judgments as to the sufficiency of the evidence. While available evidence was relatively sparse in an applicable population, we identified several ongoing studies aimed to estimate the diagnostic yield and accuracy of various primary care–based screening approaches, including microspirometry FEV_1_/FEV_6_, and a validation study of the COPD-PS prescreening questionnaire, as well as several novel screening tool development studies (Appendix B). The expectation of better evidence in the near future might influence judgments about how to use current evidence. Second, judgments about the value of earlier identification for some cases, paired with the “harms” of missing some cases or false-positive diagnostic evaluations, are required. In the following sections, we summarize the evidence on the value of earlier identification through considering efficacy of treatment in early-stage disease cases and any impact on warranted preventive services.

## Treating Patients With Mild to Moderate COPD

We identified no treatment trials in asymptomatic, screen-detected populations. We identified no trials that addressed the effectiveness of any treatment to improve health outcomes in patients with mild COPD. Almost all treatment trials almost exclusively included patients with moderate COPD, primarily the severe end of moderate (e.g., FEV_1_ of about 60% of predicted in many studies). Absolute treatment benefit estimates would be expected to be lower in a screen-detected, largely mild disease population than in these selected trials in our systematic review. We found only one treatment trial that clearly recruited a population with moderate COPD who were naïve to maintenance medications, which would be considered closer to a screen-detected population. In this trial, treatment with tiotropium reduced exacerbations and inactivity at 6 months with no treatment-attributable adverse events reported.139 Beyond this trial, there were limited data for any treatment class from trials that recruited solely mild to moderate COPD patients, as prior systematic reviewers have also found.5,101 Even when we supplemented with subgroup analyses from trials with the full range of disease severity, data remained very sparse. Additionally, subgroup analyses all had serious limitations, including being conducted post hoc, lacking control for confounders, not reporting baseline characteristics of the subgroup, and not providing interaction testing for differences in subgroup effects (Table 20). Nonetheless, these relatively weak data consistently support some reduction in exacerbations for each of the treatment classes in our review (LABAs, LABA-ICS, tiotropium, and ICS). Furthermore, LABAs and tiotropium may decrease dyspnea scores as well, but this evidence came from a single post hoc subgroup analysis, and thus is only suggestive. Overall, strength of evidence for a reduction in exacerbations and dyspnea score with early treatment in patients with moderate COPD is low, and the clinical significance of the observed reduction may be limited. Epidemiologic studies report that patients with mild to moderate COPD have an average of less than one exacerbation per year;6 one systematic review of RCTs and cohort studies reported an annual event-based exacerbation frequency (defined as doctor visits, antibiotics, steroids, or hospitalizations) of 0.82 (95% CI, 0.46 to 1.49) for mild disease and 1.17 (95% CI, 0.93 to 1.50) for moderate disease.145 Patients with screen-detected COPD might be expected to have even fewer exacerbations, which would render the absolute benefit as modest, at best.

A challenging issue when considering screening for COPD is the requirement for an asymptomatic population. Questionnaires such as the CDQ incorporate symptoms and their severity as part of their scoring, and the rationale for “screening” has largely been a case-finding one (i.e., there is a large proportion of undiagnosed disease seen in primary care). This systematic review only included asymptomatic persons, defined as those who are free of the disease; those in whom the disease is present but who have physical symptoms that are undetected by the patient or the clinician (e.g., mild dyspnea that goes unnoticed); or those who have nonspecific symptoms (e.g., sporadic sputum production or cough) that have gone unrecognized as being related to COPD. The distinction between patients who are symptomatic and those who are undetected or who present with nonspecific symptoms is difficult to determine from available clinical research. This is particularly true for smokers, many of whom have a chronic cough and some limited activity, without presenting such complaints to their physicians. Additionally, this task will be challenging for use in clinical practice unless screening/case-finding efforts are based on sociodemographic characteristics, such as age or a particular smoking history. Consistent evidence shows that COPD is underdiagnosed21,117,146 and limited data on harms reported in the treatment effectiveness trials suggest that there are no substantial serious adverse effects for most medications (i.e., upper respiratory symptoms, cough). Some concerns do remain, however, about ICS-containing medications increasing incidence of pneumonia in patients with more severe COPD147,148 and effects on bone mineral density and fracture risk. Data were too limited to make firm conclusions regarding this potential harm in our included trials of mild to moderate COPD.

The greatest potential benefit that could be achieved through screening would be increasing smoking cessation rates, since smoking cessation is the only proven beneficial treatment for reducing progression in mild to moderate COPD.149 Systematic reviews have confirmed that counseling and pharmacotherapy smoking cessation interventions are effective in patients with COPD,72,150,151 even though there is some evidence that smokers with COPD differ in their motivation to quit compared to smokers without COPD.74,152–154 Our systematic review identified four trials120–123 that examined the incremental value of adding screening spirometry to smoking cessation counseling interventions and one trial that examined the incremental value of adding “lung age,” as introduced by Morris in the mid-80s,155 to spirometry and counseling.119 The Parkes trial was the only study that reported a statistically significant absolute increase in biochemically confirmed cessation rates (7%) when screening results reported lung age to participants (number needed to treat=14).119 Since both groups received spirometry and counseling, however, this trial tested only the incremental value of adding “lung age” and suggested that the communication of lung damage might be the key. These early positive results have not been replicated in other trials that incorporate the feedback of lung age based on spirometry, including another community-based U.S. trial by McClure, which measured a less reliable self-reported cessation outcome.123 Our finding a lack of robust literature to support a smoking cessation benefit is consistent with those of the prior systematic review used by the USPSTF.156 Further, we did not identify literature to support the premise that false reassurance in smokers with normal spirometry may dampen motivation to quit. We identified four ongoing Spanish RCTs of screening spirometry in addition to counseling compared to counseling alone that will measure 12-month smoking abstinence rates (Appendix B). Results from these trials could add to this relatively underdeveloped literature base. We identified no completed or pending trials reporting the effect of awareness of COPD diagnosis influencing recommended immunization uptake rates.

In summary, given the paucity of data on screening accuracy and treatment benefit in screen-detected COPD, controversy about whether population screening or primary care case-finding should be implemented with any strategy remains. Advocates argue that the high prevalence of undiagnosed COPD cases (10% to 20%),38 as well as clinical COPD misdiagnoses in smokers who in fact have alternate treatable diagnoses (e.g., congestive heart failure), could be considered as potential benefits with few screening-related harms, since spirometry is a simple and noninvasive test.157 The underutilization of spirometric confirmation of clinically suspected COPD may result in misdiagnosis and inappropriate use of medications with potential harms, or a delay in the correct diagnosis resulting in a deferral of appropriate therapeutic interventions.158 Critics remain skeptical of the patient-focused benefits of population screening efforts in largely asymptomatic patients, particularly in light of the inadequate evidence on the prognostic markers for mild disease progression, little evidence on treatment benefit in mild disease, and high monthly costs of inhaled medications.159–161

## Limitations

Due to the fact that we found so few trials and there was so much variability between those studies that do exist, our systematic review was limited to a descriptive analysis, as meta-analysis would be inappropriate and imply false precision. The literature on screening instruments was limited by few questionnaires with external validation and heterogeneous populations with differing baseline COPD prevalence. Literature on treatment of COPD was limited by mostly short trial durations, differential withdrawal rates, and high premature drug termination with missing data for some outcomes in patients discontinuing the medications. Additionally, the majority of patients studied in the treatment RCTs had moderate COPD, with very scant evidence for patients with mild disease, which reduces our ability to assess treatment effectiveness in these patients. Our a priori methods only specified patient-focused outcomes and did not include change in FEV_1_ as an outcome. Not including this outcome, however, is consistent with USPSTF methods, particularly since it is unclear how change in FEV_1_ correlates with change in exacerbation rates. Further, we relied on harms data as reported in the effectiveness RCTs and thus may not have captured the full range of potential side effects or their population-based incidence. It is unlikely, however, that observational studies in screen-detected populations applicable to U.S.-based primary care are readily available given current practice.

## Future Research Needs

Ideally, primary care–based staged screening RCTs of ever smokers using the externally validated CDQ or LFQ prescreening questionnaire followed by microspirometry and reporting patient-focused outcomes data are needed. In the absence of such direct evidence, there are several areas for future research. These areas, however, might not fit into the USPSTF definition of screening. In 2009, the National Heart, Lung, and Blood Institute made specific recommendations for future research, including the identification and validation of case-finding tools focused on identifying moderate to severe disease, specifically patients with an FEV_1_ of less than 60 percent of predicted, as well as the development and validation of a three-stage approach to case-finding (risk factor–based questionnaire followed by a simple measure of expiratory flow and then confirmed with diagnostic spirometry).90 This approach, focused on moderate to severe disease, would be similar to the staged approach examined in a few studies in this review. Further investigation of the promising findings from Parkes’ lung age screening trial would require an RCT with an intervention group receiving screening spirometry with lung age reporting plus counseling compared to a control group receiving counseling alone. Results of such a trial would be incredibly informative. Additionally, long-term epidemiologic studies could provide a better understanding beyond what is currently known about the natural history and heterogeneity of early-stage COPD,162–164 and epidemiologic studies evaluating prognostic markers for progression would help to identify patients at greatest risk for clinical deterioration. Furthermore, long-term treatment RCTs of asymptomatic and minimally symptomatic screen-detected patients with minimal loss to followup would help to inform the discussion around the net benefits of screening.