# Results

## Literature Search

Our literature search yielded 13,141 unique citations. From these, we provisionally accepted 465 articles for review based on titles and abstracts (Appendix A Figure 1). After screening the full-text articles, we judged that 33 studies (48 articles) met the inclusion criteria (Appendix A Table 1). We excluded the remaining 428 articles (Appendix C).

## KQ 1 Does Screening for COPD With Prebronchodilator Screening Spirometry in Asymptomatic Adults Age 40 Years and Older Improve HrQOL or Reduce Morbidity or Mortality?

We found no trials that directly assessed if screening asymptomatic adults for COPD, presumably followed by appropriate health management strategies, improves HrQOL or reduces morbidity or mortality.

## KQ 2 Do Prescreening Questionnaires Reliably Identify High-Risk Asymptomatic Adults Who Are More Likely to Test Positive on Screening for COPD?

### Summary of Findings

We identified three externally validated prescreening questionnaires to select high-risk patients for screening spirometry—the CDQ, LFQ, and COPD-PS. The predictive accuracy of these questionnaires was measured against the postbronchodilator FEV_1_/FVC reference standard, considered the gold standard in the field when conducted according to quality standards based on the criteria defined by the 2005 ATS/ERS Task Force on Standardization of Lung Function Testing (Appendix D).108,109 The CDQ has been externally validated in European and Australian populations (Table 3). Despite a lack of direct U.S. validation, the quality of the CDQ’s development methodology and external validation studies make this questionnaire the most promising to - to good-quality external validation studies were identified for the CDQ, focusing mainly on a primary care population in which the majority of patients found to have COPD were identified as having mild or moderate disease (83.8% to 94.7%) (Tables 3 and 4). The populations varied from the derivation population (ever smokers) in three studies, which enrolled about half ever smokers,36 all current smokers with at least a 10-year pack-year history,89 or a general population with an unknown smoking history (Table 3).110 Most external validation studies reported that a CDQ score of greater than 16.5 had a sensitivity in the low 90 percent range and specificity in the high-30 to mid-40 percent range for identifying persons who test positive using spirometric confirmation for COPD. Choosing a higher cutpoint (19.5) reduced sensitivity and NPV but increased specificity and PPV (Table 4). While targeting ever smokers age 50 years and older, which corresponds to the derivation population, maximizes efficiency, this tactic will not include some cases of screen-detected COPD in never smokers. As such, the best approach for screening would depend on availability and costs of valid spirometry and potential downsides of missing mild cases, which could be minimized in the context of repeated screening and/or patient education encouraging early symptom-based care.

Table 3 Study and Baseline Characteristics for Externally Validated COPD Prescreening Questionnaires

Screening Instrument | Study, Year Quality | Country | N Screened N Analyzed (%) | Selection Criteria | Age, mean | % Female | % Smokers | % Preexisting Respiratory Diagnosis | Reference Standard
CDQ | Stanley, 2014^115^ Fair | Australia | 1,631 1,054 (64.6) | Ages 40–85 years; former or current smokers with no previous diagnosis of COPD or other obstructive lung disease. Recruitment setting/strategy: patients from a case-finding recruitment group for an RCT, 36 primary care centers. | 61.0 | 48.2 [c] | Current: 22.3 Former: 77.7 [c] Mean pack-years: 24.1 | 0 | Post-BD spirometry^‡^ (FEV_1_/FVC <0.7)
CDQ (RHSQ) | Dirven, 2013^110^ Fair | Netherlands | 293 39 (78.0)^†^ | Ages 40–70 years; no previous diagnosis of respiratory disease, no use of oxygen supplementation, no COPD screening in last 5 years. Recruitment setting/strategy: 10 general practices, strategy NR | NR | NR | NR Mean pack-years: NR | 0 | Post-BD spirometry (FEV_1_/FVC <0.7) plus physician’s clinical evaluation
CDQ | Frith, 2011^39^ Good | Australia | 237 201 (84.8) | Age ≥ 50 years; current or former smokers with no previous diagnosis of obstructive or nonobstructive lung disease and no treatment for obstructive lung disease in the past year; without symptoms of unstable heart disease or contraindications to spirometry. Recruitment setting/strategy: patients recruited from primary care visits or local newspaper advertising, strategy NR. | 61.0^§^ | 31.0 [c]^§^ | Current: 45.0^§^ Former: 55.0^§^ Mean pack-years: 39^§^ | 0^§^ | Post-BD spirometry^‡^ (FEV_1_/FVC <0.7) and reversibility ≤200 mL and ≤12% from baseline pre-BD FEV_1_
CDQ (IPAG) | Sichletidis, 2011^36^ Fair | Greece | 1,250 1,078 (86.2) | Age >40 years; no medically confirmed diagnosis of obstructive lung disease, medical history of any other pulmonary disease, thoracic surgery in past 6 months, acute respiratory infection, or uncontrolled cardiac disease. Recruitment setting/strategy: Primary care clinics of 50 general practitioners, the first 50 patients age ≥40 years seen in the primary care clinic. | 65.3 | 42.9 [c] | Current/former: 48.8 Mean pack-years: 19.5 [c] | 0 | Post-BD spirometry^‡^ (FEV_1_/FVC <0.7)
CDQ | Kotz, 2008^89^ Good | Netherlands | 826 676 (81.8) | Ages 40–70 years; current smokers with ≥10 pack-year history who were motivated to quit smoking with at least 1 respiratory symptom (cough, sputum, shortness of breath); without spirometry in past 12 months or previous respiratory diagnosis. Recruitment setting/strategy: general population recruited through advertising in newspapers, flyers, posters, and mailings. Patients also recruited during primary care visits. | 52.3 | 41.3 [c] | 100 Mean pack-years: 40.4 | 0 | Post-BD spirometry^‡^ (FEV_1_/FVC <0.7)
LFQ | Mintz, 2011^111^ Fair | US | 1,288 849 (65.9)^*^ | Age ≥30 years; current or former smokers with ≥10 pack-year history with no previous diagnosis of substantial lung conditions or regular use of respiratory medications in prior 4 weeks. Recruitment setting/strategy: 36 primary care centers, strategy NR | 54.0 [c] | 50.6 [c] | Current: 59.0 [c] Former: 41.0 [c] Mean pack-years: 33.4 | NR | Post-BD spirometry^‡^ (FEV_1_/FVC <0.7)
COPD-PS | Tsukuya, 2015 Fair | Japan | 2,643 2,357 (89.2) | Ages 40–70 years; no previous diagnosis of asthma or lung resection. Recruitment setting/strategy: townwide health screening | 61.0 [c] | 56.6 [c] | Current: 16.8 [c] Former: 26.0 [c] Mean pack-years: 13.0 [c] | NR | Post-BD spirometry (FEV_1_/FVC <0.7)

* Only a subset of those who screened negative on the LFQ was invited to spirometry.

† Only those who scored in the high-risk category of the CDQ were invited to undergo spirometry. 39 of 50 (78%) screen-positive patients underwent diagnostic testing.

‡ Spirometry required to meet the criteria of the American Thoracic Society/European Respiratory Society Task Force on standardization of lung function testing.108,109

§ Baseline information based on 204 patients with spirometry, not 201 patients with CDQ results.

Abbreviations: BD = bronchodilator; c = calculated; CDQ = COPD Diagnostic Questionnaire; COPD = chronic obstructive pulmonary disease; FEV_1_ = forced expiratory volume in 1 second; FVC = forced vital capacity; IPAG = International Primary Care Airways Guidelines; LFQ = Lung Function Questionnaire; N = number; NR = not reported; RCT = randomized, controlled trial; RHSQ = Respiratory Health Screening Questionnaire.

Table 4 Screening Yield for Externally Validated COPD Prescreening Questionnaires

Tool | Study, Year Quality | Population | Incomplete Questionnaire, (%) Invalid or Incomplete Spirometry, (%) | COPD Prevalence in Population ([TP+FN]/N analyzed), (%) Mild to Moderate Diagnoses, (%) | Cutoff | Screen Positives ([TP+FP]/N analyzed), (%)
CDQ | Stanley, 2014^115,116^ Fair | Current or former smokers | 178/1631 (10.9) | 138/1054 (13.1) | Intermediate/high likelihood (>16.5) | 597/1054 (56.6)^§^
CDQ | Stanley, 2014^115,116^ Fair | Current or former smokers
CDQ | Stanley, 2014^115,116^ Fair | Current or former smokers | 399/1631 (24.4)\|\| | 128/138 (92.7)^§^ | High likelihood (>19.5) | 361/1054 (34.3)^§^
CDQ
CDQ | Dirven, 2013^110^ Fair | General population | NR | NR | High likelihood (>19.5) | 50/293 (17.1)^*^ §
CDQ
CDQ | Frith, 2011^39^ Good | Current or former smokers | 3/233 (1.3) | 57/204 (27.9)^§^ | Intermediate/high likelihood (>16.5) | NR
CDQ | Frith, 2011^39^ Good | Current or former smokers
CDQ | Frith, 2011^39^ Good | Current or former smokers | 29/233 (12.4)^¶^ | 54/57 (94.7)^§^ | High likelihood (>19.5) | NR
CDQ
CDQ | Sichletidis, 2011^36^ Fair | Smokers and nonsmokers from primary care | NR | 111/1078 (10.3) | Intermediate/high likelihood (>16.5)^‡^ | 594/1078 (55.1)^§^
CDQ | Sichletidis, 2011^36^ Fair | Smokers and nonsmokers from primary care
CDQ | Sichletidis, 2011^36^ Fair | Smokers and nonsmokers from primary care | 172/1250 (13.8)^#^ | 93/111 (83.8)^§^ | High likelihood (>19.5)^‡^ | 302/1078 (28.0)^§^
CDQ | Sichletidis, 2011^36^ Fair | Smokers and nonsmokers from primary care
CDQ | Sichletidis, 2011^36^ Fair | Smokers and nonsmokers from primary care | | 90/522 (17.2)^§^ | Intermediate/high likelihood (>16.5)^‡^ in smokers only | 347/522 (66.5)^§^
CDQ | Sichletidis, 2011^36^ Fair | Smokers and nonsmokers from primary care | | NR | Intermediate/high likelihood (>16.5)^‡^ in smokers only
CDQ
CDQ | Kotz, 2008^89^ Good | Current smokers | 40/826 (4.8) | 278/676 (41.1)^§^ | Intermediate likelihood (>16.5) | 549/676 (81.2)^§^
CDQ | Kotz, 2008^89^ Good | Current smokers
CDQ | Kotz, 2008^89^ Good | Current smokers | 110/826 (13.3)^¶^ | 261/278 (93.9)^§^ | High likelihood (>19.5) | 366/676 (54.1)^§^
LFQ | Mintz, 2011^111^ Fair | Current or former smokers | NR | NR^†^ | ≤18 | 1216/1575 (77.2)^§^
LFQ | Mintz, 2011^111^ Fair | Current or former smokers | 376/1225 (30.7)^†^ \|\| | NR
COPD-PS | Tsukuya, 2015 Fair | General population | NR^**^ | 153/2357 (6.5) | ≥4 | 700/2357 (29.7)^§^
COPD-PS | Tsukuya, 2015 Fair | General population
COPD-PS | Tsukuya, 2015 Fair | General population | | NR (94.1) | ≥5 | 509/2357 (21.6)^§^

* Only screen-positive patients underwent diagnostic spirometry. 39 of 50 screen-positive patients underwent diagnostic testing.

† Patients recruited for diagnostic spirometry included all screen-positive patients (LFQ ≤18) and a subset of screen-negative patients (49 of 359).

‡ Study used the cutpoints of ≥17 points for intermediate likelihood and ≥20 points for high likelihood.

§ Calculated.

|| Not meeting quality criteria.

¶ Spirometry invalid, incomplete, or not undertaken.

# Refused or unacceptable spirometry.

** 159/2643 (6.0%) were excluded for poor study data (details not given).

Abbreviations: CDQ = COPD Diagnostic Questionnaire; COPD = chronic obstructive pulmonary disease; FN = false negative; FP = false positive; KQ = key question; N = number; NR = not reported; TP = true positive.

The LFQ, developed and internally validated in the U.S. population, was derived from the NHANES III (Table 5).86,93 The LFQ development approach, however, was limited by its use of a population solely with self-reported physician-diagnosed chronic bronchitis (not reflective of a population targeted for screening) and the use of prebronchodilator spirometry to diagnose any airway obstruction rather than COPD specifically.86 When externally validated using data from 36 U.S.-based primary care centers in a population of smokers (n=849), the LFQ showed a sensitivity of 88 percent and specificity of 25 percent.111

Table 5 Screening Yield for Derivation and Internal Validation Studies for COPD Prescreening Questionnaires With External Validation

Questionnaire | # of Questions Risk Factors/Symptoms Addressed | Original Development Population | % in Sample With Pre-Existing COPD Diagnosis | Reference Standard | Internal Validation | N Analyzed % With Spirometry-Diagnosed COPD | Initial Sensitivity Specificity | AUC | % Screened Positive | COPD Severity Identified by Questionnaire
CDQ Price, 2006^94^ Price, 2006^95^ | 8 Age, smoking history, BMI, weather-affected cough, phlegm without a cold, morning phlegm, wheeze, history of allergies | US/UK patients age ≥40, current and former smokers from primary care without respiratory disease | 0% | Post-BD FEV_1_/FVC <0.7 | [underlined: Price 2006a]94 Split sample (7:3) | 818 (19%) | [underlined: Price 2006a]94 80.4% 72.0% [underlined: Price 2006n]95 Cutpoint^*^ 16.5 Sensitivity: 80.4% Specificity: 57.5% Cutpoint^*^ 19.5 Sensitivity: 58.7% Specificity: 77.0% | 0.8158 | [underlined: Price 2006b]95 Proportion of population in each zone: High likelihood: 29.7% Intermediate likelihood: 19.9% Low likelihood: 50.4% | NR
LFQ Yawn, 2010^86^ Hanania, 2010^93^ | 5 Age; smoking history; presence of wheeze, dyspnea, and phlegm | [underlined: Yawn 2010]86 NHANES III data, patients with self-reported chronic bronchitis [underlined: Hanania 2010]93 US family practice patients age ≥40 | [underlined: Yawn 2010]86 51%^†^ [underlined: Hanania 2010]93 NR | Pre-BD FEV_1_/FVC<0.7 | None | [underlined: Yawn 2010]86 387 51% [underlined: Hanania 2010]93 837 18.6% | [underlined: Yawn 2010]86 73.2%^‡^ 58.2%^‡^ [underlined: Hanania 2010]93 82.6% 47.8% | [underlined: Yawn 2010]86 0.720 [underlined: Hanania 2010]93 0.652 | NR | NR
COPD-PS Martinez, 2008^88^ | 5 Shortness of breath, presence of phlegm/mucus, functional limitations due to breathing problems, smoking history, age | US, general practice patients age ≥35 | 38.2% | Post-BD FEV_1_/FVC <0.7 | 1000 bootstrap samples generated from original data set (N=697) | 295 38.4% | Continuous score^†^ 59.6% 83.2% | Continuous score: 0.81 | NR | NR

* Numbers are switched from the data in Price 2006 because the direction of the sensitivity and specificity indicate that the cutpoints are mislabeled in Table 3.^95^

† 100% of patients had self-reported chronic bronchitis, 51% had airflow obstruction confirmed by prebronchodilator spirometry.

‡ Sensitivity and specificity for detecting airflow obstruction.

Abbreviations: BD = bronchodilator; BMI = body mass index; CDQ = COPD Diagnostic Questionnaire; COPD = chronic obstructive pulmonary disease; FEV_1_= forced expiratory volume in 1 second; FVC = forced vital capacity; LFQ = Lung Function Questionnaire; N = number; NHANES III = Third National Health and Nutrition Examination Survey; NR = not reported; UK = United Kingdom; US = United States.

The COPD-PS development sample (n=295) was derived from an enriched sample of largely U.S.-based pulmonary specialty and primary care practices (Table 3).88 External validation in a single population-based Japanese study (n=2,357) showed a sensitivity of 67 percent and specificity of 73 percent using a cutpoint of 4; however, it is unclear if these accuracies are generalizable to a U.S. primary care screening population.112

Three other questionnaires, the COPD Assessment Test (CAT),113 the Case Finding Questionnaire (CFQ),114 and an independent questionnaire developed by Buffels and colleagues,37 have each published development studies (Table 6). While only one of these (CAT) has been internally validated, none of the questionnaires have been externally validated.

Table 6 Screening Yield for Derivation and Internal Validation Studies for COPD Prescreening Questionnaires Without External Validation

Questionnaire | # of Questions Risk Factors/Symptoms Addressed | Original Development Population | % in Sample With Pre-Existing COPD Diagnosis(Self-Report) | Reference Standard | Internal Validation | N Analyzed % With Spirometry-Diagnosed COPD | Initial Sensitivity Specificity | AUC | % Screened Positive | COPD Severity Identified by Questionnaire
Raghavan et al (based on CAT) Raghavan, 2012^113^ | 3 Age, smoking status (current and previous), symptoms of breathlessness, phlegm | Ontario, Canada general population age ≥40 | NR | Pre-BD FEV_1_/FVC <0.7 | 1000 bootstrap samples generated from original data set | 532 13.9% | 77.6% 64.9% | 0.772 | NR | NR
Buffels Buffels, 2004^37^ | 5 Cough, difficulty breathing, wheezing, allergies/hay fever | Belgian patients ages 35–70 from general practice without use of BDs or steroids | 0%^‡^ | Pre-BD FEV_1_/FVC <0.885 (men), <0.893 (women) | None | 2923 7.4% | 58%^§^ 78%^§^ | NR | 23% | Mild: 39% Moderate: 51% Severe/Very Severe: 9%/<1%
CFQ Hill, 2011^114^ | 5 Cough, phlegm and/or sputum, shortness of breath, wheezing, frequent colds | Ontario, Canada general practice smokers age ≥40; ≥20 pack-years smoking history | 10.9% | Post-BD FEV_1_/FVC <0.7, FEV_1_ <0.8 | None | 996 20.7% | NR | 0.6233 | 27.6%\|\| | NR

* Only individuals who screened positive on the COPD-PS were given diagnostic spirometry.

† Examined multiple score cutoffs.

‡ Based on no reported use of pulmonary medications.

§ Sensitivity and specificity of detecting COPD or asthma.

|| Score ≥3.

Abbreviations: BD = bronchodilator; CAT = COPD Assessment Test; CFQ = Case Finding Questionnaire; COPD = chronic obstructive pulmonary disease; COPD-PS = COPD Population Screener; FEV_1_= forced expiratory volume in 1 second; FVC = forced vital capacity; N = number; NR = not reported; UK = United Kingdom; US = United States.

Across studies, the proportion of field-based spirometry screening that was incomplete or of insufficient quality ranged from 12.4 to 30.7 percent. Therefore, quality control issues would be important for any noncentralized, office-based screening program.

### Detailed Results

We identified 11 fair- to good-quality studies (12 publications) that described three externally validated risk factor– and symptom-based self-administered prescreening questionnaires—the CDQ, LFQ, and COPD-PS. We also identified three studies describing the three nonexternally validated COPD prescreening questionnaires—the CAT,113 CFQ,114 and the questionnaire by Buffels (Tables 3, 5, and 6).37 The following results focus on the three questionnaires with external validation (CDQ, LFQ, and COPD-PS), since more research is needed on the questionnaires that lack external validation to determine their usefulness in clinical practice.

#### CDQ

The CDQ is an externally validated, eight-item, self-administered, symptom- and risk factor–based COPD prescreening questionnaire used to select high-risk patients for screening spirometry (Appendix D).94,95 The CDQ assigns scores for the following variables: age; pack-years of smoking; body mass index (BMI); and presence or absence of weather-dependent cough, sputum-productive cough, wheezing, and history of allergies. Possible scores range from 0 to 38, with highest scores attributed to older age (score 10 for ≥70 years), greater pack-years (score 7 for ≥50 pack-years), and lower BMI (score 5 for BMI <25.4 kg/m^2^), while the symptoms are scored as present or absent (score 0 for no symptom; score 3 or 4 for presence of specific symptom). Two cutpoints (16.5 and 19.5) have been proposed to select patients for screening spirometry based on receiver operating characteristic curves from the original development study.95 The internal validation and four out of five external validation studies included in this review variably reported on scores of less than 16.5, greater than 16.5, and greater than 19.5, which correspond to low, intermediate to high, and high risk of COPD, respectively (Table 4).36,39,89,95,115 The CDQ is also referred to as the International Primary Care Airways Guideline questionnaire and the Respiratory Health Screening Questionnaire.

Originally developed by the COPD Questionnaire Study Group in order to design a questionnaire that could screen for COPD in a primary care clinical setting, the original development and internal validation study was a cross-sectional study of 818 prior and current smokers age 40 years and older (Table 5).94,95 These patients were required to have no prior respiratory diagnoses or respiratory medication use in the previous year and were recruited from primary care practices in the United States and the United Kingdom (Denver, Colorado and Aberdeen, United Kingdom). Participants were mostly white (87.0% non-Hispanic white), with a mean age of 58.2 years. Almost half (44.5%) of the participants were current smokers and the remaining participants (55.5%) were former smokers with 25.6 mean pack-years of smoking. The original list of 54 candidate questions, created from literature review and Delphi panel, were administered to a total of 572 patients as part of the development sample. Univariate and bivariate analysis followed by sequential logistic regression yielded eight questions determined to be statistically significantly associated with COPD diagnosis. These final eight questions were administered to a performance sample of 246 patients (70:30 split sampling for development and internal validation) to generate a receiver operating characteristic curve. Spirometry was performed according to ATS/ERS standards108,109 and 8.9 percent of participants had spirometric results unsuitable for analysis (these were removed from analysis).

In the entire development sample (n=818), 19.0 percent of participants were diagnosed with COPD based on spirometry, although the prevalence was not reported separately for the development and validation subsets (Table 5).94,95 An article published later identified two cutpoints that optimized the negative and positive predictive values of the questionnaire: 16.5 and 19.5, respectively.95

##### External Validation: Characteristics of Included Studies

We identified two good- and three fair-quality cross-sectional external validation studies for the CDQ, with a total of 4,237 participants (Table 3).36,39,89,110,115 Two fair- to good-quality studies were performed in Australia,39,115 two fair- to good-quality studies in the Netherlands,89,110 and one fair-quality study in Greece.36 The largest two studies were an Australian study115 (n=1,631) and the Greek study36 (n=1,250). Mean ages of the four studies reporting this baseline characteristic ranged from 52.3 to 65.3 years; 31.0 to 48.2 percent of participants were women. Three of these studies exclusively recruited current and/or former smokers.39,89,115 In one study, for example, nearly half of the participants were current and/or former smokers,36 and the other study did not report smoking history.110 Mean pack-years of smoking exposure ranged from 19.5 to 40.4 pack-years.36,39,89,111,115 Three studies did not have any respiratory symptom–based inclusion/exclusions,39,110,115 whereas one study excluded patients with acute respiratory infections36 and one study required participants to have at least one respiratory symptom (cough, sputum, shortness of breath).89 All five studies excluded participants with preexisting respiratory diagnoses. Three studies recruited participants exclusively from primary care practices,36,110,115 while the other two studies recruited from the general population through advertising and primary care practice centers.39,89

Patients self-administered the CDQ questionnaire in three studies,36,89,110 a nurse administered the questionnaire in one study,115 and one study did not report who administered the questionnaire.39 The percentage of incomplete questionnaires was reported in three trials and ranged from a low of 1.3 percent,39 to a mid-range of 4.8 percent,89 to a high of 10.9 percent.115 Three of the studies were administered in languages other than English.36,89,110 Questionnaires were scored by different personnel in the studies: physicians,36 a practice assistant,110 a study programmer,39 and nurses.115 Spirometry was performed by pulmonary specialists,36 nurses,110,115 trained operators,39 or research assistants.89 Likewise, spirometry was centralized in only one study.89 Spirometry evaluation was performed by pulmonary specialists in two of the five studies.36,89 No study reported if the personnel administering the spirometry were blinded to the questionnaire results. Only one study performed blinded adjudication of spirometry.89

The diagnosis of COPD was defined as a postbronchodilator FEV_1_/FVC of less than 0.70 in all studies. Additionally, one study required physician evaluation110 and another required lack of reversibility (≤200 mL and ≤12% improvement from baseline prebronchodilator FEV_1_).39 Due to the spirometric criteria, only this latter study was able to discriminate between COPD and asthma, while the other trials actually diagnosed obstructive lung disease. Four36,39,89, 115 out of the five studies specified that “acceptable” spirometry must meet the ATS/ERS standards.108,109 Four36,39,89,115 of the five studies administered both the questionnaire and spirometry to all analyzed participants, and one study only administered spirometry to those whose CDQ questionnaire stratified them into the high-risk category (score >19.5).110

Four out of five studies reported the percent of recruited participants excluded from analyses because spirometry either did not meet quality criteria or was not completed. This ranged from 12.4^39^ to 24.4 percent; one study115 reported that more than one third of tests were excluded from the analysis due to unacceptable spirometry or incomplete questionnaires (35%). One other study reported no difference in the baseline characteristics of those analyzed and those excluded from the final analysis due to invalid spirometry, but did report that those with incomplete questionnaires had a lower postbronchodilator FVC than those with complete questionnaires (mean ± standard deviation [SD], 3.51 ± 0.76 vs. 3.98 ± 0.95 L; p=0.002).89 The remaining three studies did not report baseline characteristics of participants in the excluded group.36,39,110

COPD was diagnosed by spirometry in 10.3 to 41.1 percent of participants in each of the four studies that reported this outcome (Table 4).36,39,89,115 The highest prevalence of COPD (41.1%) was seen in the study conducted by Kotz,89 which was the only study requiring that participants be current smokers with at least a 10 pack-year history and have at least one respiratory symptom; these participants were essentially prescreened, thereby selecting for those most likely to have COPD. Prevalence of COPD in studies recruiting ever smokers ranged from 13.1 to 27.9 percent,39,115 and one general population study with more than half nonsmoking participants had an overall COPD prevalence of 10.3 percent, which was higher (17.2%) among ever smokers.36 Four studies reported the COPD severity in those diagnosed with COPD, showing that 83.8 to 94.7 percent had mild to moderate COPD according to GOLD criteria.36,39,89,115,116

##### External Validation: Outcomes

Three studies reported that 55.1, 56.6, and 81.2 percent of those taking the questionnaire had a score greater than 16.5.^36,89,115^ The highest percentage was in the study by Kotz that essentially prescreened its participants. Therefore, it can be expected that in a selected screening population (based on age, with or without ever-smoking history), about 50 percent of persons would prescreen as having at least intermediate risk of COPD on the CDQ and would move forward to spirometry (Table 4).36,89,115 Four studies reported that 17.1, 28.0, 34.3, and 54.1 percent of those taking the questionnaire scored greater than 19.5, placing them at high risk for COPD.36,89,110,115 The test positive rate for screening as high risk for COPD based on the CDQ was lowest in studies of general populations that recruited regardless of smoking status (17.1% to 28%), intermediate in those recruiting ever smokers (34.3%), and highest in those of current smokers with symptoms (54.1%). For all of these findings, the highest outlier prevalence, yields, and screen-positive results were seen in the Kotz study, where patients were already preselected based on the presence of current smoking and symptoms.89 Therefore, about one third of persons in a screening population, based on age and a history of ever smoking, would be expected to screen at high risk for COPD.

Three studies (all in ever smokers or current smokers) reported an area under the curve (AUC) ranging from 0.65 to 0.72.^39,89,115^ Sensitivity for the greater than 16.5 cutpoint ranged from 80 to 91 percent, with a clustering of sensitivities around 89 to 91 percent;36,39,89,115 the highest sensitivity of 93 percent was seen in the smokers-only subgroup analysis of the Greek study (Table 7).36 Specificity for this cutpoint ranged from 24 to 49 percent. PPVs ranged from 17 to 45 percent and NPVs ranged from 76 to 98 percent, with a clustering around 91 to 97 percent. Not surprisingly, the highest PPV and lowest NPV were seen in the study that preselected participants with symptoms.89 For the best-quality study examining an age- and smoking-based selection strategy,39 sensitivity of the CDQ at a cutpoint of 16.5 among ever smokers age 50 years and older for spirometry-confirmed, nonreversible COPD was 91 percent and specificity was 37 percent, with a PPV of 36 percent and an NPV of 91 percent.

Table 7 Diagnostic Accuracy of the COPD Diagnostic Questionnaire

Study | Population | Cutoff A (16.5) | | | | Cutoff B (19.5) | | | | AUC
Study | Population | Sensitivity (95% CI) | Specificity (95% CI) | PPV (95% CI) | NPV (95% CI) | Sensitivity (95% CI) | Specificity (95% CI) | PPV (95% CI) | NPV (95% CI) | AUC
Stanley, 2014^115^ | Current or former smokers | 80 (72 to 86)^‡^ | 47 (44 to 50)^‡^ | 18 (15 to 22)^‡^ | 94 (91 to 96)^‡^ | 63 (55 to 71)^‡^ | 70 (67 to 73)^‡^ | 24 (20 to 29)^‡^ | 93 (91 to 94)^‡^ | 0.71
Dirven, 2013^*,110^ | General population | NR | NR | NR | NR | NR | NR | 23 (12 to 38) | NR | NR
Frith, 2011^39^ | Current or former smokers | 91 (80 to 97) | 37 (29 to 45) | 36 (28 to 44) | 91 (81 to 97) | 71 (58 to 83) | 62 (54 to 70) | 42 (32 to 53) | 85 (77 to 91) | 0.72
Sichletidis, 2011^36^ † | Smokers and nonsmokers from primary care | 91 (85 to 95)^‡^ | 49 (46 to 52)^‡^ | 17 (14 to 20)^‡^ | 98 (96 to 99)^‡^ | 72 (63 to 80)^‡^ | 77 (74 to 80)^‡^ | 26 (22 to 32)^‡^ | 96 (94 to 97)^‡^ | NR
Sichletidis, 2011^36^ | Smokers only | 93 | 39 | 24 | 97 | NR | NR | NR | NR | NR
Kotz, 2008^89^ | Current smokers | 89 (85 to 92)^‡^ | 24 (20 to 29)^‡^ | 45 (41 to 49)^‡^ | 76 (68 to 83)^‡^ | 66 (60 to 71)^‡^ | 54 (49 to 59)^‡^ | 50 (45 to 55)^‡^ | 69 (64 to 74)^‡^ | 0.65

* Only screen-positive patients underwent diagnostic spirometry. 39 of 50 screen-positive patients underwent diagnostic testing.

† Study used the cutpoints of ≥17 points for intermediate likelihood and ≥20 points for high likelihood.

‡ Calculated.

Abbreviations: AUC = area under the curve; CI = confidence interval; NPV = negative predictive value; NR = not reported; PPV = positive predictive value.

Sensitivity for the greater than 19.5 cutpoint ranged from 63 to 72 percent and specificity ranged from 54 to 77 percent (Table 7).36,39,89,115 PPVs ranged from 23 to 50 percent and NPV ranged from 69 to 96 percent.36,39,89,110,115 For the best-quality study examining an age- and smoking history–based prescreening strategy,39 sensitivity of the CDQ at a cutpoint of 19.5 among ever smokers age 50 years and older for spirometry-confirmed, nonreversible COPD was 71 percent and specificity was 62 percent, with a PPV of 42 percent and an NPV of 85 percent.

Given the higher prevalence of COPD among current and former smokers, it can be expected that the yield of screening would improve when applied to ever smokers only. In a subanalysis of the study by Sichletidis limiting the population to ever smokers, the percent of participants who screened positive (CDQ score >16.5) increased from 55.1 to 66.5, corresponding with an increasing prevalence of COPD in the screened population from 10.3 to 17.2 percent (Table 4).36 Limiting to the ever-smoking population, however, missed detection of 21 cases of obstructive lung disease among never smokers (out of 111 screen-detected cases in the entire population). If the CDQ were applied to the full population, 10 of 111 cases of COPD would be missed, but half of all screened participants would require spirometry. If the CDQ were applied only to ever smokers, 27 of 111 cases of COPD would be missed, at the savings of about 250 cases of diagnostic spirometry. Thus, while there appears to be higher utility in screening a general practice population limited to current and former smokers using the CDQ, this approach will result in a number of undetected cases in never smokers.

##### Critical Appraisal

The recruitment strategies used in these studies largely represent primary care populations at risk for COPD; all studies recruited exclusively or at least partly from primary care practices, all excluded participants with known lung disease, and most recruited at least half of their participants with a smoking history.36,39,89,115 Additionally, two of the five studies were large (recruited >1,000 participants).36,115 While all studies used a postbronchodilator FEV_1_/FVC of less than 0.70 as a diagnosis for COPD, only one study included criteria for reversibility.39 In this study, the reported COPD specificity may be lower than in other studies given that the patients in other studies with reversibility would have been counted as true positives.39 Overall, approximately 65 to 86 percent of the screened population was analyzed, with up to one quarter of spirometry tests judged to be unacceptable by ATS/ERS standards. This variability in acceptable spirometry, though not ideal, may reflect the reality of screening using spirometry in primary care practice, and would reflect an important consideration on handling indeterminate findings for a broadbased screening effort.

Diagnostic accuracy results were fairly consistent across the studies despite some clinical heterogeneity (e.g., different countries, different smoking exposures, different baseline COPD prevalence). One major limitation of this body of literature is that none of the external validation studies were performed in the United States.

#### LFQ

The LFQ is a five-item, self-administered, risk factor– and symptom-based questionnaire that assigns scores to the following variables: age; smoking history (pack-years, never/current/former smoker); and presence of wheezing, dyspnea, and mucous productive cough (Appendix D).86 The questionnaire was originally developed using data from 387 NHANES III participants age 40 years and older with a self-reported doctor diagnosis of chronic bronchitis, in order to design a screening tool for primary care to identify airflow obstruction (Table 5). Airflow obstruction was defined as a prebronchodilator FEV_1_/FVC of less than 0.70 (no postbronchodilator spirometry was performed in NHANES III). Fifty-one percent of these 387 participants had confirmed obstruction on prebronchodilator spirometry. The development study began with eight candidate questions based on risk factors for airflow obstruction, and compared risk factors in those with and without airflow obstruction among those with self-reported chronic bronchitis (case-control fashion). Step-wise logistic regression for item reduction followed by qualitative assessment of validity using physician focus groups and patient interviews resulted in the final five-item questionnaire. One of the final five items (the presence of phlegm) was added to the questionnaire because of its clinical importance, despite the lack of statistical association in logistic regression. Preliminary scoring assigned one point in a dichotomous fashion for each of the items: age (50 years or older), wheezing (presence), dyspnea (presence), phlegm (presence), and smoking (20 years duration or longer), with an AUC of 0.72 regardless of decision threshold.

Limitations of the LFQ development study include its derivation in a population solely with self-reported physician-diagnosed chronic bronchitis (not reflective of a population targeted for screening) and the use of prebronchodilator spirometry to indicate any airway obstruction rather than COPD specifically.

Scoring was further tested (five-point ordinal scale vs. binary yes/no scoring) in an internal validation study by Hanania in which 837 patients age 40 years or older from two family physician group practices in Kentucky completed the LFQ and spirometry (937 initially participated, 837 analyzed) (Table 5).93 No other exclusions were made in the population other than patient age. Obstructive lung disease was defined as a prebronchodilator FEV_1_/FVC of less than 0.70. Personnel administering spirometry and blinding were not reported; 61.6 percent of participants were female and the majority were white (86.9%). Additionally, 18.6 percent of the participants had spirometrically confirmed obstructive airway disease. Using a five-point ordinal scale for each of the five questions (maximum score of 25; lower scores associated with higher risk) at a cutpoint of 18 or less, the AUC was 0.652. Sensitivity and specificity were reported as 82.6 and 47.8 percent, respectively.

##### External Validation: Characteristics of Included Studies

We identified one fair-quality external validation study meeting our selection criteria for the LFQ (Table 3).111 This study recruited 1,288 current or former smokers age 30 years or older with a 10 pack-year or greater history from 36 U.S.-based primary care centers to receive both the questionnaire and spirometry. Patients were excluded if they had a known diagnosis of “substantial lung conditions”; however, a previous diagnosis of obstructive lung disease was allowed if the patient did not use daily respiratory medications in the 4 weeks prior to the study. Half of the patients were female and the mean age of participants was 54.0 years. Additionally, 59.0 percent were current smokers, 41.0 percent were former smokers, and participants had a mean of 33.4 pack-years of smoking exposure.

The reference standard used in this study was postbronchodilator spirometry (FEV_1_/FVC <0.70) and spirometry was required to meet the criteria of the ATS/ERS standards on lung function testing.108,109 All participants with LFQ scores of 18 or less (n=1,215) were invited for spirometry while a selected subset of those who screened negative on the LFQ (n=73) were invited to spirometry. Of those attempting spirometry, 30.7 percent did not complete the spirometry per protocol or did not meet the ATS/ERS standards. A total of 849 participants remained in the analysis (Table 4).

##### External Validation: Outcomes

Spirometrically confirmed COPD prevalence was not reported, as only a subset of participants with LFQ scores greater than 18 underwent further screening with spirometry. Of those screened, 77.2 percent were identified as at risk, with an LFQ score of 18 or less. Obstructive lung disease was detected among 21.2 percent of those who screened positive on the LFQ (score of ≤18) and in 10.2 percent among the subset of patients who screened negative (>18) (Table 4).111 The estimated sensitivity was 88 percent and specificity was 25 percent, with PPV and NPV of 21 and 90 percent, respectively (Table 8).

Table 8 Diagnostic Accuracy of the Lung Function Questionnaire

Study | Population | Cutoff ≤18 | | | | AUC
Study | Population | Sensitivity (95% CI) | Specificity (95% CI) | PPV (95% CI) | NPV (95% CI) | AUC
Mintz, 2011^111^ | Current or former smokers | 88 (75 to 94)^*,†^ | 25 (22 to 28)^*,†^ | 21 (18 to 24)^*,†^ | 90 (78 to 97)^*,†^ | NR

* Used the Beggs and Greenes method to adjust for lack of spirometric verification in all subjects.165

† Calculated.

Abbreviations: AUC = area under the curve; CI = confidence interval; NPV = negative predictive value; NR = not reported; PPV = positive predictive value.

##### Critical Appraisal

Overall, the LFQ has been externally validated in only a single study in primary care U.S.-based practices. This study may have overestimated the accuracy because some patients with known COPD/obstructive lung disease but not taking daily medications were included, which may have enriched the sample. Overall, however, the participants reflect those who might be targeted for screening in primary care (current or former smokers with ≥10 pack-year exposure), although the mean age in this LFQ validation study was younger than in most CDQ studies. The high rate of unacceptable spirometry (30.7%) might also lead to overestimating the accuracy of the questionnaire, but it may also reflect the reality of spirometry performed in primary care practices.

#### COPD-PS

The COPD-PS is an externally validated, five-item, self-administered and self-scored, symptom- and risk factor–based COPD prescreening questionnaire used to select high-risk patients from the general population for screening spirometry (Appendix D).88 The COPD-PS assigns scores for the following variables: age, smoking history, dyspnea, sputum production, and dyspnea-related functional limitations. Possible scores range from 0 to 10, with higher scores being associated with a higher risk of COPD. Internal and external validation studies have explored various cutpoints ranging from 1 to 7, and have identified 4 to 6 as the ideal cutpoints.88,112

The original development and internal validation was performed in a U.S. multisite, cross-sectional study of patients from four pulmonary clinics and eight general practices who had scheduled office visits during the study period (Table 5). The final analysis sample (n=295) came largely from pulmonary specialty settings (190 patients from pulmonology practices and 105 from primary care practices). Patients age 35 years and older, regardless of smoking history, were included without exclusion for preexisting COPD or other pulmonary diagnoses, although those seeking care for acute respiratory problems were excluded (Table 5). Participants were mostly white (82.5%), with a mean age of 62.1 years. More than half were ever smokers (16.4% current smokers, 48.1% former smokers). The original working group developed a list of 23 candidate questions, which was narrowed to the five final questions using step-wise logistic regression models. Spirometry was performed according to ATS/ERS standards, and 48 percent of the initial 697 recruited patients were removed from the analysis because spirometry did not meet ATS standards.108,109

In the development sample (n=295), 38.4 percent of the participants were diagnosed with COPD based on spirometry (postbronchodilator FEV_1_/FVC <0.70) (Table 5). Using the original sample for internal validation (n=697), a 1,000 bootstrapping sample logistic regression model yielded an AUC of 0.81. Authors concluded that a cutpoint of 5 to 6 provided an acceptable sensitivity and specificity tradeoff.

The major limitation of the COPD-PS development sample was its applicability to primary care asymptomatic populations. The development/internal validation sample may not be reflective of a primary care screened population for several reasons: more than half of the patients analyzed came from pulmonary clinics; patients with previously diagnosed COPD were not excluded; and almost half of the initial sample was censored because of unacceptable spirometry per ATS standards. Additionally, this population was an enriched sample, as evidenced by a high prevalence (38.4%) of any spirometrically confirmed airway obstruction (postbronchodilator FEV_1_/FVC <0.70), and participants were found to have mostly moderate to severe disease (85%).

##### External Validation: Characteristics of Included Studies

We identified one fair-quality cross-sectional external validation study for the COPD-PS (Table 3).112 This study (n=2,357 analyzed) recruited a random sample of registered residents ages 40 to 79 years in a rural Japanese town, excluding those with physician-diagnosed asthma or lung resection. The prevalence of previously diagnosed COPD was not reported. Approximately half of patients were female (56.6%) and the mean age was 61 years. Slightly less than half of participants were ever smokers, with 16.8 percent current smokers and 26.0 percent former smokers. Participants had a mean of 13.0 pack-years of smoking exposure.

The reference standard used in the study was postbronchodilator spirometry, defining airway obstruction as an FEV_1_/FVC of less than 0.70. Spirometry was reviewed by two study pulmonologists for acceptability. A small number (6%) of those initially recruited were excluded for “poor study data.”

##### External Validation: Outcomes

Overall prevalence of COPD in the sample was low, with 6.5 percent (153/2,357) of the study sample found to have spirometrically confirmed COPD (Table 4).112 Of those identified with the disease, the majority (94.1%) were found to have mild or moderate COPD. COPD-PS scores of 4 or greater showed a sensitivity of 67 percent and specificity of 73 percent (Table 9). COPD-PS scores of 5 or greater demonstrated a sensitivity of 35 percent and specificity of 79 percent. The overall AUC was 0.748.

Table 9 Diagnostic Accuracy of the COPD-Population Screener

Study | Population | Cutoff A (4) | | | | Cutoff B (5) | | | | AUC
Study | Population | Sensitivity (95% CI) | Specificity (95% CI) | PPV (95% CI) | NPV (95% CI) | Sensitivity (95% CI) | Specificity (95% CI) | PPV (95% CI) | NPV (95% CI) | AUC
Tsukuya, 2015 | General population | 67 (60 to 74)^*^ | 73 (71 to 75)^*^ | 15 (12 to 17)^*^ | 97 (96 to 98)^*^ | 35 (27 to 42)^*^ | 79 (78 to 81)^*^ | 10 (8 to 13)^*^ | 95 (93 to 96)^*^ | 0.75

* Calculated.

Abbreviations: AUC = area under the curve; CI = confidence interval; NPV = negative predictive value; PPV = positive predictive value.

##### Critical Appraisal

The COPD-PS has been externally validated in a single population-based study, in a small Japanese rural town. The population studied had a relatively low mean pack-year smoking exposure, without exclusion of known obstructive lung disease. Data were largely complete, with few poor-quality spirometry results, and more than half of the town’s population (65.3%) in the eligible age range participated in the study during health checkups. It is unclear, however, whether the diagnostic accuracy reported could be generalizable to a U.S.-based primary care screened population.

#### Other Prescreening Questionnaires With Model Development Studies (Not Externally Validated)

In addition to the CDQ and the LFQ, we identified three COPD prescreening questionnaires that have been reported in five articles describing their development and/or internal validation; none of these four questionnaires have been externally validated (Table 6). These questionnaires include the CAT,113 CFQ,114 and an independent questionnaire created by Buffels.37 Two of the questionnaires have publications reporting their development tested in 2,923^37^ and 996 patients,114 but we identified no internal validation studies for the Buffels questionnaire or CFQ. The other questionnaire was internally validated in 532^113^ patients using a bootstrapping technique.

These questionnaires are three- to five-item, risk factor– and symptom-based, self-administered questionnaires, including some of the following variables: age, smoking history, dyspnea, phlegm, functional limitations due to dyspnea, allergy history, wheezing, cough, and frequent colds. Two questionnaires were studied in Ontario, Canada113,114 and one in Belgium.37 Two recruited from general practices37,114 and one recruited from the general population.113 One of the studies included participants with self-reported COPD diagnoses, resulting in a prevalence of previously diagnosed COPD of 10.9 percent.88,114 One study recruited smokers only, with a 20 or more pack-year exposure.114 Reference standards varied, with three studies using a pre- or postbronchodilator FEV_1_/FVC of less than 0.70,^88,113,117^ one using a postbronchodilator FEV_1_/FVC of less than 0.70 plus an FEV_1_ of less than 0.80,^114^ and one using a prebronchodilator FEV_1_/FVC of less than 0.885 in men and 0.893 in women.37

The prevalence of COPD varied widely in these studies, from 7.4 to 20.7 percent with spirometry-confirmed COPD (Table 6). In the Buffels study reporting COPD severity identified by the questionnaire, 90 percent37 were classified as mild to moderate COPD based on the GOLD criteria. Reported AUCs ranged from 0.623 to 0.77.

While these three questionnaires show promise as prescreening tools in primary care, until they are externally validated in other U.S. primary care populations, limited conclusions can be made about their validity.

## KQ 3 What Is the Test Performance of Screening Pulmonary Function Tests in Predicting Diagnosis of COPD in Asymptomatic Adults, Based on Confirmation With Postbronchodilator Spirometry to Identify Fixed Airflow Obstruction?

### Summary of Findings

We identified one good- and four fair-quality studies evaluating two different pulmonary function screening tests against a postbronchodilator FEV_1_/FVC reference standard: PEF and FEV_1_/FEV_6_ (Table 10). In all but one study,36 screening tests were administered in the prebronchodilator state. The included populations varied in their selectivity in terms of age, smoking status, and symptomatology/exclusion of preexisting COPD. Two studies of PEF by Jithoo et al and Perez-Padilla et al evaluated the largest number of patients (n=23,098);67,91 however, these two studies are from the population-based international BOLD initiative, whose primary aim was to describe the prevalence of COPD internationally. Thus, BOLD results are less applicable to the screening accuracy questions in this review, since BOLD did not exclude those with preexisting COPD and included several low-index countries not generalizable to the United States. Also, the PEF evaluation by Jithoo et al defined those with mild COPD as disease negative, while the other reported results mainly for a more selected group of those screened, greatly limiting the applicability of these PEF test results to a primary care screening population. Three studies reported the screening test performance of FEV_1_/FEV_6_ and were conducted in Australia, Greece, and Sweden (n=1,587).36,39,118 In the two studies utilizing prebronchodilator FEV_1_/FEV_6_ among ever smokers (Frith et al and Thorn et al), the sensitivities were similar (51% and 53%), as were specificities (90% and 93%) (Table 11). The reported sensitivity in the Sichletidis study that recruited about half ever smokers and utilized postbronchodilator FEV_1_/FEV_6_ for screening was much higher (80%), and specificity was also good (95%). In a subsample limited to ever smokers, postbronchodilator screening appeared relatively similar to screening test performance in the entire population, but we could not confirm, as reported data were incomplete.

Table 10 Study and Baseline Characteristics for Pulmonary Function Screening Tests

Screening Measure | Study, Year Quality | Country | N Screened N Analyzed (%) | Selection Criteria | Age, mean | % Female | % Smokers | % Pre-Existing Respiratory Diagnosis | Reference Standard
PEF | Jithoo, 2013^67^ Fair | International (14 BOLD countries^*^) | 10,712 9390 (87.6) | Age ≥40; noninstitutionalized. Recruitment setting/strategy: General population patients participating in the BOLD study. | 56.1 | 52.3 | 57.2 [c] Mean pack-years: 26.6 (males), 19.3 (females) | Asthma: 12.3 COPD: 7.4\|\| | Post-BD spirometry^‡^ (FEV_1_/FVC <LLN and FEV_1_ <80% predicted)^#^
PEF | Perez-Padilla 2009^91^ Fair | International (17 BOLD/PLATINO countries^§^) | NR 13,708 (NR) | Age ≥40; noninstitutionalized. Recruitment setting/strategy: general population patients participating in the BOLD/PLATINO studies. | 56.0 | 55.5 | Ever smokers: 45.2 Mean pack-years: 22.7 | Unknown, but some patients with pre-existing disease | Post-BD spirometry (FEV_1_/FVC <0.7)
Pre-BD FEV_1_/FEV_6_ <0.7 (using PiKo-6 handheld flow meter) | Frith, 2011^39^ Good | Australia | 237 204 (86.1) | Age ≥50; current or former smokers with no previous diagnosis of obstructive or nonobstructive lung disease and no treatment for obstructive lung disease in the past year; without symptoms of unstable heart disease or contraindications to spirometry. Recruitment setting/strategy: 4 primary care centers, recruited on prescheduled study days or from local newspaper ads. | 61.0 | 31.0 [c] | Current: 45.0 Former: 55.0 Mean pack-years: 39 | 0 | Post-BD spirometry^‡^ (FEV_1_/FVC <0.7) and reversibility ≤200 mL and ≤12% from baseline pre-BD FEV_1_
Pre-BD FEV_1_/FEV_6_ <0.7 (using COPD-6 handheld mini-spirometer | Thorn, 2012^118^ Fair | Sweden | NR 305 (NR) | Ages 45–85; smoking history of ≥15 pack-years. Recruitment setting/strategy: 21 primary care clinics, consecutive patient recruitment. | 61.2 | 56.7 | 100 Mean pack-years: 30.3 | NR | Post-BD spirometry^‡^ (FEV_1_/FVC <0.7)
Post-BD FEV_1_/FEV_6_ <0.7 (using PiKo-6 handheld flow meter) | Sichletidis, 2011^36^ Fair | Greece | 1250 1078 (86.2) | Age >40 years; no medically confirmed diagnosis of obstructive lung disease or medical history of any other pulmonary disease, thoracic surgery in past 6 months, acute respiratory infection, or uncontrolled cardiac disease. Recruitment setting/strategy: primary care clinics of 50 general practitioners, the first 50 patients age >40 seen in the clinic. | 65.3 | 42.9 [c] | Current/former: 48.8 Mean pack-years: 19.5 [c] | 0 | Post-BD spirometry^‡^ (FEV_1_/FVC <0.7)

* China, Turkey, Austria, Iceland, South Africa, Poland, Germany, Norway, Canada, Philippines, USA, Australia, United Kingdom, Sweden.

‡ Spirometry required to meet the criteria of the American Thoracic Society/European Respiratory Society Task Force on standardization of lung function testing.108,109

§ PLATINO: Conducted in 5 Latin American cities: Sao Paulo, Brazil, Mexico City, Mexico, Montevideo, Uruguay, Santiago de Chile, and Caracas; additionally, 12 sites from BOLD were used: Guangzhou, China; Adana, Turkey; Salzburg, Austria; Hanover, Germany; Krakow, Poland; Sydney, Australia; Reykjavik, Iceland; Vancouver, BC, Canada; Lexington, Kentucky, USA; Manila, the Philippines; Cape Town, South Africa; and Bergen, Norway.

|| Ever told by a health care provider they had chronic bronchitis, emphysema, or COPD.

# Mild disease is classified as disease negative based on this definition.

Abbreviations: BD = bronchodilator; BOLD = Burden of Obstructive Lung Disease; COPD = chronic obstructive pulmonary disease; FEV_1_ = forced expiratory volume in 1 second; FEV_6_ = forced expiratory volume in 6 seconds; FVC = forced vital capacity; LLN = lower limit of normal; N = number; NR = not reported; PLATINO = Proyecto Latinoamericano de Investigación en Obstrucción Pulmonar.

Table 11 Diagnostic Accuracy of Pulmonary Function Screening Tests, Sorted by Index Test

Study, Year Quality | Population | Index Test | Index Test Cutoff | Sensitivity (95% CI) | Specificity (95% CI) | PPV (95% CI) | NPV (95% CI) | AUC
Jithoo, 2013^67^ Fair | General population | PEF (L/s/m^2^) | <2.2 L/s/m^2^ | 84^*^ (81 to 86)^¶^ | 84^*^ (83 to 85)^¶^ | 31^*^ (29 to 33)^¶^ | 98^*^ (98 to 99)^¶^ | NR
Jithoo, 2013^67^ Fair | General population | PEF (L/s/m^2^) | <1.8 L/s/m^2^ | 64^*^ (60 to 67)^¶^ | 95^*^ (95 to 96)^¶^ | 55^*^ (51 to 58)^¶^ | 97^*^ (96 to 97)^¶^ | NR
Jithoo, 2013^67^ Fair | General population | PEF (L/s/m^2^) | <1.3 L/s/m^2^ | 31^*^ (28 to 34)^¶^ | 99^*^ (99 to 100)^¶^ | 83^*^ (79, 87)^¶^ | 94^*^ (94, 95)^¶^ | NR
Perez-Padilla 2009^91^ Fair | General population | PEF (L/s/m^2^) in low-risk patients | <80% predicted | NR | NR | NR | NR | 0.66
Perez-Padilla 2009^91^ Fair | General population | PEF (L/s/m^2^) in increased-risk patients^‡^ | <70% predicted | GOLD Stages III–IV: 96 (95 to 96) GOLD Stage II: 54 (53 to 54) | NR | NR | GOLD Stages III–IV: 99.9 (99.9 to 99.9) GOLD Stage II: 97 (96 to 97) | GOLD Stages I–IV (high risk): 0.76
Perez-Padilla 2009^91^ Fair | General population | PEF (L/s/m^2^) in increased-risk patients^‡^ | <80% predicted | GOLD Stages III–IV: 97 (96 to 96) GOLD Stage II: 70 (70 to 71) | NR | NR | GOLD Stages III–IV: 99.9 (99.9 to 99.9) GOLD Stage II: 98 (97 to 98)
Frith, 2011^39^ Good | Current or former smokers | Pre-BD FEV_1_/FEV_6_ | FEV_1_/FEV_6_ <0.70 | 51 (37 to 64) | 93 (87 to 96) | 73 (56 to 85) | 83 (76 to 88) | 0.85
Frith, 2011^39^ Good | Current or former smokers | Pre-BD FEV_1_/FEV_6_ | FEV_1_/FEV_6_ <0.75 | 81 (68 to 90) | 71 (63 to 79) | 52 (41 to 63) | 91 (84 to 95) | 0.85
Thorn, 2012^118^ # Fair | Current or former smokers | Pre-BD FEV_1_/FEV_6_ | FEV_1_/FEV_6_ <0.70 | 53 (42 to 64)^¶^ | 90 (85 to 93)^¶^ | 63 (51 to 74)^¶^ | 85 (80 to 89)^¶^ | 0.84
Thorn, 2012^118^ # Fair | Current or former smokers | Pre-BD FEV_1_/FEV_6_ | FEV_1_/FEV_6_ <0.73 | 79 (69 to 87)^¶^ | 80 (75 to 85)^¶^ | 58 (48 to 67)^¶^ | 92 (88 to 95)^¶^ | 0.84
Thorn, 2012^118^ # Fair | Current or former smokers | Pre-BD FEV_1_/FEV_6_ | FEV_1_/FEV_6_ <0.75 | 86 (77 to 92)^¶^ | 72 (66 to 78)^¶^ | 51 (43 to 60)^¶^ | 94 (89 to 97)^¶^ | 0.84
Sichletidis, 2011^36^ Fair | Smokers and nonsmokers from primary care | Post-BD FEV_1_/FEV_6_ | FEV_1_/FEV_6_ <0.70 | 80 (72 to 87)^¶^ | 95 (93 to 96)^¶^ | 64 (56 to 72)^¶^ | 98 (97 to 99)^¶^ | NR
Sichletidis, 2011^36^ Fair | Smokers and nonsmokers from primary care | Post-BD FEV_1_/FEV_6_ in smokers only | FEV_1_/FEV_6_ <0.70 | 80 | 94 | 75 | 96 | NR

* Moderate or severe disease only.

‡ Considered increased risk if they met any of the following criteria: “usually” coughing or bringing up phlegm, wheezing in the last year, and dyspnea on exertion (Medical Research Council [MRC] Dyspnea Scale score >1), more than 10 pack-years of smoking, more than 200 hour-years of exposure to biomass smoke or coal smoke, more than 5 years of workplace exposure to dust or smoke, or a previous medical diagnosis of asthma, COPD, chronic bronchitis, or emphysema.

¶ Calculated.

# Reports posttest dizziness (n=1), chest pain (n=1), shortness of breath (n=1).

Abbreviations: AUC = area under the curve; BD = bronchodilator; CI = confidence interval; FEV_1_ = forced expiratory volume in 1 second; FEV_6_ = forced expiratory volume in 6 seconds; FVC = forced vital capacity; GOLD = Global Initiative for Chronic Obstructive Lung Disease; NPV = negative predictive value; NR = not reported; PEF = peak expiratory flow; PPV = positive predictive value.

### Detailed Results

We identified five publications describing two index tests used for COPD screening: prebronchodilator PEF and pre- and postbronchodilator FEV_1_/FEV_6_ (Table 10). Two studies describe the screening accuracy of PEF67,91 and three studies report the screening accuracy of FEV_1_/FEV_6_.36,39,118

#### PEF

##### Description of Included Studies

Two studies (n=23,098) explored the screening accuracy of PEF in COPD diagnosis (Table 10). PEF cutoffs differed in the two studies; Jithoo used absolute thresholds of 1.3, 1.8, and 2.2 L/s/m^2^, while Perez-Padilla used percent predicted cutpoints of 70 and 80 percent. Both studies administered postbronchodilator spirometry as the reference test;108,109 however, only one study required tests to meet ATS/ERS quality standards.67 The threshold for COPD diagnosis was defined differently across studies; Jithoo required an FEV_1_/FVC of less than the LLN and an FEV_1_ of less than 80 percent of predicted,67 while Perez-Padilla used an FEV_1_/FVC ratio of less than 0.70.^91^ Jithoo also defined those with mild COPD by GOLD criteria as disease free, limiting the applicability of its results to screen detection of mild COPD, whereas Perez-Padilla considered those with mild COPD by GOLD criteria to be disease positive. Both studies were performed internationally as part of the BOLD initiative in countries recruiting general population patients age 40 years and older; Perez-Padilla additionally included patients from the Proyecto Latinoamericano de Investigación en Obstrucción Pulmonar (PLATINO) study, which aimed to describe the epidemiology of COPD in five major Latin American cities.91 Jithoo included 19.7 percent with preexisting self-reported COPD, emphysema, chronic bronchitis, or asthma, while Perez-Padilla did not report preexisting respiratory disease; however, since participants came from the BOLD and PLATINO studies, we would expect some proportion of individuals to already have respiratory disease. Approximately half (57.2% and 45.2%) had a smoking history, with a mean smoking exposure of 26.6 (male) and 19.3 (female) pack-years in one study67 and 22.7 pack-years (both sexes combined) in the other study.91 The mean age was approximately 56 years in both studies. Perez-Padilla reported results stratified into “a priori” increased risk of having COPD versus low risk. The increased risk group represented about three fourths of the entire population and was defined by any of the following criteria: “usually” coughing or bringing up phlegm, wheezing in the last year, and dyspnea on exertion (Medical Research Council [MRC] Dyspnea Scale score >1); more than 10 pack-years of smoking; more than 200 hour-years of exposure to biomass smoke or coal smoke; more than 5 years of workplace exposure to dust or smoke; or a previous medical diagnosis of asthma, COPD, chronic bronchitis, or emphysema.

##### Outcomes

COPD prevalence for moderate to severe COPD was 8.1 percent in the general population study by Jithoo et al, with 56.2 percent of these patients having moderate COPD (Table 12).67 In this study, 3.0 to 21.7 percent screened positive for moderate to severe COPD depending on the PEF threshold (1.3, 1.8, or 2.2 L/s/m^2^). In the more applicable general population study by Perez-Padilla, the prevalence of COPD was 16.9 percent, with 90.1 percent of these patients having mild or moderate COPD. The prevalence was higher among those a priori classified as having increased risk of disease (19.5% vs. 7.9% in the low risk group) and it had fewer patients with mild to moderate disease (89.2% vs. 97.5% in the low risk group).

Table 12 Screening Yield of Pulmonary Function Screening Tests, Sorted by Index Test

Study, Year Quality | Population | Index Test | Incomplete Index Test, (%) Incomplete Reference Spirometry, (%) | COPD Prevalence in Population ([TP+FN]/N analyzed), (%) Mild to Moderate Diagnoses, (%) | Index Test Cutoff | Screen Positives ([TP+FP]/N analyzed), (%)
Jithoo, 2013^67^ Fair | General population | PEF (L/s/m^2^) | 711/10,712 (6.6)^*^ † | 756/9390 (8.1)^†^ | <2.2 L/s/m^2^ | 2033/9390 (21.7)^§^
Jithoo, 2013^67^ Fair | General population | PEF (L/s/m^2^)
Jithoo, 2013^67^ Fair | General population | PEF (L/s/m^2^) | | | <1.8 L/s/m^2^ | 881/9390 (9.4)^§^
Jithoo, 2013^67^ Fair | General population | PEF (L/s/m^2^)
Jithoo, 2013^67^ Fair | General population | PEF (L/s/m^2^) | 711/10,712 (6.6)^*^ † | 425/756 (56.2)^‡^ | <1.3 L/s/m^2^ | 282/9390 (3.0)^§^
Perez-Padilla 2009^91^ Fair | General population | PEF (L/s/m^2^) in low-risk patients | NR | 244/3092 (7.9) | <80% predicted | 275/3092 (8.9)^§^
Perez-Padilla 2009^91^ Fair | General population | PEF (L/s/m^2^) in low-risk patients | NR | 238/244 (97.5)^§^
Perez-Padilla 2009^91^ Fair | General population
Perez-Padilla 2009^91^ Fair | General population | PEF (L/s/m^2^) in increased-risk patients\|\| | | 2070/10,616 (19.5)^§^ | <70% predicted | NR
Perez-Padilla 2009^91^ Fair | General population | PEF (L/s/m^2^) in increased-risk patients\|\|
Perez-Padilla 2009^91^ Fair | General population | PEF (L/s/m^2^) in increased-risk patients\|\| | | 1847/2070 (89.2)^§^ | <80% predicted | 2293/10,616 (21.6)^§^
Frith, 2011^39^ Good | Current or former smokers | Pre-BD FEV_1_/FEV_6_ | NR | 57/204 (27.9)^§^ | FEV_1_/FEV_6_ <0.70 | 39/204 (19.1)^§^
Frith, 2011^39^ Good | Current or former smokers | Pre-BD FEV_1_/FEV_6_
Frith, 2011^39^ Good | Current or former smokers | Pre-BD FEV_1_/FEV_6_ | 29/233 (12.4)^¶^ | 54/57 (94.7)^§^ | FEV_1_/FEV_6_ <0.75 | 88/204 (43.1)^§^
Thorn, 2012^118^ Fair | Current or former smokers | Pre-BD FEV_1_/FEV_6_ | NR | 77/305 (25.2) | FEV_1_/FEV_6_ <0.70 | 65/305 (21.3)^§^
Thorn, 2012^118^ Fair | Current or former smokers | Pre-BD FEV_1_/FEV_6_
Thorn, 2012^118^ Fair | Current or former smokers | Pre-BD FEV_1_/FEV_6_ | NR | 76/77 (98.7)^§^ | FEV_1_/FEV_6_ <0.73 | 106/305 (34.8)^§^
Thorn, 2012^118^ Fair | Current or former smokers | Pre-BD FEV_1_/FEV_6_
Thorn, 2012^118^ Fair | Current or former smokers | Pre-BD FEV_1_/FEV_6_ | | | FEV_1_/FEV_6_ <0.75 | 129/305 (42.3)^§^
Sichletidis, 2011^36^ Fair | Smokers and nonsmokers from primary care | Post-BD FEV_1_/FEV_6_ | NR 172/1250 (13.8)^#^ | 111/1078 (10.3) | FEV_1_/FEV_6_ <0.70 | 139/1078 (12.9)^§^
Sichletidis, 2011^36^ Fair | Smokers and nonsmokers from primary care | Post-BD FEV_1_/FEV_6_ | | 93/111 (83.8)^§^
Sichletidis, 2011^36^ Fair | Smokers and nonsmokers from primary care
Sichletidis, 2011^36^ Fair | Smokers and nonsmokers from primary care | Post-BD FEV_1_/FEV_6_ in smokers only | | 90/522 (17.2)^§^ | FEV_1_/FEV_6_ <0.70 | 98/522 (18.8)^§^
Sichletidis, 2011^36^ Fair | Smokers and nonsmokers from primary care | Post-BD FEV_1_/FEV_6_ in smokers only | | NR

* Poor-quality spirometry.

† Moderate or severe disease only.

‡ Moderate disease only.

§ Calculated.

|| Considered increased risk if they met any of the following criteria: “usually” coughing or bringing up phlegm, wheezing in the last year, and dyspnea on exertion (Medical Research Council [MRC] Dyspnoea Scale score >1), more than 10 pack-years of smoking, more than 200 hour-years of exposure to biomass smoke or coal smoke, more than 5 years of workplace exposure to dust or smoke, or a previous medical diagnosis of asthma, COPD, chronic bronchitis, or emphysema.

¶ Spirometry invalid, incomplete, or not undertaken.

# Refused or unacceptable spirometry.

Abbreviations: BD = bronchodilator; c = calculated; COPD = chronic obstructive pulmonary disease; FEV_1_ = forced expiratory volume in 1 second; FEV_6_ = forced expiratory volume in 6 seconds; FN = false negative FP = false positive; FVC = forced vital capacity; N = number; NR = not reported; PEF = peak expiratory flow; TP = true positive.

The sensitivity reported in Jithoo ranged from 31 (for PEF <1.3 L/s/m^2^) to 84 percent (for PEF <2.2 L/s/m^2^) and specificity ranged from 84 (for PEF <2.2 L/s/m^2^) to 99 percent (for PEF <1.3 L/s/m^2^) for detection of moderate to severe COPD (Table 11).67 The PPV ranged from 31 (for PEF <2.2 L/s/m^2^) to 83 percent (for PEF <1.3 L/s/m^2^); the NPV ranged from 94.3 (for PEF <1.3 L/s/m^2^) to 98.3 percent (for PEF <2.2 L/s/m^2^) for detection of moderate to severe COPD. However, it is unclear how these estimates could be used to anticipate the performance of PEF screening in primary care given that mild COPD patients were counted as disease negative. In the study by Perez-Padilla et al, the AUC for any severity of COPD was 0.66 for a threshold of less than 80 percent predicted for the detection of COPD among patients at low risk for COPD; however, other test performance characteristics were not reported for patients at low risk of COPD (Table 11).91 Test performance characteristics for the a priori increased risk group represented those with already diagnosed asthma, COPD, chronic bronchitis, or emphysema symptoms, and/or 10-year smoking history or other environmental exposure. Thus, the performance characteristics in this population would not be applicable to a full screening population. Sensitivity and specificity for using a threshold of less than 70 percent were reported by GOLD stage and only for stages corresponding to moderate or more severe disease but not mild COPD. Sensitivity was 96 percent for detecting severe to very severe COPD and 54 percent for detecting moderate COPD. Using a less than 80 percent predicted PEF threshold in the high risk patients, sensitivity was 97 percent for severe to very severe COPD (NPV, 99.9%) and 70 percent for moderate COPD (NPV, 98%). Given that these analyses are limited to a preselected, high-risk population enriched with patients with preexisting disease, it is unclear how these estimates could be used to anticipate the performance of PEF screening in primary care.

##### Critical Appraisal

Overall, neither of these two large PEF studies (>20,000 patients) is directly applicable to U.S. primary care populations, because despite large population-based sampling, the sample is enriched with those with known preexisting obstructive lung disease and includes participants from low-index countries with high environmental exposures. Heterogeneity in index test thresholds and reference standard cutoffs for COPD diagnosis (especially defining mild COPD as disease free) make robust, generalizable conclusions regarding screening accuracy impossible.

#### FEV_1_/FEV_6_

##### Description of Included Studies

One good- and two fair-quality cross-sectional diagnostic accuracy studies (n=1,587) explored the predictive accuracy of FEV_1_/FEV_6_ in COPD diagnosis (Table 10).36,39,118 Two studies examined the use of prebronchodilator FEV_1_/FEV_6_ generated using a handheld mini-spirometer (COPD-6; Vitalograph, Inc., Lenexa, KS) or flow meter (PiKo-6; nSpire Health, Inc., Longmont, CO)39,118 and one study used postbronchodilator FEV_1_/FEV_6_ based on the handheld flow meter (PiKo-6).36 Studies were in Australia,39 Greece,36 and Sweden.118 Two of these studies recruited patients from primary care practices36,118 and one study recruited from primary care practices and local newspapers.39 The lower age limit for recruitment was 40 years; mean or median age ranged from 61.0 to 65.3 years. Women represented 31.0 to 56.7 percent of the recruited population. Two studies excluded those with prior lung disease,36,39 while one did not exclude prior lung disease and did not report proportion of recruited population with known lung disease.118 Two studies39,118 only recruited participants with a smoking history and one required participants to have a smoking history of 15 pack-years or more;118 one study recruited both smokers and nonsmokers with approximately half being ever smokers (48.8%).36 Mean smoking exposures in the three studies ranged from 19.5 to 39.0 pack-years.36,39,118

All three studies used postbronchodilator FEV_1_/FVC as the reference standard and required that spirometry meet ATS/ERS quality reference standards.108,109 All three studies used an absolute postbronchodilator FEV_1_/FVC cutpoint of less than 0.70;^36,39,118^ one of these additionally specified irreversibility.39 Two studies reported the number of recruited participants excluded for incomplete or unacceptable spirometry, which ranged from 12.4 to 13.8 percent (Table 12).36,39 Two of the studies used a prebronchodilator FEV_1_/FEV_6_ cutpoint of less than 0.70 for a positive screening test and also examined the impact of higher cutpoints.39,118 One study used a postbronchodilator FEV_1_/FEV_6_ cutpoint of less than 0.70 for a positive screening test.36

##### Outcomes

Spirometrically-confirmed prevalence of any stage COPD ranged from 10.3 in a general population to 27.9 percent, with the highest prevalence reported in the Australian study of ever smokers with a mean of 39 pack-years of smoking exposure (Table 12).39 This study also required evidence of irreversibility as part of its diagnostic criteria for COPD. The majority (84% to 99%) of these COPD patients had mild to moderate COPD. Using a screening FEV_1_/FEV_6_ cutpoint of less than 0.70, 12.9 to 21.3 percent of those screened tested positive on the index test. The lowest rate of screen positives occurred in the general population group, whose screening was based on postbronchodilator flow meter results. The two studies using prebronchodilator results for screening reported AUCs of 0.84 and 0.85 for the FEV_1_/FEV_6_ threshold of less than 0.70 (Table 11).39,118 The corresponding sensitivity for prebronchodilator screening ranged from 51 to 53 percent, while specificity ranged from 89.5 to 93.0 percent (PPV, 63% to 73%; NPV, 83% to 85%). For the study using postbronchodilator screening, sensitivity was 80.2 percent and specificity was 95 percent (PPV, 64%; NPV, 98%).

The study from Greece by Sichletidis, which used postbronchodilator FEV_1_/FEV_6_, clearly excluded those with preexisting disease but was based in a primary care population. Authors reported test performance in a subanalysis limited to current smokers. Although within-study results potentially offer the best comparative test performance information, comparative results should be viewed as unsubstantiated since data were insufficiently reported to allow the independent computation of 2×2 tables for screening pulmonary function tests in the subpopulation of smokers, as was also the case for the use of the CDQ questionnaire in the same study. The data we did derive (Table 12) are consistent with an increase in test positives when screening in ever smokers, as is logical. However, limiting to ever smokers results in missing 21 cases of COPD in never smokers, in addition to the six cases missed in smokers due to imperfect sensitivity.

##### Critical Appraisal

In terms of applicability, none of the three FEV_1_/FEV_6_ studies were performed in a U.S. population. The results from Sichletidis may most closely resemble a population that would be considered for screening in the United States because it was performed in more than 1,000 patients from primary care clinics, includes a subanalysis of smokers only, and excludes participants with known COPD; however, there may be different environmental exposures in this nonU.S.-based setting.36 In addition, this study was performed using screening with postbronchodilator FEV_1_/FEV_6_, which may limit its applicability in general practice due to the need for providing bronchodilator agents. The Australian study by Frith utilizes prebronchodilator FEV_1_/FEV_6_ screening and may also be considered close to a U.S. primary care population of smokers with a heavy smoking exposure burden without known preexisting disease.39 Both Sichletidis and Frith have a similar percentage of patients who screened positive. Frith has a much lower sensitivity for the 0.70 cutpoint (51.0% vs. 80.2%). It appears that the use of bronchodilator agents during screening may greatly improve the performance of FEV_1_/FEV_6_ screening. However, the lower performance reported in Frith may be due to the fact that this study requires a reversibility component of the reference standard (postbronchodilator spirometry FEV_1_/FVC <0.70, reversibility ≤200 mL, and ≤12% from baseline prebronchodilator FEV_1_), which could result in moving screen-positive patients from those who are disease positive to those who are disease negative. Therefore, there are fewer people in the numerator for the sensitivity analysis, making the sensitivity look worse than other studies without the same reference standard components.

#### Combined Accuracy of Questionnaire and FEV_1_/FEV_6_

One cross-sectional diagnostic accuracy study by Sichletidis (n=1,078), already reviewed for the CDQ and FEV_1_/FEV_6_ index tests above, also reported the combined accuracy of screening using the CDQ screening questionnaire and the FEV_1_/FEV_6_ index test.36 Authors performed analyses considering combination results from both tests, as might be seen in a sequential screening approach, although complete test performance data were not reported for a strategy of either test positive.

In this study set in Greece, adults age 40 years and older without prior diagnoses of pulmonary disease were recruited from primary care clinics.36 All patients received both the CDQ questionnaire and the FEV_1_/FEV_6_ postbronchodilator screening test, followed by confirmatory postbronchodilator FEV_1_/FVC spirometry. In the analysis whereby the screening test was considered positive only if both CDQ and FEV_1_/FEV_6_ tests were positive, the reported sensitivity and specificity were 72 and 97 percent, respectively, in the entire population; reported sensitivity and specificity in a subset of smokers only were similar, although data were insufficient to confirm any of these test performance data through replication of 2×2 tables. The PPV was reported as 71 percent and the NPV was 97 percent in the entire population. In the subset of smokers only the reported PPV was 82 percent and the NPV was 95 percent. Overall, as would be expected with a more stringent standard, the sensitivity for the combined tests was lower than that of either the pulmonary testing or CDQ alone (72% vs. 80% and 91%, respectively). However, the specificity of testing was marginally improved over FEV_1_/FEV_6_ testing alone (97% vs. 95%) and significantly better than that of the CDQ alone (49%). NPVs remained similar; however, the PPV was increased over pulmonary tests or the CDQ alone, particularly in the analysis limited to smokers only.

## KQ 4 What Are the Adverse Effects of Screening for COPD With Prescreening Questionnaires or Screening Pulmonary Function Tests?

### Summary of Findings

Evidence of screening harms from diagnostic accuracy studies was limited; only false positives and false negatives associated with screening were reported, and few studies reported data so the number of missed cases could be calculated. Additionally, for each screening strategy, relatively few studies were available. The proportion of cases missed by the CDQ (false-negative rate) varied widely, from 9.0 to 37.0 percent, and was lowest when using the most sensitive screening threshold. For the CDQ threshold of less than 16.5 for screen negatives, and limiting to studies in which fewer than 20 percent of spirometry tests were invalid or incomplete, the proportion of missed spirometry-diagnosed COPD cases was around 10 percent. In these same studies, increasing the screening threshold to less than 19.5 increased the number of missed COPD cases to 27.9 to 34.2 percent. Missed diagnoses and the false-positive rate could not be reliably estimated for the LFQ, because only a subset of screen-negative patients received diagnostic spirometry in the single external validation study of this questionnaire; however, the majority of those who screened positive on the questionnaire were determined to be false positives (74.2%). The COPD-PS had a much lower false-positive rate compared to the CDQ or LFQ; at a cutpoint of 4 or greater, the COPD-PS resulted in a false-positive rate of 27 percent, with 33 percent missed cases (Table 13).

Table 13 Screening Harms for Externally Validated COPD Prescreening Questionnaires

Tool | Study, Year Quality | Population | Cutoff | False-Positive Rate (FP/FP+TN) | Proportion of COPD Diagnoses Missed (FN/TP+FN), (%)
CDQ | Stanley, 2014^115^ Fair | Current or former smokers | Intermediate/high likelihood (>16.5) | 487/916 (53.2)^*^ | 28/138 (20.3)^*^
CDQ | Stanley, 2014^115^ Fair | Current or former smokers | High likelihood (>19.5) | 274/916 (29.9)^*^ | 51/138 (37.0)^*^
CDQ | Dirven, 2013^110^ Fair | General population | High likelihood (>19.5) | NR | NR
CDQ | Frith, 2011^39^ Good | Current or former smokers | Intermediate/high likelihood (>16.5) | NR (73)^*^ | NR (9)^*^
CDQ | Frith, 2011^39^ Good | Current or former smokers | High likelihood (>19.5) | NR (38) | NR (29)
CDQ | Sichletidis, 2011^36^ Fair | Smokers and nonsmokers from primary care | Intermediate/high likelihood (>16.5)^‡^ | 493/967 (51.0)^*^ | 10/111 (9.0)^*^
CDQ | Sichletidis, 2011^36^ Fair | Smokers and nonsmokers from primary care | High likelihood (>19.5)^‡^ | 222/967 (23.0)^*^ | 31/111 (27.9)^*^
CDQ | Sichletidis, 2011^36^ Fair | Smokers and nonsmokers from primary care | Intermediate/high likelihood (>16.5)^‡^ in smokers only | 263/432 (60.9)^*^ | 6/90 (6.7)^*^
CDQ | Kotz, 2008^89^ Good | Current smokers | Intermediate likelihood (>16.5) | 301/398 (75.6)^*^ | 30/278 (10.8)^*^
CDQ | Kotz, 2008^89^ Good | Current smokers | High likelihood (>19.5) | 183/398 (46.0)^*^ | 95/278 (34.2)^*^
LFQ | Mintz, 2011^111^ Fair | Current or former smokers | ≤18 | NR^†^ | NR^†^
COPD-PS | Tsukuya, 2015 | General population | ≥4 | 597/2,204 (27.1)^*^ | 50/153 (32.7)^*^
COPD-PS | Tsukuya, 2015 | General population | ≥5 | 456/2,204 (20.7)^*^ | 100/153 (65.4)^*^

* Calculated.

† Patients recruited for diagnostic spirometry included all screen-positive patients (LFQ ≤18) and a subset of screen-negative patients (49/359). 5/49 patients were false negatives (10.2%).

‡ Study used the cutpoints of ≥17 points for intermediate likelihood and ≥20 points for high likelihood.

Abbreviations: CDQ = COPD Diagnostic Questionnaire; COPD = chronic obstructive pulmonary disease; FN = false negative; FP = false positive; LFQ = Lung Function Questionnaire; NR = not reported; TP = true positive.

Similarly, the false-negative rate associated with the two screening pulmonary function tests (prebronchodilator PEF, pre- and postbronchodilator FEV_1_/FEV_6_) ranged broadly, from 14.3 to 68.9 percent of cases missed based on test and cutoff applied; however, data were scant for these tests (Table 14). False-positive rates varied widely based on the screening test and threshold for positivity, with rates of around 28 percent for the most sensitive screening thresholds. Given the clinical application of prescreening questionnaires to enrich a population for more intensive, but still relatively harmless, spirometric screening, minimizing false negatives may take precedence over minimizing false positives.

Table 14 Screening Harms for Pulmonary Function Screening Tests, Sorted by Index Test

Study, Year Quality | Population | Index Test | Index Test Cutoff | False-Positive Rate (FP/FP+TN) | Proportion of COPD Diagnoses Missed (FN/TP+FN), (%)
Jithoo, 2013^67^ Fair | General population | PEF (L/s/m^2^) | <2.2 L/s/m^2^ | 1399/8634 (16.2)^§^ ¶ | 122/756 (16.1)^¶^
Jithoo, 2013^67^ Fair | General population | PEF (L/s/m^2^) | <1.8 L/s/m^2^ | 399/8634 (4.4)^§^ ¶ | 274/756 (36.2)^¶^
Jithoo, 2013^67^ Fair | General population | PEF (L/s/m^2^) | <1.3 L/s/m^2^ | 47/8634 (0.5)^§^ ¶ | 521/756 (68.9)^¶^
Perez-Padilla 2009^91^ Fair | General population | PEF (L/s/m^2^) in low-risk patients | <80% predicted | NR | NR
Perez-Padilla 2009^91^ Fair | General population | PEF (L/s/m^2^) in increased-risk patients\|\| | <70% predicted | NR | NR
Perez-Padilla 2009^91^ Fair | General population | PEF (L/s/m^2^) in increased-risk patients\|\| | <80% predicted | NR | NR
Frith, 2011^39,¶^ Good | Current or former smokers | Pre-BD FEV_1_/FEV_6_ | FEV_1_/FEV_6_ <0.70 | 11/147 (7.5)^¶^ | 28/57 (49.1)^¶^
Frith, 2011^39,¶^ Good | Current or former smokers | Pre-BD FEV_1_/FEV_6_ | FEV_1_/FEV_6_ <0.75 | 42/147 (28.6)^¶^ | 11/57 (19.3)^¶^
Thorn, 2012^118^ Fair | Current or former smokers | Pre-BD FEV_1_/FEV_6_ | FEV_1_/FEV_6_ <0.70 | 24/228 (10.5)^¶^ | 36/77 (46.8)^¶^
Thorn, 2012^118^ Fair | Current or former smokers | Pre-BD FEV_1_/FEV_6_ | FEV_1_/FEV_6_ <0.73 | 45/228 (19.7)^¶^ | 16/77 (20.8)^¶^
Thorn, 2012^118^ Fair | Current or former smokers | Pre-BD FEV_1_/FEV_6_ | FEV_1_/FEV_6_ <0.75 | 63/228 (27.6)^¶^ | 11/77 (14.3)^¶^
Sichletidis, 2011^36^ Fair | Smokers and nonsmokers from primary care | Post-BD FEV_1_/FEV_6_ | FEV_1_/FEV_6_ <0.70 | 50/967 (5.2)^¶^ | 22/111 (19.8)^¶^
Sichletidis, 2011^36^ Fair | Smokers and nonsmokers from primary care | Post-BD FEV_1_/FEV_6_ in smokers only | FEV_1_/FEV_6_ <0.70 | 26/432 (6.0)^¶^ | 18/90 (20.0)^¶^

§ Mild disease counted as a false positive.

|| Considered increased risk if they met any of the following criteria: “usually” coughing or bringing up phlegm, wheezing in the last year, and dyspnea on exertion (Medical Research Council [MRC] Dyspnea Scale score >1), more than 10 pack-years of smoking, more than 200 hour-years of exposure to biomass smoke or coal smoke, more than 5 years of workplace exposure to dust or smoke, or a previous medical diagnosis of asthma, COPD, chronic bronchitis, or emphysema.

¶ Calculated.

Abbreviations: BD = bronchodilator; COPD = chronic obstructive pulmonary disease; FEV_1_ = forced expiratory volume in 1 second; FEV_6_ = forced expiratory volume in 6 secons; FN = false negative FP = false positive; FVC = forced vital capacity; NR = not reported; PEF = peak expiratory flow; TP = true positive.

We identified no qualitative studies on psychological, quality of life, or other harms associated with screening questionnaires or pulmonary function tests.

### Detailed Results

#### False-Negative and False-Positive Results on Prescreening Questionnaires

False positives were common in the external validation studies of the CDQ prescreening questionnaire, and, for a CDQ score of greater than 16.5, the number of false positives exceeded true positives in all populations. False-positive rates (percent of COPD-free patients who will screen positive) were highest (76%) in a population of current smokers and lowest (51%) in the general population. Increasing the CDQ cutpoint to greater than 19.5 considerably improved false-positive rates, but at the cost of more missed COPD cases (Table 13).36,39,89,115 False-negative rates (missed diagnoses) at a CDQ cutpoint of greater than 16.5 ranged from 9 to 20 percent;36,39, 89,115 when limited to studies with higher quality spirometry (≤20% invalid/incomplete results), around 10 percent of diagnoses would be missed.36,89 Raising the CDQ cutpoint to 19.5 or higher greatly increased false-negative rates (28% to 34% in best estimates).36,89 When considering reported results in subgroups (i.e., results reported among ever smokers only), false-negative rates understate the actual missed diagnoses. In the one study that reported results in subgroups, fewer diagnoses appear to be missed among smokers than among the general population (6.7% vs. 9.0%); however, screening limited to smokers would have missed additional COPD diagnoses occurring in 3.8 percent of the nonsmokers in the population.36 Thus, the true missed diagnoses in an ever smoker strategy compared to a general population strategy would represent false negatives in smokers and all cases in never smokers (27 persons, about one quarter of all those with spirometry-detected COPD).

False-negative and false-positive rates could not be reliably estimated for the LFQ, because only a subset of screen-negative patients received diagnostic spirometry in the single external validation study of this questionnaire; however, the majority of those who screened positive on the questionnaire were determined to be false positive (74.2%) (Table 13).111

The COPD-PS demonstrated a lower false-positive rate compared to the CDQ. At a cutpoint of 4 or greater, the COPD-PS resulted in a false-positive rate of 27 percent, with 33 percent missed cases. At a cutpoint of 5 or greater, the false-positive rate was 21 percent, with more than half of cases missed (65% false negatives).

#### False-Negative and False-Positive Results on Prebronchodilator Screening Pulmonary Function Tests

The false-negative and false-positive rate for PEF was only reported in one67 of the two included PEF studies (Table 12). False-negative rates would be underestimated since mild disease was considered to be screen negative. Reported false-negative rates (missed diagnoses) ranged from 16 to 69 percent of moderate to severe cases being missed, depending on the cutpoints used for prescreening PEF. False-positive rates ranged from less than 1 to 16 percent, again depending on the PEF threshold used. These results are of limited utility for primary care screening due to the population targeted and the design of the study to classify participants with mild disease as screen negatives.67

The two studies39,118 examining prebronchodilator FEV_1_/FEV_6_ in ever smokers only and one study36 examining the postbronchodilator FEV_1_/FEV_6_ pulmonary function test in the general population reported false-negative rates (proportion of total diagnoses missed) ranging from 14 to 49 percent, depending on the threshold used. For the FEV_1_/FEV_6_ index test threshold of less than 0.70, the lowest false-negative rate (19.8%) was seen after postbronchodilator index testing36 (Table 12). Using a prebronchodilator FEV_1_/FEV_6_ cutoff of less than 0.70, the missed cases in two of the trials approached 50 percent.39,118 False-positive rates also varied with index test cutpoint. For the threshold of less than 0.70, false-positive rates ranged from 5 to 10.5 percent,36,39,118 with the lowest rate seen in participants screened using postbronchodilator testing.36 While relatively similar rates of false positives, false negatives, and missed diagnoses were reported for postbronchodilator screening among a subgroup limited to smokers only, these results are misleading from a population perspective. As was the case for data about screening with the CDQ, a screening strategy limited to ever smokers would miss a greater number and proportion of COPD diagnoses than are accounted for in the subsample test performance calculations. Considering all of the 21 missed diagnoses in nonsmokers as well as the 18 false-negative results in smokers, an even larger number and proportion of spirometrically-detected COPD cases (39 total cases [35%]) would be missed through prescreening only ever smokers using office spirometry.36 When analyzed to consider a combination screening approach requiring a positive screen of 16.5 on the CDQ plus postbronchodilator FEV_1_/FEV_6_, even more cases would be missed (estimated at 28% in the general population), but the false-positive rate would be improved (estimated at 3%). Data were not available to evaluate combined screening using a threshold for either test positive.36

## KQ 5 Does Identifying Asymptomatic Adults With Fixed Airflow Obstruction Through Screening Improve the Delivery and Uptake of Targeted Preventive Services? Does Screening for COPD Increase Smoking Cessation Rates or Relevant Immunization Rates Among Asymptomatic Adults Compared to Usual Care?

### Summary of Findings

We identified five fair-quality studies addressing the effectiveness of COPD screening or lung function testing in influencing smoking cessation rates (Table 15). We identified no studies examining the effectiveness of screening in increasing vaccination rates.

Table 15 Study Characteristics of Smoking Cessation Trials

Study, Year Quality | Country Recruitment | N Randomized | Followup | Inclusion | Exclusion | Treatment Comparison | Primary Outcome(s) | Secondary Outcome(s)
Kotz, 2009^121^ Kotz, 2007^166^ Kotz, 2009^124^ Kotz, 2009^167^ Fair | Netherlands General population (ads, flyers, posters, and mailings) and primary care practices | 296 | 12 months | Ages 35–70; ≥10 pack-year history; read/speak Dutch; ≥1 respiratory symptom (cough, sputum, shortness of breath); mild or moderate COPD^*^; interested in quitting smoking | Prior respiratory diagnosis; spirometry in past 12 months; contraindication to nortriptyline; FEV_1_ <50% predicted; FEV_1_/FVC >70% | IG1: CG1 intervention plus discussion of results from spirometry, prognosis of COPD, and challenging irrational beliefs about smoking CG1: 4 40-minute medium-intensity counseling plus nortriptyline CG2: Referral to GP for smoking cessation treatment without information about spirometry results or airflow limitation | Prolonged abstinence from smoking (biochemically validated) | Nicotine dependence (FTND), respiratory health (CCQ), HRQoL (CRQ)
Sippel, 1999^122^ Fair | US Primary care clinics, invitation of all smokers among routinely scheduled outpatients | 205 | 9 months | Smokers age 18+ | Non-English speaking patients, walk-in cases considered emergent | IG: CG intervention plus educational interpretation of spirometry and CO measurement results CG: Individual cessation plan; cessation counseling; solicitation of quit date and clinic or telephone followup at 1 and 4 weeks after quit date (for patients in preparation stage) | Smoking cessation rate (self-reported) | Quit attempts, change in motivational stage
Risser, 1990^120^ Fair | US Randomly selected VA outpatients | 90 | 12 months | Smokers participating in a general preventive intervention VA Demonstration Project | NR | CG: 50-minute educational intervention with self-help program, invitation to a 4-month (9 sessions) one-on-one skills training and counseling program IG: CG intervention plus 10-minute motivational intervention based on spirometry, CO level, and discussion of pulmonary symptoms | Smoking status (self-reported and biochemically validated) | Quit attempts
Parkes 2008^119^ Fair | UK Five general practices | 561 | 12 months | Age ≥35; patient record indicates was a smoker within the last 12 months | Patients receiving oxygen; those with a history of lung cancer, TB, asbestosis, silicosis, bronchiectasis, or pneumonectomy | IG: Assessment interview including spirometry. Strongly encouraged to give up smoking and access local smoking cessation clinics. Patients received their “lung age”^†^ verbally using a graphic display and were counseled that smoking cessation would help to slow down the rate of deterioration of lung function. CG: Assessment interview including spirometry. Strongly encouraged to give up smoking and access local smoking cessation clinics. Patients received their lung function scores (FEV_1_) in the mail with no further explanation. In both groups, if testing indicated asthma, participants were advised to attend GP for management and GP was informed separately. When spirometry suggested restrictive lung disease, participant and GP were sent letter to advise them on further investigation and guidelines on referral to secondary care. | Smoking cessation (biochemically validated) | Change in daily consumption of cigarettes; identification of new diagnoses
McClure, 2009^123^ McClure, 2009^168^ McClure, 2010^169^ Fair | US Community (health plan records, Quitline data, mailing list of smokers, ads) | 542 | 12 months | Smokers; age 18+; read and write English; CO level consistent with current smoking (≥10 ppm) and an average of 15 cigarettes per day for the past year or 10 cigarettes per day for ≥10 years | Currently receiving cessation treatment; significant physical or mental impairment that prevents the use of a computer or phone or impaired comprehension ability; medical contraindication for spirometry | IG: CG intervention plus personally-tailored report with self-reported smoking-related symptoms, smoking-related medical conditions, CO level and values of normal CO of nonsmokers, spirometry test and results (FEV_1_, FVC, FEF_25–75_), lung age^‡^ for individuals with FEV_1_ <80% predicted, graph demonstrating the effect of smoking cessation on lung function, information on the association between smoking and various health conditions. CG: Personalized health risk report and brief (~20 minute) counseling; advice to quit smoking, smoking cessation materials, access to free phone counseling program | Use of counseling program, 7-day point prevalent abstinence (self-reported) | Motivation to quit, quit attempts, use of other smoking cessation treatments, 30-day point prevalent abstinence (self-reported)

* Postbronchodilator FEV_1_/FVC <70% and FEV_1_ ≥50% predicted.

† Men: Lung age=2.87 × height (in inches) − (31.25 × observed FEV_1_ (in liters) − 39.375; Women: Lung age=3.56 × height (in inches) − (40 × observed FEV_1_ (in liters) − 77.28

‡ Calculated using Morris and Temple method.155

Abbreviations: CCQ = Clinical COPD Questionnaire; CG = control group; CO = carbon monoxide; COPD = chronic obstructive pulmonary disease; CRQ = Chronic Respiratory Questionnaire; FEF_25–75_ = average forced expiratory flow during the mid (25%–75%) portion of the FVC; FEV_1_= forced expiratory volume in 1 second; FTND = Fagerstrom Test for Nicotine Dependency; FVC = forced vital capacity; GP = general practitioner; HRQoL = healh-related quality of life; IG = intervention group; N = number; NR = not reported; ppm= parts per million; TB = tuberculosis; UK = United Kingdom; US = United States.

We did not find robust data to support the premise that supplying smokers with spirometry results improves smoking cessation rates (Table 16). However, in all studies, control groups received almost the same smoking cessation support as the spirometry group; studies varied in whether the control group received spirometry testing or not and in whether smoking cessation support was tailored based on spirometry or other medical examination findings. Thus, available studies test the incremental value of adding spirometry to existing smoking cessation programs. Of the three RCTs reporting biochemically confirmed abstinence, only one fair-quality trial119 telling patients their lung age reported a statistically significant difference in the intervention group compared to the control group; one underpowered U.S. Department of Veterans Affairs (VA) trial120 showed a trend toward reduction, and one trial of screen-detected patients with mild to moderate COPD who were motivated to quit showed almost identical rates of biochemically confirmed abstinence rates at 12 months in the intervention and active treatment control groups.121 This trial was likely underpowered, however, particularly for incremental comparative effectiveness.

Table 16 Smoking Cessation Outcomes for Included Trials

Study, Year Quality | Study Group | N Analyzed^†^ | Followup | ≥1 Quit Attempt, % | Self-Reported Smoking Abstinence, % | Biochemically-Validated Smoking Abstinence, % | IG vs. CG | Additional Cessation Outcomes | IG vs. CG
Kotz, 2009^121^ Kotz, 2007^166^ Kotz, 2009^124^ Kotz, 2009^167^ Fair | IG | 116 | 12 months | NR | NR | 11.2 | OR (95% CI): 0.88 (0.38 to 2.03)^§^ | 5-week abstinence (validated): 50.9% Abstinence at 5 to 26 weeks (validated): 30.2%, CG1: 23.2% | 5-week abstinence: OR (95% CI): 1.6 (0.95 to 2.7); p=0.08^§^ Abstinence at 5 to 26 weeks: OR (95% CI): 1.43 (0.79 to 2.58); p=0.236^§^
Kotz, 2009^121^ Kotz, 2007^166^ Kotz, 2009^124^ Kotz, 2009^167^ Fair | CG1 | 112 | 12 months | NR | NR | 11.6 | OR (95% CI): 0.88 (0.38 to 2.03)^§^ | 5-week abstinence (validated): 39.3% Abstinence at 5 to 26 weeks (validated): 23.2% | 5-week abstinence: OR (95% CI): 1.6 (0.95 to 2.7); p=0.08^§^ Abstinence at 5 to 26 weeks: OR (95% CI): 1.43 (0.79 to 2.58); p=0.236^§^
Sippel, 1999^122^ Fair | IG | 103 | 9 months | 48.0 | 9.0 | NR | Self-reported OR (95% CI)^‡^: Any spirometry performed: 0.6 (0.2 to 1.4) Abnormal spirometry results: 0.6 (0.1 to 2.7) | At least one quit attempt during study: 48.0% | OR (95% CI): 1.6 (0.9 to 2.8)
Sippel, 1999^122^ Fair | CG | 102 | 9 months | 36 | 14.0 | NR | Self-reported OR (95% CI)^‡^: Any spirometry performed: 0.6 (0.2 to 1.4) Abnormal spirometry results: 0.6 (0.1 to 2.7) | At least one quit attempt during study: 36.0% | OR (95% CI): 1.6 (0.9 to 2.8)
Risser, 1990^120^ Fair | IG | 45\|\| | 12 months | 40.0 | 24.4\|\| | 20.0\|\| | Self-reported conservative estimate p=0.08\|\| Validated conservative estimate p=0.06\|\| Quit attempts: p=0.015 | NR | NA
Risser, 1990^120^ Fair | CG | 45\|\| | 12 months | 16.3 | 11.1\|\| | 6.7\|\| | Self-reported conservative estimate p=0.08\|\| Validated conservative estimate p=0.06\|\| Quit attempts: p=0.015 | NR | NA
Parkes 2008^119^ Fair | IG | 280 | 12 months | NR | NR | 13.6 | Validated quit rate difference: 7.2% (95% CI, 2.2% to 12.1%); p=0.005 | Used smoking cessation help (clinic, NRT, bupropion, acupuncture): 10.7% Cigarette consumption, self-reported mean (SD): 11.7 (9.7) | Used smoking cessation help: p=0.2 Cigarette consumption: p=0.03
Parkes 2008^119^ Fair | CG | 281 | 12 months | NR | NR | 6.4 | Validated quit rate difference: 7.2% (95% CI, 2.2% to 12.1%); p=0.005 | Used smoking cessation help (clinic, NRT, bupropion, acupuncture): 7.8% Cigarette consumption, self-reported mean (SD): 13.7 (10.5) | Used smoking cessation help: p=0.2 Cigarette consumption: p=0.03
McClure, 2009^123^ McClure, 2009^168^ McClure, 2010^169^ Fair | IG | 267 | 12 months^#^ | 61.5^††^ | 30-day abstinence: 0.9^¶,††^ 7-day abstinence: 13.1^¶,††^ | NR | 30-day abstinence: OR (95% CI): 0.77 (NR); p=0.34^¶^ 7-day abstinence: OR (95% CI): 0.86 (NR); p=0.38^¶^ | Motivation to quit, mean: 3.20^**,††^ Motivation to quit (6 months), mean: 3.26^**^ | Motivation to quit (12 months): p=0.03
McClure, 2009^123^ McClure, 2009^168^ McClure, 2010^169^ Fair | CG | 269 | 12 months^#^ | 62.4 | 30 day abstinence: 13.0^¶^ 7 day abstinence: 14.9^¶^ | NR | 30-day abstinence: OR (95% CI): 0.77 (NR); p=0.34^¶^ 7-day abstinence: OR (95% CI): 0.86 (NR); p=0.38^¶^ | Motivation to quit, mean: 3.42^**^ | Motivation to quit (12 months): p=0.03

* 7.8% of participants stated that routinely measuring lung function in smokers would interfere with one’s freedom of choice; 1.2% said it was not justified for a nurse to confront them with COPD diagnosis.

† All studies assume that anyone lost to followup was a smoker.

‡ Adjusted for age and sex.

§ Adjusted for age, sex, level of education, number of previous cessation attempts, anxiety, nicotine addiction.

|| This analysis includes all patients in the final analysis and assumed missing patients to be smokers. Analysis also available using data only from subjects with known followup smoking status: N analyzed in IG: 32 and CG: 39 (self-report); IG: 27, CG: 30 (validated); cessation: IG: 34.4%, CG: 12.8%, p= 0.03 (self-reported); IG: 33.3%, CG: 10%, p=0.03 (validated).

¶ Similar values seen in analysis using data only from subjects with known followup smoking status.

# Self-reported smoking abstinence at 6 months: 30-day abstinence: IG, 6.4%, CG, 10.8%; OR (95% CI): 0.51 (NR); p= 0.04; 7-day abstinence: IG, 12.0%; CG, 14.1%; OR (95% CI): 0.77 (NR); p= 0.3; motivation to quit, mean**: IG: 3.3, CG: 3.4; p=0.12.

** Measured on a 5-point Likert scale ranging from 1 to 5 (from “not at all” to “extremely”). Motivation to quit measured among smokers only.

†† No significant difference reported between smokers with impaired lung function and those with nonimpaired lung function in the intervention group.

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; N = number; NA = not applicable; NR = not reported; NRT = nicotine replacement therapy; OR = odds ratio; SD = standard deviation.

Two U.S.-based studies powered to detect differences of at least 10 percent in self-reported abstinence rates showed no difference in abstinence at 6-, 9-, and 12-month followup in the intervention group compared to the control group (Table 16).122,123

### Characteristics of Included Studies

We identified five fair-quality studies addressing the effectiveness of COPD screening or lung function testing in influencing smoking cessation rates (1,694 participants) (Table 15).119–123 While this KQ would ideally be based on trials screening for COPD, some of the included trials simply focused on the measurement of participants’ lung function, without also reporting to patients their COPD status. Only one study informed patients they had COPD,121 while four studies only reported on decreased lung function or a patient’s “lung age.”119,120,122,123 Three studies were conducted in the United States,120,122,123 one in the Netherlands,121 and the largest study (n=561) was conducted in the United Kingdom.119 Inclusion criteria for one study required a smoking exposure of at least 10 pack-years,121 but otherwise participants with any history of smoking were included. Two trials recruited participants from primary care clinics,119,122 two recruited participants from the general population,121,123 and one trial recruited U.S. veterans participating in a general preventive intervention VA demonstration project.120 The third largest study, which was from the Netherlands, specifically recruited 296 patients interested in quitting smoking, and this study was also the only study that analyzed screen-detected COPD patients.121 Two studies had a lower age limit of 35 years,119,121 two trials had a lower age limit of 18 years,122,123 and one did not specify a lower age limit.120 The mean age ranged from 38.6 to 54.0 years, with 4.4 to 62.5 percent of participants being women (Table 17). The mean pack-years of smoking exposure ranged from 28.9 to 60.4 pack-years. Only one study specifically excluded persons with a prior respiratory diagnosis,121 while the others presumably would have included those who already had known diagnoses of COPD. Three trials reported the percent of participants with previous quit attempts, which ranged from 10.1 to 82.0 percent.120,122,123 A measure of previous quit attempts was reported in three studies; one study reported that participants had a mean of 3.8 prior quit attempts,121 another reported a mean of 1.56 prior attempts,123 while a third study reported that more than half of participants had 1 to 2 prior quit attempts.120 The mean baseline postbronchodilator FEV_1_ percent predicted was fairly high (mean, 81.5% to 89.5% in the three studies reporting it), indicating that most participants likely had no or mild COPD, which makes these studies potentially quite applicable to a screened population.119,121,122 One study only included patients who screened positive for mild to moderate COPD (FEV_1_ ≥50% but ≤70%), had at least one respiratory symptom, and were motivated to quit.121 Three studies reported motivational stage of change; one reported that 36 percent were prepared to quit,122 one reported that 17 percent were prepared to quit and 22 percent were actively trying to change or had a quit attempt in the past year,119 and a third trial reported that 75.2 percent were in the contemplation or preparation stage at baseline.123 Additionally, one study reported that 20 percent of participants had comorbidity119 and one VA study reported that 21 percent consumed more than four drinks per day.120

Table 17 Baseline Characteristics of Smoking Cessation Trials

Study, Year Quality | N Randomized | Age, years (mean) | Female, % | Smoking History, pack-years (mean) | Any Previous Quit Attempt, % | Number of Previous Quit Attempts | Lung Function Post-BD, FEV_1_ % Predicted of Normal (mean) | Patients With Previously Diagnosed COPD, %
Kotz, 2009^121^ Kotz, 2007^166^ Kotz, 2009^124^ Kotz, 2009^167^ Fair | 296 | 54.0 [c] | 37.5 [c] | 43.5 [c] | NR | 3.8 (mean) [c] | 81.5^†^ | 0^‡^
Sippel, 1999^122^ Fair | 205 | 38.6 [c] | 62.5 [c] | 28.9 [c] | 82.0 [c] | NR^‡^ | 87.0^*^ (range, 31–141) | NR
Risser, 1990^120^ Fair | 90 | NR | 4.4 [c] | 60.4 | 75.6 [c] | 0: 24.0% 1–2: 56.0% ≥3: 20.0% | NR | NR
Parkes 2008^119^ Fair | 561 | 53.0 [c] | 53.8 [c] | 30.7 [c] | NR^§^ | NR | 89.5 | 7.0 [c]
McClure, 2009^123^ McClure, 2009^168^ McClure, 2010^169^ Fair | 542 | 50.8 | 53.2 | NR | 10.1 | 1.6 (mean) | NR | NR

* Reported for intervention group only, does not report if measurements are pre- or postbronchodilator.

† All had mild/moderate COPD (54% mild, 46% moderate).

‡ Patients with pre-existing respiratory disease excluded.

Abbreviations: BD = bronchodilator; c = calculated; COPD = chronic obstructive pulmonary disease; FEV_1_ = forced expiratory volume in 1 second; N = number; NR = not reported.

Interventions and controls varied in the five trials. None of the trials involved completely untouched controls, which complicates the interpretation of primarily null findings. In two of the five trials,119,121 spirometry was administered to all participants (intervention and all control groups); in one of these studies,119 the control group received the raw FEV_1_ results without explanation, while the intervention group received the results communicated in terms of their “lung age.” In the other of the two RCTs,121 the intervention group received confrontational counseling using spirometry results, and the control group did not receive any spirometry results. In two studies, spirometry was only administered in the intervention group (Table 15).120,122 Counseling likewise varied in the trials. In the Netherlands trial, the intervention group received four 40-minute, medium-intensity counseling sessions plus nortriptyline.121 Additionally, the intervention group participated in a discussion of results from spirometry, prognosis of COPD, and challenging irrational beliefs about smoking, while one control group received the four 40-minute, medium-intensity counseling sessions plus nortriptyline, and the second control group received a referral to a primary care physician for smoking cessation treatment without information about spirometry results or airflow limitation.121 Thus, this trial addresses the impact of confrontational counseling about screen-detected COPD on smoking cessation in a select group of individuals, but was not strictly an efficacy trial of spirometry screening since there was no untreated control group. In one U.S.-based trial, the intervention group received an individual cessation plan, cessation counseling, solicitation of a quit date, and clinic or telephone followup at 1 and 4 weeks after the quit date (for patients in preparation stage), plus educational interpretation of spirometry and carbon monoxide (CO) measurement results.122 The control group received identical counseling, excluding spirometry and CO measure interpretation. In the VA trial, the intervention group received a 50-minute educational intervention with a self-help program, invitation to nine one-on-one skills training sessions and counseling program, plus a 10-minute motivational intervention based on spirometry, CO level, and discussion of pulmonary symptoms.120 The control group received the same education as the intervention group without any spirometry or symptom discussion. In the third U.S.-based trial, the intervention group received baseline counseling given to the control group, plus a personally-tailored report with self-reported smoking-related symptoms, smoking-related medical conditions, CO level and the normal CO values of nonsmokers, spirometry test results (FEV_1_, FVC, forced expiratory flow_25–75_), lung age for participants with an FEV_1_ of less than 80 percent of predicted, a graph demonstrating the effect of smoking cessation on lung function, and information on the association between smoking and various health conditions; the control group received a personalized health risk report and brief (about 20-minute) counseling, advice to quit smoking, smoking cessation materials, and access to a free phone counseling program.123 In the U.K.-based study, all patients had an assessment interview and spirometry, along with smoking cessation counseling, but only the intervention group participants received their “lung age” verbally using a graphic display and were counseled that smoking cessation would help to slow down the rate of deterioration of lung function, while the control group participants received their lung function scores (i.e., FEV_1_) in the mail with no further explanation.119

The mean length of followup ranged from 9 to 12 months in the included studies. All five studies used ITT analysis and imputed results conservatively, assuming that all of those lost to followup continued to smoke. One study had a high loss to followup rate at 12 months, with 33.3 to 40.0 percent missing biochemically validated smoking status results.120 Otherwise, the other three trials had loss to followup in the control and intervention groups ranging from 11.0 to 18.6 percent in either group.119,121,122

### Detailed Results

#### Biochemically Validated Smoking Abstinence

Three studies measured abstinence with biochemical confirmation at 12 months (Table 16).119–121 The largest study (n=561), which was conducted among U.K. primary care patients in various stages of change, showed a statistically significant difference in biochemically validated abstinence rates (13.6% vs. 6.4%; validated quit rate difference, 7.2% [95% CI, 2.2 to 12.1]; p=0.005), comparing those who received spirometry-based lung age versus those who did not. This study was not powered to detect that a smoker in the “active” phase of quitting would find feedback on lung age more useful than someone in earlier stages of change.119 One underpowered RCT (n=90) from the VA conducted in patients without any required motivation to quit showed a trend toward, but no statistically significant difference between, higher validated abstinence rates in the intervention group compared to the control group (20.0% vs. 6.7%; p=0.06).120 The third RCT (n=296) of general population screen-detected mild to moderate COPD patients motivated to quit showed nearly identical biochemically validated smoking abstinence in the intervention and control groups in adjusted and unadjusted analyses (adjusted [adj] OR, 0.88 [95% CI, 0.38 to 2.03]).121

#### Self-Reported Smoking Abstinence

Two RCTs reported abstinence rates that were ascertained only by self-report (Table 16).122,123 One adequately powered U.S.-based primary care RCT (n=205) with a mean of 9 months of followup reported no statistically significant difference in self-reported abstinence after adjusting for age and sex (9.0% vs. 14.0%; adjOR, 0.6 [95% CI, 0.2 to 1.4]); likewise, there was no difference in quit rates when only participants with abnormal spirometry were analyzed (adjOR, 0.6 [95% CI, 0.1 to 2.7]).122 The second larger and adequately powered U.S.-based study (n=536) showed no difference in the primary outcome of 7-day self-reported abstinence rates measured at 6 or 12 months of followup after adjusting for baseline differences (6 months: 12.0% vs. 14.1%; adjOR, 0.77; p=0.33; 12 months: 13.1% vs. 14.9%; adjOR, 0.86; p=0.38).123 Interestingly, there were fewer abstainers in the experimental group reporting 30-day abstinence at the 6-month followup (6.4% vs. 10.8%; adjOR, 0.51; p=0.04).

#### Quit Attempts

Three trials reported the percentage of participants in each group reporting at least one quit attempt during the trial period (Table 16).120,122,123 The VA trial showed more participants self-reporting at least one quit attempt in the intervention group (40.0% vs. 16.3%; p=0.015).120 The other two trials showed no statistically significant differences in the percent of patients having at least one quit attempt between treatment groups (48.0% vs. 36.0%; OR, 1.6 [95% CI, 0.9 to 2.8];122 and 62.4% vs. 61.5%; OR, 0.96 [95% CI not reported]; p=0.84).123

#### Cigarette Consumption

Only one trial reported the outcome of mean change in self-reported cigarette consumption, showing a statistically significantly reduction in the mean number of cigarettes consumed in the intervention group compared to the control group (11.7 vs. 13.7; p=0.03) (Table 16).119 This was the same primary care–based U.K. study reporting a statistically significant reduction in biochemically confirmed abstinence.

### Critical Appraisal

Generally, the evidence evaluating the effectiveness of tailored feedback or counseling using spirometry showed mixed results. Unfortunately, the largest RCT119 and only trial reporting a statistically significant difference in biochemically confirmed smoking cessation rates had some design issues, namely that patients with a prior diagnosis of obstructive lung disease were included (7.0% and 9.4% with medical history of COPD and asthma, respectively), potentially limiting its applicability to a screen-detected COPD population. The only study that specifically recruited screen-detected patients with mild to moderate COPD further restricted enrollment to those who had at least a 10 pack-year smoking history, mild to moderate COPD with at least one symptom, and an interest in quitting smoking, found no difference (11.2% vs 11.6%) in smoking cessation rates in the confrontational counseling group compared to the control group, although this study was underpowered to fully evaluate this outcome. Overall, data are scant to make firm conclusions regarding the effectiveness of utilizing spirometry results to motivate smokers in order to improve cessation rates.

## KQ 6 What Are the Adverse Effects of COPD Screening, Including the Impact of Targeted Preventive Services, in This Population?

### Summary of Findings

There is scant evidence examining the potential negative impact of COPD screening on targeted preventive services, including the impact on smoking cessation and immunization rates.

### Characteristics of Included Studies

One of the fair-quality RCTs included in KQ 5,121 which recruited participants with mild to moderate screen-detected COPD from the general population and primary care practices in the Netherlands, reported on the harms of COPD screening for smoking cessation using a qualitative study design in a separate publication.124 Authors administered semistructured interviews to 205 smokers ages 35 to 70 years with 10 years or more of smoking history and experiencing at least one respiratory symptom. These participants were interested in quitting smoking and all underwent spirometry testing; however, only the intervention group received a tailored counseling intervention that included a discussion of spirometry results. Participants rated four statements regarding their perception of the effectiveness of spirometry on smoking cessation attempts and the ethics of screening on a 5-point Likert scale.

### Detailed Results

Nearly half (46%) of all participants felt that measuring lung function positively influenced their attempt to quit smoking, and most (86%) felt that it was justifiable to measure lung function in heavy smokers. However, 7.8 percent of participants stated that routinely measuring lung function in smokers would interfere with one’s freedom of choice, and 1.2 percent said it was not justified to confront them with a COPD diagnosis.

## KQ 7 Does Treatment of Asymptomatic Adults With Mild to Moderate COPD Identified Through Screening Improve HrQOL or Reduce Morbidity or Mortality?

We searched for treatment efficacy literature for all of the following COPD drug classes or combinations of any of the following: LABAs, long-acting anticholinergics, and ICS. No trials recruited screen-detected patients. In order to most closely reflect the COPD severity (GOLD definition of mild to moderate disease) that would be expected to most closely reflect a screen-detected population, we included trials with either subanalyses of participants with mild to moderate COPD or trials in which the mean FEV_1_ percent predicted was 60 percent or greater. We identified a total of 20 studies of 14 distinct trials meeting these inclusion criteria (Table 18). Among these 14 relevant trials, we found two trials of LABAs,125,126 one RCT of ICS-LABA,126 five RCTs of the long-acting antimuscarinic (LAMA) tiotropium, which is in the class of long-acting anticholinergic drugs,125,127–129 and six RCTs of ICS.126,130–134 For ease of interpretation, the associated efficacy results are presented by drug class.

Table 18 Trial Characteristics for Treatment Efficacy RCTs, All Drug Classes

Study, Year Quality | Country | N Randomized | Recruitment | Followup | Inclusion | Exclusion | Treatment Comparison | Concomitant Therapies Allowed | Primary Outcome(s) Secondary Outcome(s)
Troosters, 2014^139^ Troosters, 2011^170^ Fair | International | 457 | 70 centers in 10 countries | 6 months | GOLD stage II (post-BD FEV_1_/FVC ratio <0.7; FEV_1_ ≥50% and <80% predicted; MRC dyspnea score ≥2) patients previously naïve to maintenance therapy; ages 40–80 years; smoking history of ≥10 pack-years; ability to demonstrate compliance with HandiHaler, a salbutamol exercise stress test; follow study procedures | Prior maintenance medication (LABA, inhaled or systemic corticosteroid, theophylline, leukotriene receptor antagonist) within 6 months prior to screening; current treatment with systemic steroid; diagnosis of asthma; history of CF; upper/lower respiratory tract infection or COPD exacerbation in 6 weeks prior to or during screening | IG: tiotropium bromide (18 μg/day) CG: Placebo | Salbutamol; corticosteroids for up to 2 weeks for acute exacerbations | Change in FEV_1_ Change in physical activity level; global health assessment; adverse events; exacerbations
Decramer, 2013^125^ Fair | International | 4417 (full population of original trials) NR (stage II) | INVOLVE: NR INHANCE: NR INLIGHT-2: NR | 6 months | Age ≥40 years; moderate to severe COPD (FEV_1_ ≥30% and <80% predicted, FEV_1_/FVC <70%); smoking history of ≥20 pack-years | Recent respiratory tract infection or COPD exacerbation | CG: Placebo IG1: indacaterol (150 μg/day) IG2: indacaterol (300 μg/day) IG3: tiotropium bromide (18 μg/day) IG4: formoterol (12 μg/twice a day) IG5: salmeterol (50 μg/twice a day) | Stable ICS; SABA | Trough FEV_1_ Dyspnea (TDI), quality of life (SGRQ)
UPLIFT Decramer 2009^127^ Tashkin 2012^140^ Tashkin 2008^141^ Fair | International | 5993 (full population) 2739 (stage II) 1210 (FEV_1_ ≥60% predicted [range 60%–78%])^*^ | 490 investigational centers in 37 countries | 48 months | Age ≥40 years; smoking history of ≥10 pack-years; post-BD FEV_1_ <70% predicted; FEV_1_/FVC ≤70% | History of asthma, COPD exacerbation or respiratory infection within 4 weeks before screening, history of pulmonary resection, use of supplemental oxygen for >12 hours/day, presence of a coexisting illness that could preclude participation in study or interfere with study results | IG: tiotropium bromide (18 μg/day) CG: Placebo | All respiratory medications except other inhaled anticholinergic drugs | Decline in mean FEV_1_ Decline in mean FVC and SVC; HRQoL; exacerbations; hospitalization; rate of death
TORCH Jenkins, 2009^126^ Calverley, 2007^138^ Fair | International | Full study population: 6,184 Stage I/II: NR | 42 countries, 444 centers | 9 months | Current or former smokers with a history of ≥10 pack-years; ages 40–80 years; confirmed diagnosis of COPD and pre-BD of FEV_1_ <60% of predicted; required to show <10% reversibility and a pre-BD of FEV_1_/FVC ≤0.70 | Patients with a diagnosis of asthma or other non-COPD respiratory disorder; any condition likely to cause death within 3 years; previous lung volume reduction surgery and/or lung transplant; requirement of oxygen therapy for ≥12 hours/day; current use of oral corticosteroid therapy; hospitalization during the run-in period | IG1: salmeterol (50 μg/twice a day) IG2: fluticasone propionate (500 μg/twice a day) IG3: salmeterol/fluticasone propionate combination (50 μg/500 μg) twice a day CG: Placebo | All medications for COPD except corticosteroids and inhaled long-acting bronchodilators | All-cause mortality Exacerbation rate; health status; lung function; adverse events
Lapperre 2009^132^ Fair | The Netherlands | 114 | Family practices using electronic medical records and ads in local newspapers | 30 months | Ages 45–75 years; current or former smokers; smoked for ≥10 pack-years; lung function levels compatible with GOLD stages II and III | Asthma; receipt of ICS within 6 months prior to randomization | IG1: fluticasone propionate (500 μg/twice a day) for first 6 months and then placebo IG2: fluticasone propionate (500 μg/twice a day) for 30 months IG3: fluticasone propionate (500 μg/twice a day) plus salmeterol (50 μg/twice a day) for 30 months CG: Placebo | Short-acting bronchodilators | Inflammatory cell counts in bronchial biopsy and induced sputum Post-BD spirometry; hyperresponsiveness to methacholine PC20; dyspnea score by MRC; SGRQ, CCQ
Calverley, 2008^133^ Fair | International | 911 (full study) 266 (stage II) | 95 sites in 11 countries | 12 months | Age ≥40 years; current smokers who failed a smoking cessation program or former smokers who had stopped smoking ≤12 months before the study; spirometry-diagnosed COPD: FEV_1_/FVC ≤70%, FEV_1_ 30%–70%, low FEV_1_ reversibility (<10%) | Asthma or other significant medical illness other than COPD; exacerbation within 3 months, ventilator support in past year; lobectomy, pnuemonectomy, or lung volume reduction surgery; lung cancer in past 5 years; CPAP or oxygen use; initiation of pulmonary rehabilitation in past 3 months; treatment with chronic or prophylactic antibiotics; inability to use inhalers; <80% adherence in diary data between screening and baseline | IG1: mometasone furoate (800 μg/day) IG2: mometasone furoate (400 μg/twice a day) CG: Placebo once or twice daily | Ipratropium bromide, theophylline, SABA, LABA | Post-BD FEV_1_ Exacerbations, COPD symptom score, SGRQ, SF-36, Pre-BD FEV_1_, FEF_25–75_
Tonnel, 2008^129^ Fair | France | 555 (full study) Stage I/II: 198 | 123 outpatient centers | 9 months | Outpatients age ≥40 years; clinical diagnosis of COPD (FEV_1_ 20%–70%) and SVC ≤70%; smoking history of >10 pack-years | History of asthma, allergic rhinitis, or atopy; regular use of daytime oxygen therapy; recent respiratory tract infection (within previous 6 weeks); recent history of MI (within previous 6 months); cardiac arrhythmia requiring drug therapy (within previous year); hospitalization for heart failure or pulmonary edema (within previous 3 years) | IG: tiotropium bromide (18 μg/day) CG: Placebo | Salbutamol delivered via metered-dose inhaler allowed as needed; theophylline preparations (excluding 24-hour), mucolytics, ICS, oral steroids (<10 mg prednisone daily or equivalent) allowed if dosage was stabilized for ≥6 weeks before study entry. One 10-day course of oral steroids for treatment of exacerbations was allowed. Antibiotics as deemed necessary for treatment of exacerbations. | Percentage of patients with ≥4 units of improvement in SGRQ total score Total SGRQ and VSRQ scores; exacerbations; lung function; adverse events
EUROSCOP Lofdahl 2007^142^ Pauwels 1999^130^ Fair | 9 western European countries | 1277 | 39 study centers | 36 months | Ages 30–60; current smokers (≥5 cigarettes per day); smokes for ≥10 years or history of ≥5 pack-years; post-BD FEV_1_ 50%–100% of predicted normal value; ratio of pre-BD FEV_1_ to slow vital capacity of <70%; reversibility of FEV_1_ with 1 mg inhaled terbutaline of <10%; participated in 3-month smoking-cessation program but continued to smoke; demonstrated at least 75% compliance with treatment during 3-month run-in period; change in FEV_1_ during run-in period of <15% | History of asthma; allergic rhinitis or allergic eczema; patients with a concomitant disease that could interfere with the interpretation of the study; patients using β-receptor antagonists; patients who had used oral glucocorticoids for >4 weeks during the preceding 6 months | IG: Budesonide (800 μg/day) CG: Placebo | Post-BD FEV_1_ change from BL | Severe exacerbations; adverse events
Niewoehner, 2005^128^ Good | US | 1829 (full population) Stage I/II: 287 | Patients at participating VA medical centers | 6 months | Patients in the VA system; age ≥40 years; cigarette smoking history of ≥10 pack-years; clinical diagnosis of COPD; FEV_1_ of ≤60% predicted and ≤70% of the FVC | Clinical diagnosis of asthma; MI within previous 6 months; serious cardiac arrhythmia or hospitalization for heart failure within previous year; known moderate to severe renal impairment; moderate to severe symptomatic prostatic hypertrophy or bladder-neck obstruction; narrow-angle glaucoma; current radiation or chemotherapy for a malignant condition; inability to give informed consent; taking systemic corticosteroids at unstable or regular daily doses of ≥20 mg of prednisone; not fully recovered from an exacerbation for ≥30 days before first study visit | IG: tiotropium bromide (18 μg/day) CG: Placebo | Patients continued taking all other respiratory medications (including corticosteroids and LABAs), except for open-label anticholinergic bronchodilator; primary providers were allowed to prescribe additional medications as needed (e.g., systemic steroids, antibiotics) | Percentage of patients with an exacerbation; hospitalization due to an exacerbation Time to first exacerbation; time to first hospitalization due to an exacerbation; frequency of exacerbations; exacerbation-related health care utilization; frequencies of all-cause hospitalization; hospitalization days; results of spirometry
Lung Health Study II, 2000^134^ Fair | US | 1116 | Patients who had participated in or been screened for the Lung Health Study I | Up to 54 months (mean: 40 months) | Ages 40–69 years; had airflow obstruction with a ratio of FEV_1_/FVC of <0.70 and a FEV_1_ that was 30% to 90% of the predicted value; current smokers or had quit within the previous 2 years | Patients with medical conditions such as cancer, recent MI, alcoholism, heart failure, insulin-dependent DM, and neuropsychiatric disorders; used bronchodilators or oral or inhaled corticosteroids in the previous year | IG: Inhaled corticosteroid (triameinolone acetoneide) given in a metered dose of 6 inhalations (100 μg per inhalation) twice a day, resulting in a total dose of 1200 μg per day CG: Placebo inhaler | NR | Rate of decline in FEV_1_ after the administration of bronchodilator Respiratory symptoms; cause-specific morbidity and mortality; airway reactivity in response to methacholine; HrQOL (SF-36)
Vestbo, 1999^131^ Fair | Demark | 290 | Random age-stratified sample from around Righospitalet in Copenhagen | 36 months | Ages 30–70; participant in the Copenhagen City Heart Study; FEV_1_/FVC <0.7; reversibility <15% following post-BD spirometry and 10 days of oral prednisolone | Long-term treatment with oral or inhaled steroids in last 6 months; pregnancy or lactation; serious systemic disease; chronic alcohol or drug use; participation in other clinical studies of COPD within 1 month of inclusion | IG: budesonide 1200 μg/day (800 μg morning, 400 μg evening) for 6 months; 400 μg/twice a day for 30 months CG: Placebo | Stable β_2_-agnoists, theophylline, disodium chromoglycate, and mucolytics. Up to 4 weeks of oral, inhaled, or parenteral steroids for up to three 4-week periods a year | FEV_1_ decline Exacerbations

* Inclusion criteria was FEV_1_ <70%, but 23 patients had an FEV_1_ >70% (protocol violation) and were included in the analysis.

Abbreviations: BL = baseline; CCQ = Clinical COPD Questionnaire; CF = cystic fibrosis; CG = control group; COPD = chronic obstructive pulmonary disease; CPAP = continuous positive airway pressure; DM = diabetes mellitus; EUROSCOP = European Respiratory Society study on Chronic Obstructive Pulmonary Disease; FEV_1_/FVC = forced expiratory volume in 1 second/forced vital capacity; GOLD = Global Initiative for Chronic Obstructive Lung Disease; HrQOL = health-related quality of life; ICS = inhaled corticosteroids; IG = intervention group; INHANCE = INdacaterol to Help Achieve New COPD treatment Excellence; INLIGHT = INdacaterol efficacy evaLuation using 150 μg doses witH COPD paTients; INVOLVE = INdacaterol: Value in COPD: Longer Term Validation of Efficacy and Safety; LABA = long-acting β-agonist; MI = myocardial infarction; MRC = Medical Research Council; N = number; NR = not reported; post-BD = postbronchodilator; pre-BD = prebronchodilator; SABA = short-acting β-agonist; SF-36 = Short Form-36; SGRQ = St. George’s Respiratory Questionnaire; SVC = slow vital capacity; TDI = transition dyspnea index; TORCH = Towards a Revolution in COPD Health; UPLIFT = Understanding Potential Long-term Impacts on Function with Tiotropium; US = United States; VA = U.S. Department of Veterans Affairs; VSRQ = Visual Simplified Respiratory Questionnaire.

### LABAs

#### Summary of Findings

Although no RCTs examined the clinical effectiveness of LABAs in screen-detected populations, we identified two industry-sponsored post hoc subanalyses of almost exclusively moderate COPD (94% moderate; 6% mild) treatment with LABAs, with 6 months to 3 years of followup. Most of the patient-important outcomes we sought were not reported at all (i.e., exercise capacity) or were reported in just one of the two analyses (i.e., exacerbations, all-cause mortality, dyspnea score); subgroup analyses were further limited by power and not controlling for confounders. Based on reporting from the subanalysis of the Towards a Revolution in COPD Health (TORCH) trial only, LABAs did not appear to provide an all-cause mortality benefit at 3 years for any stage of COPD.126 It was not clear whether exacerbations were reduced since the only trial reporting this outcome (TORCH) did not provide statistical analysis by treatment arm for the subgroup; however, there was no evidence that stage of COPD modified the impact of LABAs on reduced exacerbations in the larger population. In pooled analysis of different LABAs, there was a statistically significant short-term impact on dyspnea score after 6 months, although more robust evidence would be needed to make firm conclusions. Further, although both analyses reported HrQOL outcomes, they found mixed results. One analysis by Decramer showed short-term improvement in the proportion achieving clinical meaningful improvements in HrQOL with LABAs compared to placebo treatment at 6 months; in contrast, the TORCH-based analysis showed no difference in mean HrQOL between treatment groups after several years of followup in those with predominantly moderate disease or in all patients regardless of disease severity. The overall strength of evidence for the effect of LABAs on health outcomes in moderate COPD patients is insufficient for exercise capacity and low for other health outcomes.

#### Overview of Available Studies

No RCTs examined the clinical effectiveness of LABAs in screen-detected populations. We identified two industry-sponsored post hoc subanalyses of mild to moderate COPD treatment with LABAs: one subanalysis of mild to moderate COPD (>90% moderate) by Decramer125 pooling three unique, double-blind, placebo-controlled RCTs135–137 of different LABAs (formoterol, salmeterol, and indacaterol) and one subanalysis of the double-blind, placebo-controlled TORCH trial analyzing LABA-treated (salmeterol) participants with an FEV_1_ of 50 percent of predicted or greater, in which 99 percent of participants had moderate COPD (Table 18).126

The Decramer subanalysis pooled the fair-quality international INdacaterol: Value in COPD: Longer Term Validation of Efficacy and Safety (INVOLVE), INdacaterol to Help Achieve New COPD treatment Excellence (INHANCE), and INdacaterol efficacy evaLuation using 150 μg doses witH COPD paTients (INLIGHT)-2 trials (n=4,417; n=2,353 with moderate COPD) examining formoterol (12 μg/twice a day), indacaterol (150 or 300 μg/day), or salmeterol (50 μg/twice a day) compared to placebo with 6-month followup.125 These three primary trials recruited patients age 40 years or older with moderate to severe COPD (FEV_1_ ≥30% and <80% of predicted; FEV_1_/FVC <70%) and a smoking history of 20 pack-years or more. Although inclusion criteria would exclude patients with mild disease, authors note that approximately 7 percent of the included population was found to have mild COPD because one trial began administering post-rather than prebronchodilator spirometry, thereby relabeling some participants previously defined as moderate to the mild category. Patients with a recent respiratory tract infection or COPD exacerbation were excluded; however, concomitant short-acting β-agonists and stable ICS use were allowed. The primary outcomes in these trials were trough FEV_1_ (change from baseline in FEV_1_ after a 24-hour dosing interval) and secondary outcomes included dyspnea and quality of life at 6-month followup. In the subanalysis of only patients with moderate COPD (FEV_1_ 50% to 79% of predicted), the mean age was 64 years, and 32.7 percent of participants were women (Table 19).125 The majority of participants were former smokers (56%), with 44 percent indicating that they were current smokers without any reported mean pack-year exposure. Almost 5 percent (4.6%) of participants had at least one nonrecent exacerbation in the preceding year. The mean FEV_1_ percent predicted for this moderate COPD subpopulation was 64.0 percent, and the baseline HrQOL as measured by the SGRQ was 41.2, indicating that the population had moderate limitations. Withdrawal rate was approximately 25 percent in two of the three trials overall and approximately 14 percent among those with moderate disease.135,136 Each of the included trials used ITT analysis.

Table 19 Baseline Characteristics for Treatment Efficacy RCTs, All Drug Classes

Study, Year Quality | N Randomized | Age, years (mean) | Female, % | Smoking Status, % | Smoking History, pack-years (mean) | Number of Exacerbations in the Preceding Year (mean) | Lung Function Post-BD, FEV_1_ % Predicted of Normal (mean) | HrQOL | Exercise Capacity
Troosters, 2014^139^ Troosters, 2011^170^ Fair | 457 | 61.7\|\| | 31.5\|\| | Current: 59.4\|\| | 44.0\|\| | NR | 65.7\|\| | WPAI: Activity impairment due to health, %: 26.8\|\| | Steps, number/day: 6402.7\|\| Time in age-appropriate moderate or higher activity, minutes/day: 20.0\|\|
Decramer, 2013^125^ Fair | Stage II: 2353 | 64 | 32.7\|\| | Former: 56\|\| Current: 44\|\| | NR | At least 1: 4.6%\|\| | 64.0\|\| | SGRQ total score, mean: 41.2\|\| | NR
UPLIFT Decramer 2009^127^ Tashkin 2012^140^ Tashkin 2008^141^ Fair | Stage II: 2739 FEV_1_ ≥60%: 1210 | Stage II: 64.5\|\| FEV_1_ ≥60%: 64 | Stage II: NR FEV_1_ ≥60%: 29.9%\|\| | Stage II: Current: 33.0%\|\| Former: 67.0%\|\| FEV_1_ ≥60%: Current: 32.3%\|\| Former: 67.7%\|\| | Stage II: 47.5\|\| FEV_1_ ≥60%: 47.6\|\| | Stage II: NR FEV_1_ ≥60%: NR | Stage II: 59\|\| FEV_1_ ≥60%: 64 | SGQR total score, mean: Stage II: 41.5\|\| FEV_1_ ≥60%: 40 | Stage II: NR FEV_1_ ≥60%: NR
TORCH Jenkins, 2009^126^ Calverley, 2007^138^ Fair | Stage I/II: 2183 | 64.9^*^ | 28.0^*^\|\| | Current: 47.0^*^ Former: 53.0^*^\|\| | NR | Requiring hospitalization, mean (SD): 0.2 (0.5)^*^ | 58.8^*^ | SGRQ score, mean (SD)^*^: Total: 45.4 (17.7) Symptom score: 60.3 (21.0) Activity score: 57.1 (20.6) Impact score: 33.6 (19.6) | NR
Lapperre 2009^132^ Fair | 114 | 61.8^†^\|\| | 13.9^†^\|\| | Current: 63.4^†^\|\| | 43.5^†^\|\| | NR | 63.0^†^ | SGRQ total score, mean: 30.0^†^\|\| | NR
Calverley, 2008^133^ Fair | Full pop: 911 Stage II: 266 | Full pop: 65.1 Stage II: NR | Full pop: 31.7 Stage II: NR | Full pop: Current, 27.4; former, 72.6 Stage II: NR | Full pop: NR Stage II: NR | Full pop: NR Stage II: NR | Full pop: 46.7 Stage II: NR | Full pop: NR Stage II: NR | Full pop: NR Stage II: NR
Tonnel, 2008^129^ Fair | Full pop: 555 Stage II: 198 | Full pop: 64.2^‡^\|\| Stage II: NR | Full pop: 13.9^‡^\|\| Stage II: NR | Full pop: Current: 27.0^‡^\|\| Stage II: NR | Full pop: 43.7^‡^\|\| Stage II: NR | Full pop: NR Stage II: NR | Full pop: 46.8^‡^\|\| Stage II: NR | SGRQ total score, mean: Full pop: 47.4^‡^\|\| Stage II: NR | Full pop: NR Stage II: NR
EUROSCOP Lofdahl 2007^142^ Pauwels 1999^130^ Fair | 1277 | 52.4\|\| | 27.2\|\| | Current: 100.0 | 39.3\|\| | NR | 76.8^§^\|\| | NR | NR
Niewoehner, 2005^128^ Good | Full pop: 1829 Stage I/II: 287 | Full pop: 67.8\|\| Stage I/II: NR | Full pop: 1.5\|\| Stage I/II: NR | Full pop: Current: 29.3\|\| Stage I/II: NR | Full pop: 68.4\|\| Stage I/II: NR | Full pop: NR Stage I & II: NR | Full pop: 35.6\|\| Stage I & II: NR | Full pop: NR Stage I & II: NR | Full pop: NR Stage I & II: NR
Lung Health Study, 2000^134^ Fair | 1116 | 56.3\|\| | 36.9\|\| | Current: 90.2\|\| | NR | NR | 67.8\|\| | NR | NR
Vestbo, 1999^131^ Fair | 290 | 59.0\|\| | 39.6\|\| | Current: 76.6\|\| Never: 4.1\|\| | NR | NR | 86.6 | NR | NR

* Baseline characteristics only include the 2156 patients included in the efficacy analysis.

† Baseline characteristics include only the 101 adherent patients included in the analysis.

‡ Baseline characteristics include only the 554 patients who received treatment.

§ Prebronchodilator spirometry measure.

|| Calculated.

Abbreviations: EUROSCOP = European Respiratory Society study on Chronic Obstructive Pulmonary Disease; FEV_1_= forced expiratory volume in 1 second; HrQOL = health-related quality of life; N = number; NR = not reported; pop = population; SD = standard deviation; SGRQ = St. George’s Respiratory Questionnaire; TORCH = Towards a Revolution in COPD Health; UPLIFT = Understanding Potential Long-term Impacts on Function with Tiotropium; WPAI = Work Productivity and Activity Impairment Questionnaire.

The TORCH subanalysis examined participants with an FEV_1_ of 50 to 60 percent of predicted from the fair-quality international TORCH trial (n=6,184; 28 mild; 2,155 moderate), which examined salmeterol (50 μg/twice a day), fluticasone propionate (500 μg/twice a day), salmeterol/fluticasone propionate combination (50 μg/500 μg/twice a day) or placebo in COPD patients with a 36-month followup (Table 18).126,138 Results for the salmeterol and placebo arms only are reported here. This trial included current or former smokers ages 40 to 80 years with a smoking history of 10 pack-years or more, confirmed diagnosis of COPD, and an FEV_1_ of less than 60 percent of predicted. Although the main trial was limited to patients with moderate to severe COPD, authors state that the subanalysis included 28 patients who were diagnosed with mild COPD (FEV_1_ ≥80% of predicted). Additionally, enrolled patients were required to show less than 10 percent reversibility and a prebronchodilator FEV_1_/FVC of less than 0.70. Patients with nonCOPD respiratory disorders were excluded, along with those diagnosed with any condition likely to cause death within 3 years, those with previous lung volume reduction surgery and/or lung transplantation, those requiring the use of oxygen therapy for at least 12 hours per day, patients using oral corticosteroid therapy, and patients who were hospitalized during the run-in period. Concomitant COPD medications (except oral or inhaled corticosteroids and LABAs) were allowed. The primary outcome of the TORCH trial was all-cause mortality and secondary outcomes included exacerbation rate, health status, lung function, and adverse events. The mean age of participants with mild to moderate COPD was 64.9 years, and 28.0 percent of participants were women (Table 19). Approximately half of participants in the subanalysis were former smokers (53.0%), with 47 percent reporting that they were current smokers. The mean number of exacerbations among the participants with moderate COPD requiring hospitalization in the preceding year was 0.20, and the mean postbronchodilator FEV_1_ was 58.8 percent of predicted. The baseline HrQOL as measured by the SGRQ was 45.4, indicating that the population had moderate limitations. The withdrawal rate and loss to followup were high in the main trial (36.9% in the LABA arm and 44.2% in the placebo arm), although withdrawal rates and loss to followup were not reported in the subanalysis. Analysis was done by ITT; however, the withdrawals were included in the exacerbation and HrQOL analysis.

Both of these studies were post hoc analyses; neither performed interaction testing and only one125 controlled for confounders (Table 20). Groups were matched at baseline in both analyses.

Table 20 Subgroup Credibility Table

Study, Year Quality | Subgroup | Timing of Analysis | Interaction Testing Performed? | Groups Matched at Baseline? | Controlled for Confounders?
Decramer, 2013^125^ Fair | COPD stage II | Post-hoc | No | Yes | Yes
Decramer, 2009^127^ Fair | COPD stage II | Prespecified (published later) | Yes (for exacerbations only) | Yes | No
TORCH Jenkins, 2009^126^ Fair | FEV_1_ ≥50% predicted | Post-hoc | Yes: Only for ICS-LABA arm. There was no evidence of a difference in treatment effect across GOLD stages on all-cause mortality (p=0.402), exacerbations (p=0.254), or SGRQ (p=0.321) | Groups not evenly distributed by FEV_1_, but characteristics were similar across groups | NR
Calverley, 2008^133^ Fair | COPD stage II | Post-hoc | No | NR | No
Tashkin, 2012^140^ Fair | FEV_1_ ≥60% predicted | Post-hoc | No | Only difference is statistically significantly more smokers in CG than IG (36% vs. 29%; p=0.011) | For HrQOL analysis only
Tonnel, 2008^129^ Fair | Stage II (FEV_1_ 50%–70%) | NR | Yes (p=0.0787) | NR by stage | Adjusted for baseline SGRQ
Niewoehner, 2005^128^ Good | FEV_1_ >49% predicted | Unspecified | NR | NR | No

Abbreviations: CG = control group; COPD = chronic obstructive pulmonary disease; FEV_1_= forced expiratory volume in 1 second; GOLD = Global Initiative for Chronic Obstructive Lung Disease; HrQOL = health-related quality of life; IG = intervention group; NR = not reported; SGRQ = St. George’s Respiratory Questionnaire; TORCH = Towards a Revolution in COPD Health.

#### Detailed Results

##### Exacerbations

Only one trial, TORCH (n=1,057 from salmeterol and placebo arms only, analyzed for this outcome), reported exacerbations (Table 21).126 The TORCH subanalysis among participants with mild to moderate COPD (99% moderate) showed that the annual rate of moderate to severe exacerbations (defined as symptomatic deterioration requiring treatment with antibiotic agents, systemic corticosteroids, hospitalization, or a combination of these) was 0.71 in the salmeterol group and 0.82 in the placebo group (no statistical testing done by treatment arm) at 36 months. In the main analysis including participants with all stages of COPD, there was a reduction in moderate to severe exacerbations in the salmeterol group compared to placebo group (relative risk [RR], 0.82 [95% CI, 0.76 to 0.89]), and no evidence of a difference in treatment effect on exacerbations by COPD disease stage (p=0.254).

Table 21 Event-Based Outcomes for LABAs

Drug Class | Study, Year Quality | Treatment Comparison | Study Group | N Analyzed | Followup | Exacerbations | IG vs. CG | Hospital Utilization | IG vs. CG | All-Cause Mortality | IG vs. CG
LABA-Formoterol | Decramer, 2013^125^ Fair | IG: formoterol (12 μg/twice a day) CG: Placebo | IG | NA | 6 months | NR | NR | NR | NR | NR | NR
LABA-Formoterol | Decramer, 2013^125^ Fair | IG: formoterol (12 μg/twice a day) CG: Placebo | CG | NA | 6 months | NR | NR | NR | NR | NR | NR
LABA-Indacaterol | Decramer, 2013^125^ Fair | IG1: indacaterol (150 μg/day) IG2: indacaterol (300 μg/day) CG: Placebo | IG1 | NA | 6 months | NR | NR | NR | NR | NR | NR
LABA-Indacaterol | Decramer, 2013^125^ Fair | IG1: indacaterol (150 μg/day) IG2: indacaterol (300 μg/day) CG: Placebo | IG2 | NA | 6 months | NR | NR | NR | NR | NR | NR
LABA-Indacaterol | Decramer, 2013^125^ Fair | IG1: indacaterol (150 μg/day) IG2: indacaterol (300 μg/day) CG: Placebo | CG | NA | 6 months | NR | NR | NR | NR | NR | NR
LABA-Salmeterol | Decramer, 2013^125^ Fair | IG: salmeterol (50 μg/twice a day) CG: Placebo | IG | NA | 6 months | NR | NR | NR | NR | NR | NR
LABA-Salmeterol | Decramer, 2013^125^ Fair | IG: salmeterol (50 μg/twice a day) CG: Placebo | CG | NA | 6 months | NR | NR | NR | NR | NR | NR
LABA-Salmeterol | TORCH Jenkins, 2009^126^ Calverley, 2007^138^ Fair | IG: salmeterol (50 ug/twice a day) CG: Placebo | IG | 522 | 36 months | Annual rate of moderate or severe exacerbations: 0.71^*^ | NR | NR | NA | 48 (9.2%) | NR
LABA-Salmeterol | TORCH Jenkins, 2009^126^ Calverley, 2007^138^ Fair | IG: salmeterol (50 ug/twice a day) CG: Placebo | CG | 535 | 36 months | Annual rate of moderate or severe exacerbations: 0.82^*^ | NR | NR | NA | 61 (11.4%) | NR

* Symptomatic deterioration requiring treatment with antibiotic agents, systemic corticosteroids, hospitalization, or a combination of these.

Abbreviations: CG = control group; IG = intervention group; LABA = long-acting β-agonist; N = number; NA = not applicable; NR = not reported; TORCH = Towards a Revolution in COPD Health.

##### All-Cause Mortality

Only one trial, TORCH (n=1,057),126 reported all-cause mortality in patients with mild to moderate COPD, finding similar rates across treatment groups (9.2% in the salmeterol group vs. 11.4% in the placebo group) at 36 months (no statistical testing done by treatment arm) (Table 21). The main analysis including all participants (n=6,112) showed no statistically significant difference in the primary outcome of all-cause mortality across all treatments.

##### Dyspnea Score

Only the Decramer subanalysis reported dyspnea score as an outcome (Table 22).125 The Decramer subanalysis (n=2,117) showed that the OR for the percent of patients achieving a meaningful difference (≥1 point) in dyspnea score (measured by the Transition Dyspnea Index) was higher in each of the LABA groups compared to placebo at 6 months (salmeterol 50 μg/twice a day, 1.72 [95% CI, 1.12 to 2.66]; indacaterol 150 μg/day, 1.99 [95% CI, 1.45 to 2.74]; indacaterol 300 μg/day, 2.44 [95% CI, 1.79 to 3.31]; formoterol 12 μg/twice a day, 1.91 [95% CI, 1.29 to 2.85]).

Table 22 Questionnaire- or Event-Based Outcomes for LABAs

Drug Class | Study, Year Quality | Treatment Comparison | Study Group | N Analyzed | Followup | Dyspnea Score | IG vs. CG | HrQOL | IG vs. CG | Exercise Capacity | IG vs. CG
LABA-Formoterol | Decramer, 2013^125^ Fair | IG: formoterol (12 μg/twice a day) CG: Placebo | IG | 309 | 6 months | % achieving a minimally clinical difference on the TDI: 57.3%^*^ | OR: 1.91 (1.29, 2.85) | % achieving a minimally clinical difference on the SGRQ total score: 52.2%^†^ | OR: 1.63 (1.15 to 2.30) | NR | NR
LABA-Formoterol | Decramer, 2013^125^ Fair | IG: formoterol (12 μg/twice a day) CG: Placebo | CG | 675 | 6 months | % achieving a minimally clinical difference on the TDI: 49.3%^*^ | OR: 1.91 (1.29, 2.85) | % achieving a minimally clinical difference on the SGRQ total score: 42.0%^†^ | OR: 1.63 (1.15 to 2.30) | NR | NR
LABA-Indacaterol | Decramer, 2013^125^ Fair | IG1: indacaterol (150 μg/day) IG2: indacaterol (300 μg/day) CG: Placebo | IG1 | 448 | 6 months | % achieving a minimally clinical difference on the TDI: 63.8%^*^ | IG1: OR (vs. CG): 1.99 (1.45 to 2.74) IG2: OR (vs. CG): 2.44 (1.79 to 3.31) | % achieving a minimally clinical difference on the SGRQ total score: 57.0%^†^ | IG1: OR (vs. CG): 2.14 (1.59 to 2.88) IG2: OR (vs. CG): 1.78 (1.34 to 2.37) | NR | NR
LABA-Indacaterol | Decramer, 2013^125^ Fair | IG1: indacaterol (150 μg/day) IG2: indacaterol (300 μg/day) CG: Placebo | IG2 | 496 | 6 months | % achieving a minimally clinical difference on the TDI: 66.8%^*^ | IG1: OR (vs. CG): 1.99 (1.45 to 2.74) IG2: OR (vs. CG): 2.44 (1.79 to 3.31) | % achieving a minimally clinical difference on the SGRQ total score: 55.5%^†^ | IG1: OR (vs. CG): 2.14 (1.59 to 2.88) IG2: OR (vs. CG): 1.78 (1.34 to 2.37) | NR | NR
LABA-Indacaterol | Decramer, 2013^125^ Fair | IG1: indacaterol (150 μg/day) IG2: indacaterol (300 μg/day) CG: Placebo | CG | 675 | 6 months | % achieving a minimally clinical difference on the TDI: 49.3%^*^ | IG1: OR (vs. CG): 1.99 (1.45 to 2.74) IG2: OR (vs. CG): 2.44 (1.79 to 3.31) | % achieving a minimally clinical difference on the SGRQ total score: 42.0%^†^ | IG1: OR (vs. CG): 2.14 (1.59 to 2.88) IG2: OR (vs. CG): 1.78 (1.34 to 2.37) | NR | NR
LABA-Salmeterol | Decramer, 2013^125^ Fair | IG: salmeterol (50 μg/twice a day) CG: Placebo | IG | 189 | 6 months | % achieving a minimally clinical difference on the TDI: 56.9%^*^ | OR: 1.72 (1.12 to 2.66) | % achieving a minimally clinical difference on the SGRQ total score: 50.3%^†^ | OR: 1.98 (1.31 to 2.99) | NR | NR
LABA-Salmeterol | Decramer, 2013^125^ Fair | IG: salmeterol (50 μg/twice a day) CG: Placebo | CG | 675 | 6 months | % achieving a minimally clinical difference on the TDI: 49.3%^*^ | OR: 1.72 (1.12 to 2.66) | % achieving a minimally clinical difference on the SGRQ total score: 42.0%^†^ | OR: 1.98 (1.31 to 2.99) | NR | NR
LABA-Salmeterol | TORCH Jenkins, 2009^126^ Calverley, 2007^138^ Fair | IG: salmeterol (50 ug/twice a day) CG: Placebo | IG | 522 | 36 months | NR | NR | Adjusted change in SGRQ total score from BL, mean^‡^: −1.5 | NR | NR | NR
LABA-Salmeterol | TORCH Jenkins, 2009^126^ Calverley, 2007^138^ Fair | IG: salmeterol (50 ug/twice a day) CG: Placebo | CG | 535 | 36 months | NR | NR | Adjusted change in SGRQ total score from BL, mean^‡^: −1.3 | NR | NR | NR

* % achieving a meaningful clinical difference (≥ 1 point).

† % achieving a meaningful clinical difference (≥−4 units).

‡ Adjusted for age, gender, BMI, baseline FEV_1_, baseline SGRQ, region, and smoking status.

Abbreviations: BL = baseline; BMI = body mass index; CG = control group; HrQOL = health-related quality of life; IG = intervention group; LABA = long-acting β-agonist; N = number; NR = not reported; OR = odds ratio; SGRQ = St. George’s Respiratory Questionnaire; TDI = transition dyspnea index; TORCH = Towards a Revolution in COPD Health.

##### HrQOL

Both studies reported HrQOL outcomes among participants with mild to moderate COPD, showing mixed results (Table 22). The Decramer subanalysis showed that the OR for the percent of patients achieving a meaningful clinical difference (≥4 units) in HrQOL (measured by the SGRQ) was higher in the LABA groups compared to placebo at 6 months (salmeterol, 1.98 [95% CI, 1.31 to 2.99]; indacaterol 150 μg, 2.14 [95% CI, 1.59 to 2.88]; indacaterol 300 μg, 1.78 [95% CI, 1.34 to 2.37]; formoterol 12 μg/twice a day, 1.63 [95% CI, 1.15 to 2.30]).125 Conversely, the TORCH subanalysis showed that there was no clinically meaningful difference in HrQOL (measured by the SGRQ) from baseline in either the salmeterol or placebo group at 26 months (mean change from baseline, −1.5 vs. −1.3 in the intervention and control group, respectively; no statistical testing done by treatment arm).126 Further, the main trial (all severities of COPD) showed no statistically significant difference in HrQOL in the salmeterol group compared to the placebo group (difference, −1.0 [95% CI, −2.0 to 0]).

##### Exercise Capacity

We found no trials that reported changes in exercise capacity among patients with mild to moderate COPD treated with LABAs.

#### Critical Appraisal

The lack of efficacy RCTs of LABAs in screen-detected COPD populations limits the strength of evidence for this question. One post hoc subanalysis of a large four-arm RCT and one post hoc pooled subanalysis from three other RCTs provide data on patients with mild to moderate COPD.125,126 Both of these studies were large, totaling more than 2,000 patients with mild to moderate COPD; however, almost all participants had moderate COPD, with the TORCH trial recruiting participants on the more severe end of moderate (FEV_1_ about 60% of predicted), and only one of these trials provided longer-term followup (TORCH, 3 years; Decramer, 6 months). There was a number of limitations in these subgroup analyses, including: 1) the primary trials were powered for the entire population, not subgroups; 2) both analyses were post hoc; 3) neither analysis performed interaction testing; and 4) only Decramer controlled for confounders. The inconsistency in reported outcomes across the studies further limited the strength of available evidence.

### ICS-LABA Combination

#### Summary of Findings

Although no RCTs examined the clinical effectiveness of ICS-LABA combinations among screen-detected COPD populations, we found a single post hoc subgroup analysis from the TORCH trial on the impact of ICS-LABA combined treatment on selected patient-important outcomes in adults with almost exclusively moderate COPD (98.5% moderate; 1.5% mild). An additional RCT by Lapperre included an ICS-LABA arm; however, there were no patient-oriented outcomes reported for this treatment. Low strength of evidence supports an improvement in exacerbations, while very low strength of evidence supports improved mortality but no change in HrQOL. Strength of evidence is insufficient for exercise capacity and dyspnea symptomatology.

#### Overview of Available Studies

We found no RCTs examining the clinical effectiveness of ICS-LABA combined treatment among screen-detected COPD populations. One subanalysis from the TORCH trial126 provided data on the effectiveness of an ICS-LABA treatment combination among patients with mild to moderate COPD, and a four-arm trial by Lapperre included an ICS-LABA arm and placebo arm (in addition to two fluticasone arms); however, there were no patient-oriented outcomes reported for the combination arm (Table 18).132

The subanalysis of the four-arm TORCH trial, discussed previously, examined the efficacy of an ICS-LABA (salmeterol/fluticasone) combination compared to placebo.126,138 Results from the salmeterol/fluticasone propionate combination (50 μg/500 μg/twice a day) arm and the placebo arm were analyzed in a post hoc subanalysis (n=1,097) at 3 years of followup for patients with moderate COPD.126

Only the post hoc subanalysis from the TORCH trial provided data on the patient-oriented outcomes of all-cause mortality, exacerbations, and HrQOL (Tables 23 and 24).126 The all-cause mortality benefit seen in the analysis was not consistent with interaction testing, which showed no heterogeneity of effect by COPD stage. Statistically significant improvements in HrQOL did not meet the threshold of clinically meaningful change. There were fewer annual rates of exacerbations in the ICS-LABA arm of this analysis, but it is unclear if this is clinically meaningful.

Table 23 Event-Based Outcomes for ICS and LABA Combination Therapy

Drug Class | Study, Year Quality | Treatment Comparison | Study Group | N Analyzed | Followup | Exacerbations | IG vs. CG | Hospital Utilization | IG vs. CG | All-Cause Mortality | IG vs. CG
ICS/LABA-Salmeterol/Fluticasone Propionate | TORCH Jenkins, 2009^126^ Calverley, 2007^138^ Fair | IG: salmeterol/fluticasone propionate combination (50 μg/500 μg) twice a day CG: Placebo | IG | 562 | 36 months | Annual rate of moderate or severe exacerbations: 0.57^*^ | Reduction in annual rate of moderate or severe exacerbations (vs. CG): 31% (95% CI, 19 to 40%) | NR | NA | 44 (7.8%) | HR: 0.67 (95% CI, 0.45 to 0.98)
ICS/LABA-Salmeterol/Fluticasone Propionate | TORCH Jenkins, 2009^126^ Calverley, 2007^138^ Fair | IG: salmeterol/fluticasone propionate combination (50 μg/500 μg) twice a day CG: Placebo | CG | 535 | 36 months | Annual rate of moderate or severe exacerbations: 0.82^*^ | Reduction in annual rate of moderate or severe exacerbations (vs. CG): 31% (95% CI, 19 to 40%) | NR | NA | 61 (11.4%) | HR: 0.67 (95% CI, 0.45 to 0.98)
ICS/LABA-Salmeterol/Fluticasone Propionate | Lapperre 2009^132^ Fair | IG: fluticasone propionate (500 μg/twice a day) plus salmeterol (50 μg/twice a day) for 30 months CG: Placebo | IG | NA | 30 months | NR | NA | NR | NA | NR | NR
ICS/LABA-Salmeterol/Fluticasone Propionate | Lapperre 2009^132^ Fair | IG: fluticasone propionate (500 μg/twice a day) plus salmeterol (50 μg/twice a day) for 30 months CG: Placebo | CG | NA | 30 months | NR | NA | NR | NA | NR | NR

* Symptomatic deterioration requiring treatment with antibiotic agents, systemic corticosteroids, hospitalization, or a combination of these.

Abbreviations: CI = confidence interval; CG = control group; HR = hazard ratio; ICS = inhaled corticosteroids; IG = intervention group; LABA = long-acting β-agonist; N = number; NA = not applicable; NR = not reported; TORCH = Towards a Revolution in COPD Health.

Table 24 Questionnaire- or Event-Based Outcomes for ICS and LABA Combination Therapy

Drug Class | Study, Year Quality | Treatment Comparison | Study Group | N Analyzed | Followup | Dyspnea Score | IG vs. CG | HrQOL | IG vs. CG | Exercise Capacity | IG vs. CG
ICS/LABA-Salmeterol/Fluticasone Propionate | TORCH Jenkins, 2009^126^ Calverley, 2007^138^ Fair | IG: salmeterol/fluticasone propionate combination (50 μg/500 μg) twice a day CG: Placebo | IG | 562 | 36 months | NR | NR | Adjusted change in SGRQ total score from BL, mean^*^: −3.7 | Difference in adjusted mean change vs. CG^*^: −2.3 (95% CI, −4.0 to −0.7) | NR | NR
ICS/LABA-Salmeterol/Fluticasone Propionate | TORCH Jenkins, 2009^126^ Calverley, 2007^138^ Fair | IG: salmeterol/fluticasone propionate combination (50 μg/500 μg) twice a day CG: Placebo | CG | 535 | 36 months | NR | NR | Adjusted change in SGRQ total score from BL, mean^*^: −1.3 | Difference in adjusted mean change vs. CG^*^: −2.3 (95% CI, −4.0 to −0.7) | NR | NR
ICS/LABA-Salmeterol/Fluticasone Propionate | Lapperre 2009^132^ Fair | IG: fluticasone propionate (500 μg/twice a day) plus salmeterol (50 μg/twice a day) for 30 months CG: Placebo | IG | 21 | 30 months | NR | NR | NR | NR | NR | NR
ICS/LABA-Salmeterol/Fluticasone Propionate | Lapperre 2009^132^ Fair | IG: fluticasone propionate (500 μg/twice a day) plus salmeterol (50 μg/twice a day) for 30 months CG: Placebo | CG | 20 | 30 months | NR | NR | NR | NR | NR | NR

* Adjusted for age, gender, BMI, baseline FEV_1_, baseline SGRQ, region, and smoking status.

Abbreviations: BL = baseline; BMI = body mass index; CI = confidence interval; CG = control group; HrQOL = health-related quality of life; IG = intervention group; N = number; NR = not reported; SGRQ = St. George’s Respiratory Questionnaire; TORCH = Towards a Revolution in COPD Health.

#### Detailed Results

##### Exacerbations

Only one study, the subanalysis of the TORCH trial, reported exacerbations by stage of COPD, finding that the annual rate of moderate to severe exacerbations (defined as symptomatic deterioration requiring treatment with antibiotic agents, systemic corticosteroids, hospitalization, or a combination of these) was lower in the ICS-LABA treatment combination group compared to the placebo group (0.57 in intervention group vs. 0.82 in control group; annual reduction rate in intervention group, 31% [95% CI, 19 to 40]) (Table 23).126

##### All-Cause Mortality

One subanalysis of the TORCH trial reported all-cause mortality among patients with moderate COPD, finding a statistically significant reduction between those receiving the ICS-LABA combination versus those on placebo at 3 years of followup (3.6% absolute reduction; 7.8% vs. 11.4%; hazard ratio [HR], 0.67 [95% CI, 0.45 to 0.98]) (Table 23).126 Interaction testing, however, showed no difference in treatment effect across the GOLD stages on all-cause mortality (p=0.402), and the main TORCH results showed no difference for probability of death at 3 years (adjHR, 0.82 [95% CI, 0.68 to 1.00]).138

##### Dyspnea Score

We found no trials that reported change in dyspnea score among mild to moderate COPD patients treated with an ICS-LABA combination.

##### HrQOL

Only one study, the TORCH subanalysis, reported HrQOL (measured by the SGRQ) in patients with moderate COPD (Table 24).126 Results showed that there was a greater reduction in the change from baseline in HrQOL among patients in the ICS-LABA treatment group compared to the placebo group; however, neither arm achieved a clinically meaningful change (defined as ≥4 units) from baseline (−3.7 vs. −1.3 in intervention vs. control group, respectively; difference, −2.3 [95% CI, −4.0 to −0.7]).

##### Exercise Capacity

We found no trials that reported change in exercise capacity among patients with mild to moderate COPD treated with an ICS-LABA combination.

#### Critical Appraisal

Data assessing the effectiveness of combination ICS-LABA treatment are limited to one post hoc subanalysis among patients with mild to moderate COPD (98.5% of participants had moderate COPD and were on the more severe end of moderate; FEV_1_ about 60% of predicted).126 The evidence available suggests a possible all-cause mortality benefit among this subpopulation that was not seen in the main trial across all stages of COPD, as well as possible improvement in HrQOL and a reduction in exacerbations; however, more evidence is required to make firm conclusions. Interpretation of this evidence should be made with caution given that this analysis was done post hoc and interaction testing indicated no difference among outcomes across all stages of disease. It is unclear whether the difference reported in exacerbation rates would be clinically meaningful in practice; the changes found in HrQOL were determined to not be clinically meaningful by study authors.

### Long-Acting Anticholinergics/LAMAs (Tiotropium)

#### Summary of Findings

Although we found no RCTs of tiotropium to treat screen-detected COPD, we found a single trial from Troosters et al that included only untreated patients with moderate (stage 2) COPD and five subgroup analyses examining those with moderate or mild COPD derived from three individual trials (Understanding Potential Long-term Impacts on Function with Tiotropium [UPLIFT], French trial from Tonnel et al, and VA trial from Nieoehner et al) and one pooled analysis of subgroup data from the tiotropium arm of the INHANCE trial reported by Decramer. All trials used tiotropium at doses of 18 μg daily in the intervention group and placebo in the control group. There were at least three different studies reporting outcomes for exacerbations or HrQOL, but just one study for the other three outcomes (exercise capacity, dyspnea, and all-cause mortality). Results were somewhat mixed for tiotropium’s effect on exacerbations and HrQOL, although the bulk of the evidence suggested a beneficial effect on both. The trial from Troosters et al, with the population most approximating a screen-detected population, showed a statistically significant reduction in exacerbations and a statistically significant, but probably not clinically meaningful, difference in work productivity score. The overall strength of evidence for the effect of tiotropium on health outcomes in screen-detected COPD patients is low to moderate for exacerbations, low for HrQOL, and insufficient for other health outcomes.

#### Overview of Available Studies

We found no RCTs examining the clinical effectiveness of the LAMA tiotropium among screen-detected COPD populations. One fair-quality international trial specifically recruited patients with moderate COPD who were naïve to previous maintenance therapy (Table 18).139 Four subanalyses examined patients with moderate COPD,125,127–129 with one additional post hoc subanalysis further analyzing participants with mild stage 2 COPD (defined as FEV_1_ 60% to 70% of predicted).140 Two subanalyses (one prespecified and one post hoc)127,140 are from one fair-quality international trial (UPLIFT),141 one subanalysis is from a fair-quality French trial,129 one is from a good-quality U.S.-based trial in the VA system,128 and one is a post hoc subanalysis of the tiotropium arm from the INHANCE trial.125 The pooled data from Decramer contained a small number (about 7%) of patients with mild COPD (FEV_1_ ≥80% of predicted). Two analyses recruited participants on the more severe end of moderate COPD.128,129 The number of patients analyzed with moderate COPD ranged from 198 to 2,739, comprising a total of 4,592 patients. All primary trials required a minimum smoking history of 10 pack-years, with one subanalysis requiring a minimum of 20 pack-years.125 All primary trials excluded patients with a recent COPD exacerbation or respiratory tract infection (within 4 to 6 weeks of recruitment). Two trials excluded persons with asthma128,129 and three trials had some comorbidity exclusions.128,129,141 The minimum age was 40 years in all trials, with a mean age of 61.7 to 67.8 years (Table 19). The proportion of women ranged from 1.5 percent in the VA trial128 to 33.0 percent,125 and the mean smoking exposure ranged from 44.0 to 68.4 pack-years. None of the trials reported the mean number of exacerbations in the year preceding study recruitment; however, one subanalysis reported that 3.2 percent of the participants had at least one exacerbation in the preceding year, with more exacerbations in the placebo arm than in the tiotropium arm at baseline (1.3% vs. 5.0%).125 The mean FEV_1_ percent predicted at baseline was reported for four analyses for patients with moderate COPD and ranged from 59 to 65.7 percent of predicted.125,127,139,140 Three analyses reported the mean baseline HrQOL, which was 41.5 for patients with moderate disease,127 40.0 for the subset of patients with a baseline FEV_1_ of 60 to 70 percent of predicted,140 and 41.2 in one pooled analysis of three RCTs.125 Only one trial reported baseline physical activity, reporting a mean of 6,402.7 steps per day across all participants.139

The primary outcome varied across studies and was change in FEV_1_ in two trials,127,139 trough FEV_1_ in one subanalysis,125 percent of patients with 4 units or more of improvement in HrQOL in another trial,129 and percent of patients with an exacerbation or hospitalization due to an exacerbation in one trial (Table 18).128 Secondary outcomes included change in physical activity level (measured via activity monitor), exacerbations, time to first exacerbation, dyspnea, mortality, quality of life, hospitalization utilization, pulmonary function test change, and adverse events. Followup was 6 months in three trials,125,128,139 9 months in one trial,129 and 48 months in UPLIFT, the largest trial.127

All trials used tiotropium at doses of 18 μg daily in the intervention group and placebo in the control group (Table 18). One four-arm RCT was open label for the tiotropium arm,125 whereas the rest of the RCTs were double-blinded. One subanalysis provided outcomes data for the tiotropium and placebo arms among patients with mild to moderate COPD,125 while the other analysis was from clinical effectiveness trials of tiotropium compared to placebo. All trials allowed concomitant COPD inhaler medications.

Baseline characteristics were similar in the tiotropium and placebo groups, with three notable exceptions (Table 19). In the Tonnel trial, the placebo group had more current smokers and higher baseline HrQOL scores compared to the tiotropium group;129 the INHANCE subanalysis placebo arm had more participants with a recent COPD exacerbation compared to the tiotropium arm;125 and the UPLIFT trial subanalysis had statistically significantly fewer current smokers in the tiotropium group compared to the control group (29% vs. 36%; p=0.011).140

Discontinuation was reported in three of the trials among patients with moderate COPD.125,127,139 Discontinuation rates in the UPLIFT trial at 4 years were high for patients in this subpopulation, in both the intervention and control groups (30.6% and 34.7%, respectively),127 and in the INHANCE subanalysis, discontinuation rates were also notable, with 22 percent of the open-label tiotropium group and 26 percent of the placebo group discontinuing therapy at 6 months.125 The discontinuation rate at 6 months in the Troosters trial was lower at 11.3 and 9.6 percent in the tiotropium and placebo groups, respectively.139 All trials analyzed results using ITT methods, described as the inclusion of all participants receiving medications or taking at least one inhaled capsule and providing any followup after baseline data. All trials were sponsored by the pharmaceutical industry.

#### Detailed Results

##### Exacerbations

Three trials (n=3,483) reported outcomes related to exacerbations among patients with moderate disease, showing mixed results (Table 25).127,128,139 Two subanalyses showed a difference in exacerbation rates among those treated with tiotropium, while one underpowered subanalysis showed no difference in exacerbation rates in the tiotropium group compared to the placebo group. Two of these three trials defined what they considered to be an exacerbation.127,128 Exacerbations in the UPLIFT trial were defined as an increase/new onset of one or more respiratory symptoms for 3 days or more requiring antibiotic and/or systemic steroid treatment.127 Exacerbations in the VA trial were defined as a complex of respiratory symptoms, including an increase or new onset of more than one of the following: cough, sputum, wheezing, dyspnea, or chest tightness with a duration of at least 3 days requiring treatment with antibiotics or systemic steroids, hospitalization, or both.128

Table 25 Event-Based Outcomes for Tiotropium

Drug Class | Study, Year Quality | Treatment Comparison | Study Group | N Analyzed | Followup | Exacerbations | IG vs. CG | Hospital Utilization | IG vs. CG | All-Cause Mortality | IG vs. CG
Long-acting anticholinergic (tiotropium) | UPLIFT Decramer 2009^127^ Tashkin 2012^140^ Tashkin 2008^141^ | IG: tiotropium bromide (18 μg/day) CG: Placebo | IG | Stage II: 1384 FEV_1_ ≥60%: 632 | 48 months | Stage II: ≥1: 59.5% (824/1384)^*,§^ Median months to first: 23.1 (95% CI, 21.0 to 26.3)^*^ Mean number: 0.56 (95% CI, 0.52 to 0.60)^*^ FEV_1_ ≥60%: ≥1: 56%^*^ | Stage II: Time to first exacerbation: HR: 0.82 (95% CI, 0.75 to 0.90); p<0.0001 Mean number: RR, 0.80 (95% CI, 0.72 to 0.88); p<0.0001 FEV_1_ ≥60%: ≥1: HR, 0.83 (95% CI, 0.71 to 0.96); p=0.011 | Stage II: ≥1 hospitalized exacerbations: 15.2% (211/1384)^§^ Median months to first hospitalized exacerbation: NR Mean number of hospitalized exacerbations: 0.08 (0.07 to 0.09) FEV_1_ ≥60%: ≥1 hospitalized exacerbations: 13% | Stage II: Time to first hospitalized exacerbation: HR, 0.74 (95% CI, 0.62 to 0.88); p=0.001 Mean number of hospitalized exacerbations: RR, 0.80 (95% CI, 0.63 to 1.03); p=0.082 FEV_1_ ≥60%: ≥1 hospitalized exacerbations: HR, 0.86 (95% CI, 0.64 to 1.16); p=0.334 | Stage II: All-cause mortality: 9.2% (128/1384)^§^ Mortality from lower respiratory disease: 1.4% (20/1384)^§^ FEV_1_ ≥60%: All-cause mortality: 7.4% (47/632)^§^ | Stage II: All-cause mortality: HR, 0.84 (95% CI, 0.66 to 1.07) Mortality for lower respiratory tract infection: HR, 0.81 (95% CI, 0.45 to 1.46) FEV_1_ ≥60%: All-cause mortality: HR, 0.66 (95% CI, 0.45 to 0.96); p=0.031 More cardiac deaths and deaths due to COPD exacerbation occurred in the CG and numerically more deaths due to cancer occurred in the IG (data not reported)
Long-acting anticholinergic (tiotropium) | UPLIFT Decramer 2009^127^ Tashkin 2012^140^ Tashkin 2008^141^ | IG: tiotropium bromide (18 μg/day) CG: Placebo | CG | Stage II: 1355 FEV_1_ ≥60%: 578 | 48 months | Stage II: ≥1: 65.1% (882/1355)^*,§^ Median months to first: 17.5 (95% CI, 15.9 to 19.7)^*^ Mean number: 0.70 (95% CI, 0.65 to 0.75)^*^ FEV_1_ ≥60%: ≥1: 62%^*^ | Stage II: Time to first exacerbation: HR: 0.82 (95% CI, 0.75 to 0.90); p<0.0001 Mean number: RR, 0.80 (95% CI, 0.72 to 0.88); p<0.0001 FEV_1_ ≥60%: ≥1: HR, 0.83 (95% CI, 0.71 to 0.96); p=0.011 | Stage II: ≥1 hospitalized exacerbations: 19.5% (264/1355)^§^ Median months to first hospitalized exacerbation: NR Mean number of hospitalized exacerbations: 0.10 (95% CI, 0.08 to 0.12) FEV_1_ ≥60%: exacerbation requiring hospitalization: 15% | | Stage II: All-cause mortality: 10.8% (147/1355)^§^ Mortality from lower respiratory disease: 1.8% (24/1355)^§^ FEV_1_ ≥60%: All-cause mortality: 11.1% (64/578)^§^
Long-acting anticholinergic (tiotropium) | Decramer, 2013^125^ Fair | IG: tiotropium bromide (18 μg/day) CG: Placebo | IG | NA | 6 months | NR | NR | NR | NR | NR | NR
Long-acting anticholinergic (tiotropium) | Decramer, 2013^125^ Fair | IG: tiotropium bromide (18 μg/day) CG: Placebo | CG | NA | 6 months | NR | NR | NR | NR | NR | NR
Long-acting anticholinergic (tiotropium) | Niewoehner, 2005^128^ Good | IG: tiotropium bromide (18 μg per day) CG: Placebo | IG | NR\|\| | 6 months | NR | OR for ≥1 exacerbations: NS (numbers NR)^†^ | NR | NA | NR | NR
Long-acting anticholinergic (tiotropium) | Niewoehner, 2005^128^ Good | IG: tiotropium bromide (18 μg per day) CG: Placebo | CG | NR\|\| | 6 months | NR | OR for ≥1 exacerbations: NS (numbers NR)^†^ | NR | NA | NR | NR
Long-acting anticholinergic (tiotropium) | Tonnel, 2008^129^ Fair | IG: tiotropium bromide (18 μg per day) CG: Placebo | IG | NA | 9 months | NR | NA | NR | NA | NR | NR
Long-acting anticholinergic (tiotropium) | Tonnel, 2008^129^ Fair | IG: tiotropium bromide (18 μg per day) CG: Placebo | CG | NA | 9 months | NR | NA | NR | NA | NR | NR
Long-acting anticholinergic (tiotropium) | Troosters, 2014^139^ Troosters, 2011^170^ Fair | IG: tiotropium bromide (18 μg per day) CG: Placebo | IG | 238 | 6 months | 4.6% (11/238)^‡^ | OR: 0.42 (95% CI, 0.21 to 0.84) | NR | NA | 0 | NR
Long-acting anticholinergic (tiotropium) | Troosters, 2014^139^ Troosters, 2011^170^ Fair | IG: tiotropium bromide (18 μg per day) CG: Placebo | CG | 219 | 6 months | 11.0% (24/219)^‡^ | OR: 0.42 (95% CI, 0.21 to 0.84) | NR | NA | 0 | NR

* Increase/new onset >1 respiratory symptom for ≥3 days requiring antibiotic and/or systemic steroid.

† A complex of respiratory symptoms (increase or new onset) of >1 of the following: cough, sputum, wheezing, dyspnea, or chest tightness with a duration of at least 3 days requiring treatment with antibiotics or systemic steroids, hospitalization, or both.

‡ Definition of exacerbation not reported.

§ Calculated.

|| N not reported individually for intervention and control groups. Total analyzed for stages I and II is 287.

Abbreviations: CI = confidence interval; CG = control group; COPD = chronic obstructive pulmonary disease; FEV_1_= forced expiratory volume in 1 second; HR = hazard ratio; IG = intervention group; N = number; NA = not applicable; NR = not reported; NS = not significant; OR = odds ratio; RR = risk ratio; UPLIFT = Understanding Potential Long-term Impacts on Function with Tiotropium.

The UPLIFT trial’s subanalysis of patients with moderate COPD (n=2,739) reported that the time to first exacerbation and mean number of exacerbations were statistically significantly lower in the tiotropium group compared to placebo at 4 years (time to first exacerbation, 23.1 vs. 17.5 months; HR, 0.82 [95% CI, 0.75 to 0.90]; p<0.0001; mean number of exacerbations, 0.56 vs. 0.70; RR, 0.80 [95% CI, 0.72 to 0.88]; p<0.0001) (Table 25).127 There was no interaction of treatment effect on exacerbations and GOLD stage (p=0.237), and the main trial (including patients with all COPD severities) showed a decrease in exacerbations in the tiotropium group compared to the placebo group (0.73 vs. 0.85 exacerbations per patient-year; RR, 0.86 [95% CI, 0.81 to 0.91]). The Troosters trial (n=457) also showed a reduction in exacerbations among patients in the tiotropium group compared to the placebo group at 6 months (4.6% vs. 11.0%; OR, 0.42 [95% CI, 0.21 to 0.84]).139 Similar results were seen in the UPLIFT subanalysis (Table 25). Conversely, the VA trial (n=287) reported no difference in exacerbations among moderate COPD patients in the tiotropium group compared to the placebo group at 6 months, but this trial was not powered to adequately asses this outcome for the subanalysis.128

Only the two UPLIFT subanalyses reported exacerbations requiring hospitalization among patients with moderate COPD at 4 years (Table 25).127,140 Both analyses showed no difference among those treated with tiotropium compared to placebo. Specifically, the UPLIFT subanalysis including patients with moderate disease reported no difference in the mean number of patients hospitalized with exacerbations per patient-year compared to placebo (0.08 vs. 0.10; RR, 0.80 [95% CI, 0.63 to 1.03]), but found a reduction in time to first hospitalization due to an exacerbation (HR, 0.74 [95% CI, 0.62 to 0.88]).127 The UPLIFT subanalysis for patients with a subset of moderate COPD (FEV_1_ 60% to 70% of predicted) showed no difference in patients with one or more hospitalizations due to exacerbations (13% vs. 15%; HR, 0.86 [95% CI, 0.64 to 1.16]).

##### All-Cause Mortality

The two subanalyses from the UPLIFT trial provide the only information on all-cause mortality among patients with moderate COPD (Table 25).127,140 The first analysis (n=2,739) found that all-cause mortality and mortality due to lower respiratory tract infections were similar in the tiotropium and placebo groups at 48 months (9.2% vs. 10.8%; HR, 0.84 [95% CI, 0.66 to 1.07]; 1.4% vs. 1.8%; HR, 0.81 [95% CI, 0.45 to 1.46], respectively).127 Conversely, in the post hoc subanalysis of participants with an FEV_1_ of 60 to 70 percent of predicted (n=1,210), all-cause mortality was statistically significantly lower in the tiotropium group compared to the placebo group (7.4% vs. 11.1%; HR, 0.66 [95% CI, 0.45 to 0.96]).140 Further, there were more cardiac deaths and deaths due to COPD exacerbation in the placebo group and more absolute deaths due to cancer in the tiotropium group (data not reported).

##### Dyspnea Score

Only one study (the post hoc subanalysis of the INHANCE trial; n=658) reported dyspnea scores among patients with mild to moderate COPD (Table 26).125 Results showed that more patients achieved a meaningful clinical difference (≥1 point) in dyspnea score in the tiotropium group compared to the placebo group at 6 months (64.6% vs. 49.3%; OR, 1.59 [95% CI, 1.07 to 2.37]).

Table 26 Questionnaire- or Test-Based Outcomes for Tiotropium

Drug Class | Study, year Quality | Treatment Comparison | Study Group | N Analyzed | Followup | Dyspnea Score | IG vs. CG | HrQOL | IG vs. CG | Exercise capacity | IG vs. CG
Long-acting anticholinergic (tiotropium) | UPLIFT Decramer 2009^127^ Tashkin 2012^140^ Tashkin 2008^141^ | IG: tiotropium bromide (18 μg/day) CG: Placebo | IG | Stage II: 908 FEV_1_ ≥60%: NR (632 randomized) | 48 months | NR | NR | Stage II: deterioration of mean SGRQ total score: 0.89 units/year (SE, 0.13) FEV_1_ ≥60%: % achieving a minimally clinical difference on the SGRQ total score: 52%^†^ | p<0.05 | NR | NR
Long-acting anticholinergic (tiotropium) | UPLIFT Decramer 2009^127^ Tashkin 2012^140^ Tashkin 2008^141^ | IG: tiotropium bromide (18 μg/day) CG: Placebo | CG | Stage II: 839 FEV_1_ ≥60%: NR (578 randomized) | 48 months | NR | NR | Stage II: deterioration of mean SGRQ total score: 0.99 units/year (SE, 0.13) FEV_1_ ≥60%: % achieving a minimally clinical difference on the SGRQ total score: 44%^†^ | p=0.58 | NR | NR
Long-acting anticholinergic (tiotropium) | Decramer, 2013^125^ Fair | IG: tiotropium bromide (18 μg/day) CG: Placebo | IG | 236 | 6 months | % of patients achieving a minimally clinical difference on TDI: 64.6%^*^ | OR, 1.59 (1.07 to 2.37) | % of patients achieving a minimally clinical difference on SGRQ total score: 51.8%^†^ | OR, 1.46 (1.01 to 2.10) | NR | NR
Long-acting anticholinergic (tiotropium) | Decramer, 2013^125^ Fair | IG: tiotropium bromide (18 μg/day) CG: Placebo | CG | 675 | 6 months | % of patients achieving a minimally clinical difference on TDI: 49.3%^*^ | OR, 1.59 (1.07 to 2.37) | % of patients achieving a minimally clinical difference on SGRQ total score: 42.0%^†^ | OR, 1.46 (1.01 to 2.10) | NR | NR
Long-acting anticholinergic (tiotropium) | Niewoehner, 2005^128^ Good | IG: tiotropium bromide (18 μg/day) CG: Placebo | IG | NR | 6 months | NR | NR | NR | NR | NR | NR
Long-acting anticholinergic (tiotropium) | Niewoehner, 2005^128^ Good | IG: tiotropium bromide (18 μg/day) CG: Placebo | CG | NR | 6 months | NR | NR | NR | NR | NR | NR
Long-acting anticholinergic (tiotropium) | Tonnel, 2008^129^ Fair | IG: tiotropium bromide (18 μg/day) CG: Placebo | IG | 105 | 9 months | NR | NR | Adjusted change in SGRQ total score from BL, mean (SE)^‡^: −8.85 (1.37) | Difference in change in score from BL, mean (SE)^‡^: −1.47 (1.99); 95% CI, −5.37 to 2.44; p=0.46 | NR | NR
Long-acting anticholinergic (tiotropium) | Tonnel, 2008^129^ Fair | IG: tiotropium bromide (18 μg/day) CG: Placebo | CG | 93 | 9 months | NR | NR | Adjusted change in SGRQ total score from BL, mean (SE)^‡^: −7.38 (1.44) | Difference in change in score from BL, mean (SE)^‡^: −1.47 (1.99); 95% CI, −5.37 to 2.44; p=0.46 | NR | NR
Long-acting anticholinergic (tiotropium) | Troosters, 2014^139^ Troosters, 2011^170^ Fair | IG: tiotropium bromide (18 μg/day) CG: Placebo | IG | 221 | 6 months | NR | NR | Change in WPAI score from BL: 2.1 (±22%) | Least-squares mean difference in change in WPAI score from BL: −3.76 (−7.39 to −0.13); p=0.043 | Min/day of light activity, mean (SD): 111.4 (±81.7) Proportion of inactive patients (<6000 steps/day), n (%): 78 (39.8) | Proportion of inactive patients: OR, 0.86 (95% CI, 0.57 to 1.30); p=0.48^§^
Long-acting anticholinergic (tiotropium) | Troosters, 2014^139^ Troosters, 2011^170^ Fair | IG: tiotropium bromide (18 μg/day) CG: Placebo | CG | 205 | | | NR | Change in WPAI score from BL: −5.6 (±20%) | Least-squares mean difference in change in WPAI score from BL: −3.76 (−7.39 to −0.13); p=0.043 | Min/day of light activity, mean (SD): 101.4 (±79.9) Proportion of inactive patients (<6000 steps/day), n (%): 79 (43.4) | Proportion of inactive patients: OR, 0.86 (95% CI, 0.57 to 1.30); p=0.48^§^

* % achieving a meaningful clinical difference (≥ 1 point).

† % achieving a meaningful clinical difference (≥−4 units).

‡ Adjusted for baseline SGRQ total scores.

§ Between-group difference only significant at 12 weeks: p=0.047.

Abbreviations: BL = baseline; CG = control group; FEV_1_= forced expiratory volume in 1 second; IG = intervention group; Min = minutes; N = number; NR = not reported; OR = odds ratio; SE = standard error; SGRQ = St. George’s Respiratory Questionnaire; TDI = transition dyspnea index; UPLIFT = Understanding Potential Long-term Impacts on Function with Tiotropium; WPAI = Work Productivity and Activity Impairment Questionnaire.

##### HrQOL

Four trials provided HrQOL outcomes for patients with moderate COPD (Table 26).125,127,129,139 The only trial exclusively recruiting patients with moderate disease reported statistically significant, although modest, differences in work productivity and activity impairment scores, but it is unlikely that these represent a clinically meaningful difference.139 One subanalysis reported no difference in HrQOL (measured by SGRQ) change from baseline in the tiotropium group compared to the placebo group.129

Conversely, two subanalyses (one post hoc and one a priori) reported more patients with a clinically meaningful change in HrQOL score (measured by SGRQ) among participants in the tiotropium group compared to the placebo group (Tables 20 and 26).125,127 Specifically, the Troosters trial (n=426) reported changes in the Work Productivity and Activity Impairment (WPAI) score, a six-item questionnaire measuring health problem–related impairments, absenteeism, and presenteeism in paid and unpaid work during the past 7 days; however, no minimum clinically meaningful change has been validated for COPD. Authors reported an improvement in WPAI score in the tiotropium group and deterioration of WPAI score in the placebo group, but the CIs are wide (difference, −3.76 [95% CI, −7.39 to −0.13]) at 24 weeks.139 The percentage of work time missed due to ill health was similar between the tiotropium and placebo groups (mean difference, −2.33% [95% CI, −7.39 to 2.73]). Additionally, more patients were rated by their physicians as having excellent global health assessments of overall health status in the tiotropium group compared to the placebo group at week 24 (18.1% vs. 10.9%). The Tonnel subanalysis (n=198) reported similar changes in mean HrQOL score among patients in the tiotropium and placebo groups (−8.85 vs. −7.38; absolute difference, 1.47 [95% CI, −5.37 to 2.44]).129 The main Tonnel trial, whose primary outcome was HrQOL change (as measured by SGRQ) (which included patients with all stages of COPD), showed a statistically significant difference in the percentage of patients achieving a minimal clinically meaningful change in HrQOL, with interaction testing showing no heterogeneity of effect by COPD severity (p=0.078). The INHANCE subanalysis for patients with mild to moderate COPD reported a −5.2 raw mean change from baseline in HrQOL (measured by SGRQ) in the tiotropium group and −3.1 in the placebo group at 6 months (minimally clinical difference defined as −4.0), with more achieving a clinically meaningful change in HrQOL score in the tiotropium group compared to the placebo group (51.8% vs. 42.0%; OR, 1.46 [95% CI, 1.01 to 2.10]).125 The UPLIFT trial subanalysis reported an improvement in HrQOL score among both groups in the first 6 months of treatment, with a subsequent worsening in score at similar rates over time (0.89 vs. 0.99 units per year; p=0.58).127 At any given time point, the difference in HrQOL score between the tiotropium and placebo groups ranged from 2.7 to 4.0 units. For the UPLIFT subgroup analysis of COPD patients with an FEV_1_ of 60 to 70 percent of predicted, the tiotropium group was more likely to experience a clinically meaningful change in HrQOL compared to the placebo group (52% vs. 44%; p<0.05).140

##### Exercise Capacity

Only the Troosters trial, which recruited only patients with moderate COPD, reported the outcome of exercise capacity at 6 months (Table 26).139 The mean activity rate measured with activity monitors was not statistically significantly different in the tiotropium group compared to the placebo group at 6 months (proportion of inactive patients [<6,000 steps/day], 39.8% vs. 43.4%; OR, 0.86 [95% CI, 0.57 to 1.30]). There was a statistically significantly lower proportion of inactive patients in the tiotropium group compared to the placebo group at 12 weeks (p=0.047).

#### Critical Appraisal

No trials examining the effectiveness of tiotropium among patients with mild to moderate COPD were found; however, the Troosters trial population is the closest identified to a screen-detected population due to the fact that the trial only recruited patients with moderate COPD who were naïve to maintenance therapy. It was also the only trial specifically recruiting this population, so it was not subject to the limitations of subanalyses; however, it was powered to detect disease-oriented outcome of FEV_1_ change, not the outcomes considered in this review. Despite being underpowered to fully evaluate exacerbations, it did find a statistically significant difference in this outcome when comparing those treated with tiotropium to those on placebo. The HrQOL outcomes from Troosters, while improved in the tiotropium group, are unlikely to be clinically meaningful.

The trial durations of the included subanalyses were short (≤9 months) in all but one trial, which provided 4-year followup, limiting the ability to assess patient-centered outcomes over time. All but two125,127 subanalyses were prespecified. Two of the five subanalyses performed interaction testing for the reported outcomes, showing no heterogeneity of treatment effect by COPD severity.127,129 Additionally, three subanalyses controlled for confounders for at least one outcome.125,129,140 Overall, reporting for tiotropium outcomes was scant, and for three outcomes (exercise capacity, dyspnea, and all-cause mortality), only one trial reported results, making conclusions difficult. The only outcome with data from more than one trial was quality of life, which showed that there may be a modest, statistically significant improvement in the percentage of patients who experience a clinically meaningful change, but further research is needed to confirm this finding.

### ICS

#### Summary of Findings

While there were more trials of ICS among patients with mild to moderate COPD than for the other medications we examined, there were still relatively few trials evaluating the effectiveness of ICS for each of the patient-important outcomes. Unlike the other medication classes in our review (LABAs, ICS-LABA, long-acting anticholinergics/LAMAs), ICS is the only medication class in which mild COPD participants are represented in greater number. Data were further limited by representing primarily subgroup analyses, since the European Respiratory Society study on Chronic Obstructive Pulmonary Disease (EUROSCOP) was the only RCT that specifically aimed to recruit patients with mild disease (patients with moderate disease were also included).130 EUROSCOP reported exacerbations and all-cause mortality, as did three other trials. Most reported data, including the EUROSCOP results, supported a reduction in exacerbations with ICS, although differences in the definition of this outcome limited robust conclusions. All-cause mortality appeared similar between ICS and placebo groups, although relatively low mortality rates and lack of long-term followup limit the robustness of these findings. For HrQOL or dyspnea symptoms, data are very sparse and limited, since only subanalyses from two trials were available and no outcome data were reported for exercise capacity. The overall strength of evidence for the effect of ICS on exacerbations in screen-detected COPD patients is insufficient for exercise capacity and low for other health outcomes.

#### Overview of Available Studies

Six fair-quality RCTs (n=3,983) examined the effectiveness of ICS compared to placebo in populations with either mild to moderate COPD or in populations with a mean FEV_1_ of 60 percent of predicted or greater (Table 18).126,130–134 No RCTs examined the clinical effectiveness of ICS in a screen-detected COPD population. The EUROSCOP trial (n=1,277) was the only RCT that exclusively recruited patients with mild to moderate COPD.130 Two post hoc subanalyses126,133 of larger RCTs by Calverley133 and the TORCH trial138 provided outcomes data on patients with mild to moderate COPD; neither trial controlled for confounders or performed interaction testing. Three RCTs131,132,134 are included in this review because their mean FEV_1_ percent predicted was 60 percent or greater (63.0%, 67.8%, and 86.6%), with the Vestbo trial having the highest mean FEV_1_ of 86.6 percent.131 None of these three RCTs provided subanalyses of strictly mild to moderate COPD patients.

Two trials recruited patients from centers internationally;126,133 one trial each was performed in the United States,134 the Netherlands,132 western Europe,130 and Denmark (Table 18).131 Three of the analyses, the Lung Health Study (LHS) II, a subanalysis of the TORCH trial, and EUROSCOP, were large, with more than 1,000 patients each;126,134,142 two analyses recruited more than 200 patients,131,133 and one study was small with less than 100 patients.132 The lower age limit was as low as 30 years in two trials,130,131 with EUROSCOP having an upper age cutoff of 60 years;130 the mean age in the six trials ranged from 52.4 to 65.1 years (Table 19). The majority of participants were men, with percentage of women ranging from 13.9 to 39.6 percent. All studies, except the population-based Vestbo trial,131 only recruited former or current smokers. Three RCTs had a minimum smoking exposure requirement of 5^130^ to 10 pack-years,126,132 although only two RCTs reported mean smoking exposures, which were 39.3 and 43.5 pack-years. Five trials had exclusions for serious medical comorbid conditions.130,131,133,134, 138 Only the TORCH trial reported the mean number of exacerbations requiring hospitalization in the preceding year across treatment groups, which was 0.2.^126^ Five RCTs reported the mean baseline postbronchodilator FEV_1_ percent predicted, which ranged from 58.8 to 86.6 percent.126,130–132,134 Two analyses were composed entirely of moderate COPD patients,132,133 one analysis recruited almost entirely moderate COPD patients (98.7%),126 and three studies130,131,134 did not report the proportion of patients with mild COPD, but two of these likely included a fair number of mild patients since the baseline FEV_1_ percent predicted was greater than 80 percent.130,131 Baseline HrQOL (measured by SGRQ) was reported in two trials,126,132 with mean scores of 45.4 and 30.0 across the population; the TORCH trial126 included symptomatic patients, as reflected by the baseline HrQOL, and the majority of patients with moderate COPD had an FEV_1_ percent predicted on the more severe end of the range (50% to <60%). The LHS II134 excluded those who used bronchodilators or corticosteroids (inhaled or systemic) in the past year, the Vestbo trial excluded those using oral or inhaled steroids in the past 6 months,131 and the Lapperre trial excluded those using ICS in the past 6 months.132

Two RCTs were four-armed trials with additional combination ICS-LABA arms,126,132 and one RCT had three arms examining two doses of ICS compared to placebo (Table 18).133 One trial examined mometasone furoate (800 μg/day),133 two RCTs examined budesonide (800 to 1,200 μg/day),130,131 two RCTs examined fluticasone (1,000 μg/day),126,132 and one examined the effectiveness of triamcinalone (1,200 μg/day);134 all inhalers were dosed daily or twice a day. Concomitant COPD medications were allowed in all the trials except the EUROSCOP trial, which did not allow LABAs or cromolyn.130

Primary outcomes in the included trials varied from all-cause mortality,126 mean postbronchodilator FEV_1_133 or change in FEV_1_,130,131,134 and inflammatory cell counts in bronchial biopsies and induced sputum (Table 18).132 Secondary outcomes included exacerbations, respiratory symptoms, cause-specific morbidity and mortality, airway reactivity in response to methacholine, HrQOL, and adverse events. Followup ranged from 9 to 54 months.

Three RCTs measured compliance with canister weights or hidden canister counters,130,132,134 one RCT used patient self-report for compliance,133 and two RCTs did not report compliance ascertainment methods.131,138 Four of the six trials reported high compliance rates in the primary trials.130–133 The EUROSCOP and Calverley trials excluded those with less than 75 and 80 percent adherence, respectively, during the run-in periods,130,133 and the Lapperre trial (the only trial not using ITT) excluded patients with less than 70 percent adherence.132 In the Lapperre trial, no patients in the ICS group and five out of 29 patients in the placebo group were excluded for nonadherence. The Vestbo trial reported that few patients had less than 75 percent compliance, although it was one of the trials that did not report compliance ascertainment methods.131 The LHS II reported 54 percent compliance in the ICS group and 59 percent in the placebo group as measured by canister weight.134

Withdrawal, discontinuation, and loss to followup rates were reported inconsistently in the six trials. Discontinuation rates varied widely in the four RCTs reporting these data and ranged from 5 percent in the LHS II134 to as high as 42.4 percent in the Calverley trial.133 Similarly, ITT was handled variably in the five trials using it.130,131,133,134,138 One trial included only participants with at least one dose of treatment and one baseline and one postbaseline visit (806 analyzed/911 randomized).133 The TORCH trial included all patients in the efficacy analysis, except 72 of the 6,184 randomized due to site standardization issues. The EUROSCOP and Vestbo trials analyzed all randomized participants meeting inclusion criteria and run-in compliance thresholds.130 The LHS II reported ITT without providing additional details and the Lapperre trial did not use ITT. All trials except the LHS II were sponsored by the pharmaceutical industry.

#### Detailed Results

##### Exacerbations

Four RCTs reported exacerbation rates among patients with mild to moderate COPD (n=2,803),126,130,131,133 but only two performed statistical testing to detect differences among treatment groups (Table 27). Trials defined exacerbations variably, leading to wide variations in exacerbation rates. The EUROSCOP trial (n=1,277), which recruited patients with mild to moderate COPD, reported a statistically significantly lower yearly rate of severe exacerbations (defined as exacerbation requiring oral corticosteroids), but overall the absolute difference was very small in both groups at 3 years (0.05 vs. 0.07; RR, 0.63 [95% CI, 0.47 to 0.85]).130 A subanalysis of the TORCH trial of patients with mild to moderate COPD (n=1,072) reported a lower annual rate of moderate to severe exacerbations (defined as symptomatic deterioration requiring treatment with antibiotic agents, systemic corticosteroids, hospitalization, or a combination of these) for the fluticasone group compared to the placebo group (0.68 vs. 0.82) without providing statistical testing by treatment arm.126 The main trial showed a reduction in moderate or severe exacerbations in the fluticasone group compared to placebo (RR, 0.82 [95% CI, 0.76 to 0.89]).138 Similarly, the post hoc subanalysis of the Calverley trial (n=266) including patients with moderate COPD reported more patients with exacerbations (defined as clinically significant worsening of COPD symptoms requiring treatment with antibiotics and/or systemic steroids) in the placebo group compared to either of the mometasone furoate groups (18% [800 μg/daily] vs. 27% [400 μg/twice a day] vs. 35% [placebo]; no statistical testing provided) at 1 year.133 These subanalysis results should be interpreted with caution, however, as the subanalysis did not report baseline characteristics for the patients with moderate COPD, making it impossible to assess differences among treatment groups. The LHS II (n=1,116) reported comparable rates of hospitalizations (0.99 vs. 2.1; p=0.07) and emergency department visits (1.3 vs. 1.0; p=0.36) for respiratory conditions per 100 patient-years for the triamcinolone and placebo groups at 40 months.134 The Vestbo trial (n=290) reported no statistically significant difference in annual exacerbations or in exacerbations requiring hospital admission at 3 years, but the definition of exacerbations was inconsistent with that of the field, so these results are not comparable to the other studies (defined as affirmative answer to the question “Have you since your last visit experienced more cough and phlegm than usual?”).131

Table 27 Event-Based Outcomes for ICS

Drug Class | Study, Year Quality | Treatment Comparison | Study Group | N Analyzed | Followup | Exacerbations | IG vs. CG | Hospital Utilization | IG vs. CG | All-Cause Mortality | IG vs. CG
ICS-Budesonide | EUROSCOP Lofdahl 2007^142^ Pauwels 1999^130^ Fair | IG: Budesonide (800 μg/day) CG: Placebo | IG | 593 | 36 months | Yearly rate of severe exacerbations: 0.05^*^ | RR (95% CI): 0.63 (0.47 to 0.85); p=0.002 | NR | NR | Deaths, n (%): 8 (1.3)^†^ | Deaths: p=0.64
ICS-Budesonide | EUROSCOP Lofdahl 2007^142^ Pauwels 1999^130^ Fair | IG: Budesonide (800 μg/day) CG: Placebo | CG | 582 | 36 months | Yearly rate of severe exacerbations: 0.07^*^ | RR (95% CI): 0.63 (0.47 to 0.85); p=0.002 | NR | NR | Deaths, n (%): 10 (1.7)^†^ | Deaths: p=0.64
ICS-Budesonide | Vestbo, 1999^131^ Fair | IG: Budesonide 1200 μg/day (800 μg morning, 400 μg evening) for 6 months; 400 μg/twice a day for 30 months CG: Placebo | IG | 145 | 36 months | 155 exacerbations (unclear % of patients)^‡^ | “Difference was not significant” | 0.7% admitted to hospital for exacerbation (1 patient admitted twice) | NR | Deaths: 4 (2.8%)^§^ | NR
ICS-Budesonide | Vestbo, 1999^131^ Fair | IG: Budesonide 1200 μg/day (800 μg morning, 400 μg evening) for 6 months; 400 μg/twice a day for 30 months CG: Placebo | CG | 145 | 36 months | 161 exacerbations (unclear % of patients)^‡^ | “Difference was not significant” | 0.7% admitted to hospital for exacerbation (1 patient admitted once) | NR | Deaths: 5 (3.4%)^§^ | NR
ICS-Fluticasone Propionate | TORCH Jenkins, 2009^126^ Calverley, 2007^138^ Fair | IG: Fluticasone propionate (500 μg/twice a day) CG: Placebo | IG | 537 | 36 months | Annual rate of moderate/severe exacerbations: 0.68\|\| | NR | NR | NA | 53 (9.9%) | NR
ICS-Fluticasone Propionate | TORCH Jenkins, 2009^126^ Calverley, 2007^138^ Fair | IG: Fluticasone propionate (500 μg/twice a day) CG: Placebo | CG | 535 | 36 months | Annual rate of moderate/severe exacerbations: 0.82\|\| | NR | NR | NA | 61 (11.4%) | NR
ICS-Fluticasone Propionate | Lapperre 2009^132^ Fair | IG1: Fluticasone propionate (500 μg/twice a day) for the first 6 months and then placebo for 24 months IG2: Fluticasone propionate (500 μg/twice a day) for 30 months CG: Placebo | IG1 | NA | 30 months | NR | NA | NR | NA | NR | NR
ICS-Fluticasone Propionate | Lapperre 2009^132^ Fair | IG1: Fluticasone propionate (500 μg/twice a day) for the first 6 months and then placebo for 24 months IG2: Fluticasone propionate (500 μg/twice a day) for 30 months CG: Placebo | IG2 | NA | 30 months | NR | NA | NR | NA | NR | NR
ICS-Fluticasone Propionate | Lapperre 2009^132^ Fair | IG1: Fluticasone propionate (500 μg/twice a day) for the first 6 months and then placebo for 24 months IG2: Fluticasone propionate (500 μg/twice a day) for 30 months CG: Placebo | CG | NA | 30 months | NR | NA | NR | NA | NR | NR
ICS-Mometasone Furoate | Calverley, 2008^133^ Fair | IG1: Mometasone furoate (800 μg/day) IG2: Mometasone furoate (400 μg/twice a day) CG: Placebo | IG1 | NR (97 randomized) | 12 months | 18% (Number NR)^¶^ | NR | NR | NR | NR | NR
ICS-Mometasone Furoate | Calverley, 2008^133^ Fair | IG1: Mometasone furoate (800 μg/day) IG2: Mometasone furoate (400 μg/twice a day) CG: Placebo | IG2 | NR (88 randomized) | 12 months | 27% (Number NR)^¶^ | NR | NR | NR | NR | NR
ICS-Mometasone Furoate | Calverley, 2008^133^ Fair | IG1: Mometasone furoate (800 μg/day) IG2: Mometasone furoate (400 μg/twice a day) CG: Placebo | CG | NR (81 randomized) | 12 months | 35% (Number NR)^¶^ | NR | NR | NR | NR | NR
ICS-Triamcinolone Acetonide | Lung Health Study II, 2000^134^ Fair | IG: Triamcinolone acetoneide, 6 inhalations (100 μg/inhalation) twice a day, total dose of 1200 μg/day CG: Placebo | IG | NR (559 randomized) | 40 months | NR | NA | Hospitalizations per 100-py for respiratory conditions: 0.99 ED visits not resulting in hospitalization per 100-py for respiratory conditions: 1.3 | Hospitalizations per 100-py for respiratory conditions: p=0.07 ED visits not resulting in hospitalization per 100-py for respiratory conditions: p=0.36 | All-cause mortality, n: 15^#^ CVD-related mortality, n: 6 | All-cause mortality: p=0.49 CVD-related mortality: p=0.16
ICS-Triamcinolone Acetonide | Lung Health Study II, 2000^134^ Fair | IG: Triamcinolone acetoneide, 6 inhalations (100 μg/inhalation) twice a day, total dose of 1200 μg/day CG: Placebo | CG | NR (557 randomized) | 40 months | NR | NA | Hospitalizations per 100-py for respiratory conditions: 2.1 ED visits not resulting in hospitalization per 100-py for respiratory conditions: 1.0 | Hospitalizations per 100-py for respiratory conditions: p=0.07 ED visits not resulting in hospitalization per 100-py for respiratory conditions: p=0.36 | All-cause mortality, n (%): 19 (3.4)^#^ CVD-related mortality, n (%): 2 (0.4) | All-cause mortality: p=0.49 CVD-related mortality: p=0.16

* Event requiring a course of oral corticosteroids.

† Causes of death in the placebo group were bronchial carcinoma (3 subjects), sudden cardiac arrest (2), trauma (2), myocardial infarction (1), pulmonary embolism (1), and exacerbation of COPD (1). Causes of death in the budesonide group were bronchial carcinoma (3), myocardial infarction (2), sudden cardiac arrest (1), ruptured aortic aneurysm (1), and gastric carcinoma (1).

‡ Affirmative answer to the question “Have you since your last visit experienced more cough and phlegm than usual?”

§ Deaths unrelated to COPD or treatment.

|| Symptomatic deterioration requiring treatment with antibiotic agents, systemic corticosteroids, hospitalization, or a combination of these.

¶ Clinically significant worsening of COPD symptoms requiring treatment with antibiotics and/or systemic steroids.

# Causes of death in the placebo group were cardiovascular disease (2 subjects), lung cancer (4), other cancer (10), other or unknown cause (3). Causes of death in the triamcinolone group were cardiovascular disease (6 subjects), lung cancer (5), other cancer (2), other or unknown cause (2).

Abbreviations: CG = control group; COPD = chronic obstrctive pulmonary disease; CVD = cardiovascular disease; ED = emergency department; EUROSCOP = European Respiratory Society study on Chronic Obstructive Pulmonary Disease; ICS = inhaled corticosteroids; IG = intervention group; N = number; NA = not applicable; NR = not reported; py = person-years; RR = risk ratio; TORCH = Towards a Revolution in COPD Health.

##### All-Cause Mortality

Four fair-quality RCTs reported all-cause mortality among patients with mild to moderate COPD (n=3,653),126,131,134,142 but only the EUROSCOP trial and the LHS II performed statistical testing, showing no statistical difference between treatment groups (Table 27).130,134 Mortality was rare (<5%) in all trials, except the 36-month TORCH trial, in which all-cause mortality was 9.9 percent (53/537) in the fluticasone group and 11.4 percent (61/535) in the placebo group; the main trial showed no all-cause mortality benefit from fluticasone over placebo.126,138 This higher number of deaths in the TORCH trial subanalysis may be because most participants with moderate COPD were on the more severe end (63% of those with moderate disease had an FEV_1_ of 50% to <60% of predicted). In the EUROSCOP trial (n=1,277), deaths were similarly rare in the ICS and placebo groups at 3 years (8/593 [1.3%] vs. 10/582 [1.7%]; p=0.64).130 The only death related to COPD was in the placebo group; other causes of death were bronchial carcinoma (3 vs. 3 subjects), sudden cardiac arrest (2 vs. 2), trauma (2 in the control group), myocardial infarction (2 vs. 1), pulmonary embolism (1 in the control group), sudden cardiac arrest (1 in the intervention group), ruptured aortic aneurysm (1 in the intervention group), and gastric carcinoma (1 in the intervention group). In the LHS II (n=1,116), which was the longest trial (up to 54 months; mean, 40 months, with a mean FEV_1_ of 67.8% of predicted), all-cause mortality rates were relatively rare (<5%) and similar in both groups (15/559 vs. 19/557; p=0.49), as were the causes of death from cardiovascular disease (6 intervention vs. 2 control subjects; p=0.16), lung cancer (5 vs. 4; p=0.74), and other or unknown cause (2 vs. 3; p=0.65), except for other cancer (2 vs. 10; p=0.02). The Vestbo trial reported a low death rate, with none of the deaths attributable to COPD or treatment at 3 years (2.8% vs. 3.4%).131

##### Dyspnea Score

Two fair-quality RCTs with a mean baseline FEV_1_ of 60 percent of predicted or greater, Lapperre and LHS II, reported self-reported dyspnea scores (as measured by the MRC) (Table 28).132,134 The LHS II reported that statistically significantly fewer participants in the triamcinolone group experienced dyspnea compared to the placebo group at 36 months (p=0.02); MRC score change from baseline was not reported, however, so it is not clear if this finding is clinically important.134 The Lapperre trial reported a statistically significant lower MRC dyspnea score in the fluticasone group compared to the control group over months 7 to 24 of the trial (mean difference of −0.2 points/year [95% CI, −0.3 to −0.06]; p=0.003); however, neither the treatment or placebo group had a minimum clinically important difference in MRC score from baseline (minimum >1 point).132

Table 28 Questionnaire- or Test-Based Outcomes for ICS

Drug Class | Study, Year Quality | Treatment Comparison | Study Group | N Analyzed | Followup | Dyspnea Score | IG vs. CG | HrQOL | IG vs. CG | Exercise Capacity | IG vs. CG
ICS-Budesonide | EUROSCOP Lofdahl 2007^142^ Pauwels 1999^130^ Fair | IG: Budesonide (800 μg/day) CG: Placebo | IG | 593 | 36 months | NR | NR | NR | NR | NR | NR
ICS-Budesonide | EUROSCOP Lofdahl 2007^142^ Pauwels 1999^130^ Fair | IG: Budesonide (800 μg/day) CG: Placebo | CG | 582 | 36 months | NR | NR | NR | NR | NR | NR
ICS-Budesonide | Vestbo, 1999^131^ Fair | IG: budesonide 1200 μg/day (800 μg morning, 400 μg evening) for 6 months; 400 μg/twice a day for 30 months CG: Placebo | IG | NA | 36 months | NR | NR | NR | NR | NR | NR
ICS-Budesonide | Vestbo, 1999^131^ Fair | IG: budesonide 1200 μg/day (800 μg morning, 400 μg evening) for 6 months; 400 μg/twice a day for 30 months CG: Placebo | CG | NA | 36 months | NR | NR | NR | NR | NR | NR
ICS-Fluticasone Propionate | TORCH Jenkins, 2009^126^ Calverley, 2007^138^ Fair | IG: fluticasone propionate (500 μg/twice a day) CG: Placebo | IG | 537 | 36 months | NR | NR | Change in SGRQ from BL, mean: −2.1 | NR | NR | NR
ICS-Fluticasone Propionate | TORCH Jenkins, 2009^126^ Calverley, 2007^138^ Fair | IG: fluticasone propionate (500 μg/twice a day) CG: Placebo | CG | 535 | 36 months | NR | NR | Change in SGRQ from BL, mean: −1.3 | NR | NR | NR
ICS-Fluticasone Propionate | Lapperre 2009^132^ Fair | IG1: fluticasone propionate (500 μg/twice a day) for first 6 months and then placebo for 24 months IG2: fluticasone propionate (500 μg/twice a day) for 30 months CG: Placebo | IG1 | 23 | 30 months | NR | IG1 vs. CG: NR IG2 vs. CG: change in MRC dyspnea score compared to CG during months 7 to 24: −0.2 points/year (95% CI, −0.3 to −0.06); p=0.003 | NR | IG1 vs. CG: NR IG2 vs. CG: change in SGRQ activity score compared to CG during months 7 to 24: −3.1 points/year (95% CI, −5.5 to −0.7); p=0.012 | NR | NR
ICS-Fluticasone Propionate | Lapperre 2009^132^ Fair | IG1: fluticasone propionate (500 μg/twice a day) for first 6 months and then placebo for 24 months IG2: fluticasone propionate (500 μg/twice a day) for 30 months CG: Placebo | IG2 | 22 | 30 months | NR | IG1 vs. CG: NR IG2 vs. CG: change in MRC dyspnea score compared to CG during months 7 to 24: −0.2 points/year (95% CI, −0.3 to −0.06); p=0.003 | NR | IG1 vs. CG: NR IG2 vs. CG: change in SGRQ activity score compared to CG during months 7 to 24: −3.1 points/year (95% CI, −5.5 to −0.7); p=0.012 | NR | NR
ICS-Fluticasone Propionate | Lapperre 2009^132^ Fair | IG1: fluticasone propionate (500 μg/twice a day) for first 6 months and then placebo for 24 months IG2: fluticasone propionate (500 μg/twice a day) for 30 months CG: Placebo | CG | 20 | 30 months | NR | IG1 vs. CG: NR IG2 vs. CG: change in MRC dyspnea score compared to CG during months 7 to 24: −0.2 points/year (95% CI, −0.3 to −0.06); p=0.003 | NR | IG1 vs. CG: NR IG2 vs. CG: change in SGRQ activity score compared to CG during months 7 to 24: −3.1 points/year (95% CI, −5.5 to −0.7); p=0.012 | NR | NR
ICS-Mometasone Furoate | Calverley, 2008^133^ Fair | IG1: mometasone furoate (800 μg/day) IG2: mometasone furoate (400 μg/twice a day) CG1: Placebo | IG1 | NA | 12 months | NR | NR | NR | NR | NR | NR
ICS-Mometasone Furoate | Calverley, 2008^133^ Fair | IG1: mometasone furoate (800 μg/day) IG2: mometasone furoate (400 μg/twice a day) CG1: Placebo | IG2 | NA | 12 months | NR | NR | NR | NR | NR | NR
ICS-Mometasone Furoate | Calverley, 2008^133^ Fair | IG1: mometasone furoate (800 μg/day) IG2: mometasone furoate (400 μg/twice a day) CG1: Placebo | CG | NA | 12 months | NR | NR | NR | NR | NR | NR
ICS-Triamcinolone Acetonide | Lung Health Study II, 2000^134^ Fair | IG: Triamcinolone acetoneide) 6 inhalations (100 μg/inhalation) twice a day, total dose of 1200 μg/day CG: Placebo | IG | NR (559 randomized) | 36 months | Highest dyspnea level, %: No dyspnea, %: 68.2 Dyspnea walking up a slight hill or hurrying, %: 20.8 Walks more slowly than similarly aged people, %: 4.4 More severe dyspnea, %: 6.6 | Highest dyspnea level: p=0.02 | NR | NR | NR | NR
ICS-Triamcinolone Acetonide | Lung Health Study II, 2000^134^ Fair | IG: Triamcinolone acetoneide) 6 inhalations (100 μg/inhalation) twice a day, total dose of 1200 μg/day CG: Placebo | CG | NR (557 randomized) | 36 months | Highest dyspnea level, %: No dyspnea, %: 61.5 Dyspnea walking up a slight hill or hurrying, %: 22.7 Walks more slowly than similarly aged people, %: 6.7 More severe dyspnea, %: 9.1 | Highest dyspnea level: p=0.02 | NR | NR | NR | NR

Abbreviations: BL = baseline; CI = confidence interval; CG = control group; EUROSCOP = European Respiratory Society study on Chronic Obstructive Pulmonary Disease; HrQOL = health-related quality of life; ICS = inhaled corticosteroids; IG = intervention group; MRC = Medical Research Council; N = number; NA = not applicable; NR = not reported; SGRQ = St. George’s Respiratory Questionnaire; TORCH = Towards a Revolution in COPD Health; yr = year.

##### HrQOL

Two fair-quality RCTs (post hoc subanalysis of the TORCH trial and RCT by Lapperre with baseline mean FEV_1_ ≥60%) reported mean HrQOL (measured by SGRQ) change from baseline among patients with mild to moderate COPD (Table 28).126,132 Both trials showed that neither the fluticasone nor the placebo group had changes reaching the threshold for a minimum clinically important difference (≥4 units) over the 30- to 36-month trial periods. The TORCH trial reported changes from baseline in HrQOL in the fluticasone or placebo groups (mean SGRQ change, −2.1 vs. −1.3) that did not meet minimum clinically important difference; neither the treatment or placebo group had a HrQOL mean difference over 3 years meeting the threshold for a minimum clinically important change.126 Conversely, the Lapperre trial reported a statistically significantly greater change in mean SGRQ activity score in the fluticasone group, but changes in each group again did not meet the threshold for a minimum clinically important change (change during months 7 to 24, −3.1 points/year [95% CI, −5.5 to −0.7]; p=0.012).132

##### Exercise Capacity

We found no trials that reported change in exercise capacity among patients with mild to-moderate COPD treated with ICS.

#### Critical Appraisal

Overall, there were few trials evaluating the effectiveness of ICS among patients with mild to moderate COPD. The EUROSCOP trial was the only RCT identified that specifically aimed to recruit patients with mild disease.130 Additionally, one large and one smaller post hoc subanalysis of an RCT (both with limitations) and two RCTs with a mean baseline FEV_1_ of 60 percent or greater provided data for patient-oriented outcomes for patients of interest to this review. Most trials had limitations due to variably defined ITT analyses, high withdrawal rates, and the exclusion of noncompliant patients during run-in periods, which may not reflect clinical practice. The two subanalyses had serious limitations, including the lack of baseline comparability reporting, 133 lack of interaction testing,133 lack of control for confounders,126,133 and post hoc timing (Table 20).126,133

Despite the scant evidence and limitations, overall results seem to indicate a reduction in exacerbations with ICS; however, exacerbations were variably defined, and therefore annual rates of exacerbations varied widely. Results from the one trial in patients with mild to moderate COPD (EUROSCOP) (n=1,175) show a statistical difference in exacerbation rates, but as expected, the annual rates of exacerbations are very low (<0.1 exacerbations/year) in patients with milder COPD severity, so the absolute difference is very small (0.02 exacerbations/year).130

Results for the other patient-centered outcomes were similarly scant. The four trials reporting all-cause mortality suggest that it is rare among patients with moderate COPD (<5%) and that there is no all-cause mortality benefit at up to 54 months of followup. Dyspnea scores come from two RCTs of all stages—one not clinically meaningful and one uncertain if clinically meaningful—with overall evidence too limited to make any firm conclusions about the impact of ICS treatment on dyspnea. HrQOL was only reported in one trial with a baseline FEV_1_ of 60 percent or greater and one subanalysis, with both showing that neither the ICS or placebo group met the threshold for a minimum clinically important change over 30 to 36 months. More evidence is needed, however, to fully evaluate the impact of ICS on HrQOL.

## KQ 8 What Are the Adverse Effects of COPD Treatment in Patients With Mild to Moderate COPD?

We searched for treatment harms literature for all of the following COPD drug classes or combinations of any of the following: LABAs, long-acting anticholinergics, and ICS. There were no RCTs evaluating the harms of treatment among a screen-detected COPD population. The evidence on treatment harms in patients with mild to moderate disease is limited to the available trials including patients with milder stages of COPD and to subanalyses of larger treatment trials that report results by disease stage. Overall, there were fewer than five trials reporting harms for any individual medication class, limiting the ability to make firm conclusions regarding the risk of treating patients with early disease.130–134 In addition to evaluating the treatment harms reported in the RCTs included for KQ 7, we evaluated the harms reported by 3 percent or more of the study population on FDA drug labels for the considered drug classes, which ranged from dry mouth and coughing to vomiting and pneumonia (Appendix E).

### LABAs

#### Summary of Findings

One treatment effectiveness RCT126 and one post hoc analysis of pooled trial data by Decramer125 provided data on harms associated with treating mild to moderate COPD patients with LABAs (Table 29). Details regarding the study characteristics of these RCTs have been discussed previously (see KQ 7). Results were scantily reported, with only the subanalysis of mild to moderate COPD patients in the TORCH trial reporting reduced rates of withdrawal and pneumonia in the salmeterol group; both analyses reported somewhat mixed results, but overall there were few differences between treated and untreated groups for a variety of individual adverse events.

Table 29 Withdrawals and Adverse Events Reported in Treatment Efficacy RCTs: LABAs

Drug Class | Study, Year Quality | Treatment Comparison | Study Group | N Analyzed | Followup | Withdrawals | IG vs. CG | Adverse Events | IG vs. CG
LABA-Formoterol | Decramer, 2013^125^ Fair | IG: formoterol (12 μg/twice a day) CG: Placebo | IG | 309 | 6 months | NR | NR | Any adverse event: 57.9% COPD worsening: 15.2% Nasopharyngitis: 8.7% Upper RTI: 2.6% Cough: 4.2% | NR
LABA-Formoterol | Decramer, 2013^125^ Fair | IG: formoterol (12 μg/twice a day) CG: Placebo | CG | 675 | 6 months | NR | NR | Any adverse event: 55.9% COPD worsening: 17.8% Nasopharyngitis: 8.2% Upper RTI: 3.3% Cough: 4.3% | NR
LABA-Indacaterol | Decramer, 2013^125^ Fair | IG1: indacaterol (150 μg/day) IG2: indacaterol (300 μg/day) CG: Placebo | IG1 | 448 | 6 months | NR | NR | Any adverse event: 58.9% COPD worsening: 14.5% Nasopharyngitis: 7.8% Upper RTI: 6.5% Cough: 5.6% | NR
LABA-Indacaterol | Decramer, 2013^125^ Fair | IG1: indacaterol (150 μg/day) IG2: indacaterol (300 μg/day) CG: Placebo | IG2 | 496 | 6 months | NR | NR | Any adverse event: 61.3% COPD worsening: 13.9% Nasopharyngitis: 10.1% Upper RTI: 5.0% Cough: 7.3% | NR
LABA-Indacaterol | Decramer, 2013^125^ Fair | IG1: indacaterol (150 μg/day) IG2: indacaterol (300 μg/day) CG: Placebo | CG | 675 | 6 months | NR | NR | Any adverse event: 55.9% COPD worsening: 17.8% Nasopharyngitis: 8.2% Upper RTI: 3.3% Cough: 4.3% | NR
LABA-Salmeterol | Decramer, 2013^125^ Fair | IG: salmeterol (50 μg/twice a day) CG: Placebo | IG | 189 | 6 months | NR | NR | Any adverse event: 45.0% COPD worsening: 14.8% Nasopharyngitis: 10.1% Upper RTI: 0.0% Cough: 2.7% | NR
LABA-Salmeterol | Decramer, 2013^125^ Fair | IG: salmeterol (50 μg/twice a day) CG: Placebo | CG | 675 | 6 months | NR | NR | Any adverse event: 55.9% COPD worsening: 17.8% Nasopharyngitis: 8.2% Upper RTI: 3.3% Cough: 4.3% | NR
LABA-Salmeterol | TORCH Jenkins, 2009^126^ Calverley, 2007^138^ Fair | IG1: salmeterol (50 μg/twice a day) CG: Placebo | IG1 | 531 | 36 months | Withdrawal rate (reasons NR), %: 27.0 | NR | Any adverse event, n (%): 471 (89.0) Serious adverse event, n (%): 174 (33.0) Fatal adverse event, n (%): 29 (5.0) Probability of pneumonia^*^, %: 9.4 Incidence of pneumonia, rate/1000 treatment years: 36 | NR
LABA-Salmeterol | TORCH Jenkins, 2009^126^ Calverley, 2007^138^ Fair | IG1: salmeterol (50 μg/twice a day) CG: Placebo | CG | 543 | 36 months | Withdrawal rate (reasons NR), %: 35.0 | NR | Any adverse event, n (%): 470 (87.0) Serious adverse event, n (%): 197 (36.0) Fatal adverse event, n (%): 37 (7.0) Probability of pneumonia^*^, %: 10.6 Incidence of pneumonia, rate/1000 treatment years: 43 | NR

* Kaplan-Meier probability. When investigating time to first pneumonia, there was no evidence of treatment differences by severity (p=0.402).

Abbreviations: CG = control group; COPD = chronic obstructive pulmonary disease; IG = intervention group; LABA = long-acting β-agonist; N = number; NR = not reported; RCT = randomized, controlled trial; RTI = respiratory tract infection; TORCH = Towards a Revolution in COPD Health.

#### Detailed Results

##### Withdrawal Rates

The subanalysis of the TORCH trial is the only study identified reporting withdrawal rates for mild to moderate COPD patients treated with the LABA salmeterol; however, reasons for withdrawal were not indicated (Table 29).126 Withdrawal rates were greater in the control group (35.0%) than in the treatment group (27.0%), although statistical testing was not provided.

##### Composite and Individual Adverse Events

The Decramer post hoc analysis of data pooled from three unique treatment RCTs reported adverse event rates from four separate LABA arms: formoterol (12 μg/twice a day), salmeterol (50 μg/twice a day), and indacaterol (150 and 300 μg/day).125 Overall, adverse events were mostly similar across each of the LABA intervention groups and the placebo group (Table 29). The difference in incidence of any adverse event between the formoterol and placebo groups was similar (57.9% vs. 55.9%; no statistical testing provided). Additionally, the incidence of nasopharyngitis, upper respiratory tract infections, and cough were comparable in the formoterol and placebo groups (8.7% vs. 8.2%, 2.6% vs. 3.3%, and 4.2 vs. 4.3%, respectively). Decramer reported similar findings between both indacaterol groups (150 and 300 μg/day) and the placebo group (58.9% vs. 61.3% vs. 55.9%; no statistical testing provided). Additionally, the incidence of nasopharyngitis was similar between the indacaterol and placebo groups; however, upper respiratory tract infections and cough were slightly more common in the treatment groups, but no statistical testing was done (6.5% vs. 5.0% vs. 3.3% and 5.6% vs. 7.3% vs. 4.3%, respectively). Rates of any adverse event were higher in the placebo group (55.9%) than in the salmeterol group (45.0%); however, rates of nasopharyngitis, upper respiratory tract infections, and cough were mixed (Table 29).

The subanalysis of the TORCH trial reported the incidence of any adverse event, serious adverse events, and fatal adverse events, showing mixed results between salmeterol and placebo groups (any adverse event, 89.0% vs 87.0%; serious adverse event, 33.0% vs 36.0%; fatal adverse event, 5.0 % vs. 7.0%; no statistical testing provided) (Table 29).126 The treatment association of adverse events was not reported or commented on by study authors. Common adverse events (incidence of ≥3% of study population) reported on FDA labels were generally mild and ranged from cough and headaches to chest pain and vomiting (Appendix E).

##### Pneumonia

Only the subanalysis of mild to moderate COPD of the TORCH trial reported the incidence of pneumonia and the Kaplan-Meier probability of pneumonia in the salmeterol and placebo groups (Table 29).126 Results showed a numerically higher probability of developing pneumonia in the control group than in the treatment group (10.6% vs. 9.4%; no statistical testing provided). Additionally, there was a higher incidence rate of pneumonia in the control group (43 per 1,000 treatment-years) than in the treatment group (36 per 1,000 treatment-years). Overall, there was no evidence of treatment differences by severity of COPD (p=0.402).126

### ICS-LABA Combination

#### Summary of Findings

Two treatment effectiveness RCTs provided data on harms associated with treating mild to moderate COPD patients with the combination of LABAs and ICS (Table 30).126,132 Details regarding the study characteristics of these RCTs have been discussed previously (see KQ 7). Withdrawal rates appeared to be mixed, with the subanalysis of the TORCH trial reporting lower rates of withdrawal in the salmeterol/fluticasone group than in the placebo group, and the Lapperre trial reporting similar rates of withdrawal between treatment groups. Only the subanalysis of the TORCH trial reported on the incidence of composite or individual adverse events, finding relatively similar rates between treated and control groups, except perhaps a higher risk for pneumonia with treatment, in contrast to findings for LABAs in the same study.126 Paucity of data makes robust conclusions challenging.

Table 30 Withdrawals and Adverse Events Reported in Treatment Efficacy RCTs: ICS and LABA Combination Therapy

Drug Class | Study, Year Quality | Treatment Comparison | Study Group | N Analyzed | Followup | Withdrawals | IG vs. CG | Adverse Events | IG vs. CG
ICS/LABA-Salmeterol/Fluticasone Propionate | TORCH Jenkins, 2009^126^ Calverley, 2007^138^ Fair | IG: salmeterol/fluticasone propionate combination (50 μg/500 μg) twice a day CG: Placebo | IG | 565 | 36 Months | Withdrawal rate (reasons NR), %: 27.0 | NR | Any adverse event, n (%): 487 (86.2) Serious adverse event, n (%): 198 (35.0) Fatal adverse event, n (%): 27 (4.8) Probability of pneumonia^*^, %: 15.3 Incidence of pneumonia, rate/1000 treatment years: 56 | NR
ICS/LABA-Salmeterol/Fluticasone Propionate | TORCH Jenkins, 2009^126^ Calverley, 2007^138^ Fair | IG: salmeterol/fluticasone propionate combination (50 μg/500 μg) twice a day CG: Placebo | CG | 543 | 36 Months | Withdrawal rate (reasons NR), %: 35.0 | NR | Any adverse event, n (%): 470 (86.6) Serious adverse event, n (%): 197 (36.0) Fatal adverse event, n (%): 37 (6.8) Probability of pneumonia^*^, %: 10.6 Incidence of pneumonia, rate/1000 treatment years: 43 | NR
ICS/LABA-Salmeterol/Fluticasone Propionate | Lapperre 2009^132^ Fair | IG: fluticasone propionate (500 μg/twice a day) plus salmeterol (50 μg/twice a day) for 30 months CG: Placebo | IG | 21 | 30 Months | 4 (1 in months 0 to 6, 3 in months 7 to 30), reason NR | NA | NR | NA
ICS/LABA-Salmeterol/Fluticasone Propionate | Lapperre 2009^132^ Fair | IG: fluticasone propionate (500 μg/twice a day) plus salmeterol (50 μg/twice a day) for 30 months CG: Placebo | CG | 20 | 30 Months | 4 (3 in months 0 to 6, 1 in months 7 to 30), reason NR | NA | NR | NA

* Kaplan-Meier probability. When investigating time to first pneumonia, there was no evidence of treatment differences by severity (p=0.402).

Abbreviations: CG = control group; ICS = inhaled corticosteroids; IG = intervention group; LABA = long-acting β-agonist; N = number; NR = not reported; RCT = randomized, controlled trial; TORCH = Towards a Revolution in COPD Health.

#### Detailed Results

##### Withdrawal Rates

Both the Lapperre trial and the subanalysis of the TORCH trial reported rates of withdrawals; however, neither analysis provides reasons for withdrawals (Table 30).126,132 The subanalysis of the TORCH trial reported lower rates of withdrawal in the fluticasone/salmeterol combination group compared to the placebo group (27.0% vs. 35.0%; no statistical testing provided).126 Conversely, the Lapperre trial, an RCT with a mean baseline FEV_1_ of 63.0 percent of predicted, reported similar numbers of withdrawals between the fluticasone/salmeterol and placebo groups (19.0% vs. 20.0%; no statistical testing provided).132

##### Composite and Individual Adverse Events

Only the subanalysis of mild to moderate COPD of the TORCH trial reported the incidence of composite adverse events (Table 30).126 Results of the incidence of any adverse event, serious adverse events, and fatal adverse events were similar between the fluticasone/salmeterol and placebo groups (86.2% vs. 86.6%, 35.0% vs. 36.0%, and 4.8% vs. 6.8%, respectively; no statistical testing provided). The treatment association of adverse events was not reported or commented on by study authors. Common adverse events (incidence of ≥3% of study population) reported on FDA labels were generally mild and ranged from throat irritation and headaches to pneumonia and dizziness (Appendix E).

##### Pneumonia

Only the subanalysis of mild to moderate COPD of the TORCH trial reported the incidence of pneumonia and the Kaplan-Meier probability of pneumonia in the salmeterol/fluticasone and placebo groups (Table 30).126 Results showed a higher Kaplan-Meier probability of developing pneumonia in the treatment group than in the control group (15.3% vs. 10.6%; no statistical testing provided). Additionally, there was a higher incidence rate of pneumonia in the treatment group (56 cases per 1,000 treatment-years) than in the control group (43 cases per 1,000 treatment-years). Overall, there was no evidence of treatment differences by severity of COPD (p=0.402).126

### Long-Acting Anticholinergics/LAMAs (Tiotropium)

#### Summary of Findings

Two treatment effectiveness RCTs127,139 and one post hoc analysis of pooled study data125 provided data on harms associated with treating mild to moderate COPD patients with the LAMA tiotropium (Table 31). Details regarding the study characteristics of these RCTs have been discussed previously (see KQ 7). Overall reporting of adverse events was scant, with a single trial127 reporting very similar withdrawal rates with and without tiotropium, and two studies reporting incidence of a mix of adverse events, with both suggesting up to a 10 percent increase in any adverse event in the tiotropium group, but no difference in serious adverse events.

Table 31 Withdrawals and Adverse Events Reported in Treatment Efficacy RCTs: Tiotropium

Drug Class | Study, Year Quality | Treatment Comparison | Study Group | N Analyzed | Followup | Withdrawals | IG vs. CG | Adverse Events | IG vs. CG
Long-Acting Anticholinergic (Tiotropium) | UPLIFT Decramer 2009^127^ Tashkin 2012^140^ Tashkin 2008^141^ | IG: tiotropium bromide (18 μg/day) CG: Placebo | IG | Stage II: 1384 FEV_1_ ≥60%: 632 | 48 months | Stage II: 30.6% (424/1384) (17% adverse event, 8.4% consent withdrawn, 1.4% protocol noncompliance, 2.7% lost to followup, 1.1% other)^†^ FEV_1_ ≥60%: 30.4% (192/632) (15.5% adverse event, 9.5% consent withdrawn, 2.2% protocol noncompliance, 2.0% lost to followup, 1.1% other) † | Stage II: Rate of discontinuation: p=0.024 | Stage II: Adverse events leading to discontinuation: 17.0% (235/1384)^†^ FEV_1_ ≥60%: Adverse events leading to discontinuation: 15.5% (98/632)^†^ | NR
Long-Acting Anticholinergic (Tiotropium) | UPLIFT Decramer 2009^127^ Tashkin 2012^140^ Tashkin 2008^141^ | IG: tiotropium bromide (18 μg/day) CG: Placebo | CG | Stage II: 1355 FEV_1_ ≥60%: 578 | 48 months | Stage II: 34.7% (470/1355) (17.8% adverse event, 11.7% consent withdrawn, 2.3% protocol noncompliance, 2.0% lost to followup, 1.0% other) † FEV_1_ ≥60%: 31.5% (182/578) (15.2% adverse event, 11.1% consent withdrawn, 1.7% protocol noncompliance, 2.2% lost to followup, 1.2% other) † | Stage II: Rate of discontinuation: p=0.024 | Stage II: Adverse events leading to discontinuation: 17.8% (241/1355)^†^ FEV_1_ ≥60%: Adverse events leading to discontinuation: 15.2% (88/578)^†^ | NR
Long-Acting Anticholinergic (Tiotropium) | Decramer, 2013^125^ Fair | IG: tiotropium bromide (18 μg/day) CG: Placebo | IG | 236 | 6 months | NR | NR | Any adverse event: 67.0% COPD worsening: 13.1% Nasopharyngitis: 10.2% Upper RTI: 5.5% Cough: 5.0% | NR
Long-Acting Anticholinergic (Tiotropium) | Decramer, 2013^125^ Fair | IG: tiotropium bromide (18 μg/day) CG: Placebo | CG | 675 | 6 months | NR | NR | Any adverse event: 55.9% COPD worsening: 17.8% Nasopharyngitis: 8.2% Upper RTI: 3.3% Cough: 4.3% | NR
Long-Acting Anticholinergic (Tiotropium) | Niewoehner, 2005^128^ Good | IG: tiotropium bromide (18 μg/day) CG: Placebo | IG | NR | 6 months | NR | NA | NR | NA
Long-Acting Anticholinergic (Tiotropium) | Niewoehner, 2005^128^ Good | IG: tiotropium bromide (18 μg/day) CG: Placebo | CG | NR | 6 months | NR | NA | NR | NA
Long-Acting Anticholinergic (Tiotropium) | Tonnel, 2008^129^ Fair | IG: tiotropium bromide (18 μg/day) CG: Placebo | IG | 105 | 9 months | NR | NA | NR | NA
Long-Acting Anticholinergic (Tiotropium) | Tonnel, 2008^129^ Fair | IG: tiotropium bromide (18 μg/day) CG: Placebo | CG | 93 | 9 months | NR | NA | NR | NA
Long-Acting Anticholinergic (Tiotropium) | Troosters, 2014^139^ Troosters, 2011^170^ Fair | IG: tiotropium bromide (18 μg/day) CG: Placebo | IG | 221 | 6 months | NR | NA | Serious adverse events, n (%)^*^: Hip fracture: 1 (0.5) Abdominal abscess: 1 (0.5) Tendon disorder: 1 (0.5) Cerebral artery occlusion: 1 (0.5) Cerebral infarction: 1 (0.5) Joint abscess: 1 (0.5) Bladder transitional cell carcinoma: 1 (0.5) Pancreatic cyst: 1 (0.5) Streptococcal infection: 1 (0.5) | NR
Long-Acting Anticholinergic (Tiotropium) | Troosters, 2014^139^ Troosters, 2011^170^ Fair | IG: tiotropium bromide (18 μg/day) CG: Placebo | CG | 205 | 6 months | NR | NA | Serious adverse events, n (%)^*^: Renal failure: 2 (1.0) Cardiac failure: 1 (0.5) MI: 1 (0.5) Acute respiratory failure: 1 (0.5) Angina pectoris: 1 (0.5) Rectal polyp: 1 (0.5) Acute pancreatitis: 1 (0.5) Coronary disease: 1 (0.5) | NR

* All serious adverse events were considered unrelated to the study drug and all patients recovered.

† Calculated.

Abbreviations: CG = control group; COPD = chronic obstructive pulmonary disease; FEV_1_= forced expiratory volume in 1 second; IG = intervention group; N = number; NA = not applicable; NR = not reported; RCT = randomized, controlled trial; RTI = respiratory tract infection; UPLIFT = Understanding Potential Long-term Impacts on Function with Tiotropium.

#### Detailed Results

##### Withdrawal Rates

Only the two subanalyses of the UPLIFT trial reported withdrawals due to adverse events among patients with moderate COPD randomized to tiotropium versus placebo (Table 31).127,140 Reported results show a similar risk of adverse events leading to discontinuation in both the subanalysis of participants with moderate COPD127 and the narrower subanalysis of participants with a baseline FEV_1_ of 60 percent of predicted or greater140 (17.0% vs. 17.8% and 15.5% vs. 15.2%, respectively; no statistical testing provided).

##### Composite and Individual Adverse Events

One RCT by Troosters and the post hoc analysis of pooled study data by Decramer reported the incidence of composite adverse events or individual adverse events among patients with mild to moderate COPD, showing slightly higher rates in the tiotropium group compared to the placebo group (Table 31).125,139 The post hoc pooled analysis reported higher rates of any adverse event in the tiotropium group compared to the placebo group; however, no statistical testing was performed (67% vs. 55.9%).125 Both studies reported individual adverse events experienced by study participants. Trooster’s trial reported serious adverse events occurring in 1 percent or greater of the population, which included hip fractures, abdominal abscesses, tendon disorders, cerebral artery occlusions, cerebral infarctions, joint abscesses, bladder cancer, pancreatic cysts, and strep infection.139 Overall, individual rates of serious events were rare and were similar between treatment groups (4.1% vs. 4.4%; statistical testing not provided). Additionally, the post hoc analysis of pooled trial data by Decramer reported slightly higher rates of adverse events among patients treated with tiotropium; however, no statistical testing was provided.125 Specifically, the incidence of nasopharyngitis was higher in the tiotropium group compared to the placebo group (10.2% vs. 8.2%), as was the incidence of upper respiratory tract infections (5.5% vs. 3.3%) and cough (5.0% vs. 4.3%). Common adverse events (incidence of ≥3% of study population) reported on FDA labels were generally mild and ranged from dry mouth and cough to urinary tract and respiratory infections (Appendix E).

##### Pneumonia

We found no studies of long-acting anticholinergics that reported the incidence of pneumonia among patients with mild to moderate COPD.

### ICS

#### Summary of Findings

Six RCTs reported treatment harms associated with ICS among patients with mild to moderate COPD (Table 32).126,130–134 Details regarding the study characteristics of these RCTs have been discussed previously (see KQ 7). Overall, withdrawal rates were similar between treatment groups in the four trials that reported these data. Results of the composite outcome of any adverse event or serious adverse events were mixed, but generally showed few differences between treated and untreated groups. Data on pneumonia, bone density, and fractures were sparse and mixed. One post hoc subanalysis reported more ischemic cardiac events in the placebo group, although these results should be interpreted with caution due to study methods.

Table 32 Withdrawals and Adverse Events Reported in Treatment Efficacy RCTs: ICS

Drug Class | Study, Year Quality | Treatment Comparison | Study Group | N Analyzed | Followup | Withdrawals | IG vs. CG | Adverse Events | IG vs. CG
ICS-Budesonide | EUROSCOP Lofdahl 2007^142^ Pauwels 1999^130^ Fair | IG: budesonide (800 μg/day) CG: Placebo | IG | 593 | 36 months | Withdrawal due to adverse events, n: 70 (11.0%) | p=0.51 | Serious adverse events, n (%): Total: 177 (29.8) Neoplasm: 21 (3.5) CV disorder: 28 (4.7) GI disorder: 17 (2.9) Respiratory disorder: 17 (2.9) Musculoskeletal disorder: 14 (2.4) Ischemic cardiac event^§^: 3.0% New lumbar fractures: 5 (NR)^*^ | Serious adverse event: p=0.37 New lumbar fractures: p=0.50 Ischemic cardiac event: p=0.048^§^
ICS-Budesonide | EUROSCOP Lofdahl 2007^142^ Pauwels 1999^130^ Fair | IG: budesonide (800 μg/day) CG: Placebo | CG | 582 | 36 months | Withdrawal due to adverse events, n: 62 (10.6%) | p=0.51 | Serious adverse events, n (%): Total: 161 (27.7) Neoplasm: 25 (4.3) CV disorder: 32 (5.5) GI disorder: 15 (2.6) Respiratory disorder: 14 (2.4) Musculoskeletal disorder: 16 (2.7) Ischemic cardiac event^§^: 5.3% New lumbar fractures: 3 (NR)^*^ | Serious adverse event: p=0.37 New lumbar fractures: p=0.50 Ischemic cardiac event: p=0.048^§^
ICS-Budesonide | Vestbo, 1999^131^ Fair | IG: budesonide 1200 μg/day (800 μg morning, 400 μg evening) for 6 months; 400 μg/twice a day for 30 months CG: Placebo | IG | 145 | 36 months | 36 (16 adverse events, 3 disease deterioration, 17 other) | NR | Serious adverse events: 14 events in 10 patients (9.6%)^†^ Worsening of COPD: 36 (24.8%) Pneumonia: 16 (11.0%) Viral infection: 34 (23.4%) | Adverse events: p=0.001^†^
ICS-Budesonide | Vestbo, 1999^131^ Fair | IG: budesonide 1200 μg/day (800 μg morning, 400 μg evening) for 6 months; 400 μg/twice a day for 30 months CG: Placebo | CG | 145 | 36 months | 51 (17 adverse events, 7 disease deterioration, 27 other) | NR | Serious adverse events: 41 events in 34 patients (28.3%)^†^ Worsening of COPD: 34 (23.4%) Pneumonia: 24 (16.6%) Viral infection: 34 (23.4%) | Adverse events: p=0.001^†^
ICS-Fluticasone Propionate | TORCH Jenkins, 2009^126^ Calverley, 2007^138^ Fair | IG: fluticasone propionate (500 μg/twice a day) CG: Placebo | IG | 544 | 36 months | Withdrawal rate (reasons NR), %: 32.0 | NR | Any adverse event, n (%): 481 (88.4) Serious adverse event, n (%): 169 (31.1) Fatal adverse event, n (%): 38 (6.9) Probability of pneumonia^‡^, %: 12.8 Incidence of pneumonia, rate/1000 treatment years: 58 | NR
ICS-Fluticasone Propionate | TORCH Jenkins, 2009^126^ Calverley, 2007^138^ Fair | IG: fluticasone propionate (500 μg/twice a day) CG: Placebo | CG | 543 | 36 months | Withdrawal rate (reasons NR), %: 35.0 | NR | Any adverse event, n (%): 470 (86.6) Serious adverse event, n (%): 197 (36.2) Fatal adverse event, n (%): 37 (6.8) Probability of pneumonia^‡^, %: 10.6 Incidence of pneumonia, rate/1000 treatment years: 43 | NR
ICS-Fluticasone Propionate | Lapperre 2009^132^ Fair | IG1: fluticasone propionate (500 μg/twice a day) for the first 6 months and then placebo for 24 months IG2: fluticasone propionate (500 μg/twice a day) for 30 months CG: Placebo | IG1 | 23 | 30 months | 3 (13.0%) (2 in months 0 to 6, 1 in months 7 to 30), reason NR | NR | NR | NR
ICS-Fluticasone Propionate | Lapperre 2009^132^ Fair | IG1: fluticasone propionate (500 μg/twice a day) for the first 6 months and then placebo for 24 months IG2: fluticasone propionate (500 μg/twice a day) for 30 months CG: Placebo | IG2 | 22 | 30 months | 4 (18.1%) (0 in months 0 to 6, 4 in months 7 to 30), reason NR | NR | NR | NR
ICS-Fluticasone Propionate | Lapperre 2009^132^ Fair | IG1: fluticasone propionate (500 μg/twice a day) for the first 6 months and then placebo for 24 months IG2: fluticasone propionate (500 μg/twice a day) for 30 months CG: Placebo | CG | 20 | 30 months | 4 (20.0%) (3 in months 0 to 6, 1 in months 7 to 30), reason NR | NR | NR | NR
ICS-Mometasone | Calverley, 2008^133^ Fair | IG1: mometasone furoate (800 μg/day) IG2: mometasone furoate (400 μg/twice a day) CG: Placebo | IG1 | NA | 12 months | NR | NR | NR | NR
ICS-Mometasone | Calverley, 2008^133^ Fair | IG1: mometasone furoate (800 μg/day) IG2: mometasone furoate (400 μg/twice a day) CG: Placebo | IG2 | NA | 12 months | NR | NR | NR | NR
ICS-Mometasone | Calverley, 2008^133^ Fair | IG1: mometasone furoate (800 μg/day) IG2: mometasone furoate (400 μg/twice a day) CG: Placebo | CG | NA | 12 months | NR | NR | NR | NR
ICS-Triamcinolone Acetonide | Lung Health Study II, 2000^134^ Fair | IG: Triamcinolone acetoneide) 6 inhalations (100 μg/inhalation) twice a day, total dose of 1200 μg/day CG: Placebo inhaler | IG | 158 (lumbar spine); 176 (femoral neck) NR (other events) (559 randomized) | 36 months | NR | NA | Bone mineral density (g/cm^2^), mean (SE): Lumbar spine: 0.985 (0.013) Lumbar spine % change from BL: −0.35 (0.33) Femoral neck: 0.747 (0.010) Femoral neck % change from BL: −2.00 (0.35) | Bone mineral density (g/cm^2^): Lumbar spine: p=0.89 Lumbar spine % change from BL: p=0.007 Femoral neck: p=0.73 Femoral neck % change from BL: p<0.001
ICS-Triamcinolone Acetonide | Lung Health Study II, 2000^134^ Fair | IG: Triamcinolone acetoneide) 6 inhalations (100 μg/inhalation) twice a day, total dose of 1200 μg/day CG: Placebo inhaler | CG | 170 (lumbar spine); 183 (femoral neck) NR (other events) (557 randomized) | 36 months | NR | NA | Bone mineral density (g/cm^2^), mean (SE): Lumbar spine: 0.988 (0.014) Lumbar spine % change from BL: 0.98 (0.36) Femoral neck: 0.752 (0.010) Femoral neck % change from BL: −0.22 (0.32) | Bone mineral density (g/cm^2^): Lumbar spine: p=0.89 Lumbar spine % change from BL: p=0.007 Femoral neck: p=0.73 Femoral neck % change from BL: p<0.001

* Radiographs only on a subset of patients (653); N not given for each group.

† None of the serious adverse events were believed to be related to treatment or treatment failure.

‡ Kaplan-Meier probability. When investigating time to first pneumonia, there was no evidence of treatment differences by severity (p=0.402).

§ Event only collected if spontaneously reported by a primary care physician.

Abbreviations: BL = baseline; CG = control group; COPD = chronic obstructive pulmonary disease; CV = cardiovascular; EUROSCOP = European Respiratory Society study on Chronic Obstructive Pulmonary Disease; GI = gastrointestinal; IG = intervention group; N = number; NR = not reported; RCT = randomized, controlled trial; SE = standard error; TORCH = Towards a Revolution in COPD Health.

#### Detailed Results

##### Withdrawals

Four of the six ICS effectiveness trials reported withdrawals,126,130–132 with two of these trials specifically reporting withdrawals due to adverse events (Table 32).130,131 The EUROSCOP trial, which recruited only patients with mild to moderate COPD who were naïve to maintenance therapy, reported that withdrawals due to adverse events were similar in the budesonide and placebo groups (11.8% vs. 10.6%; p=0.51).130 Likewise, the Vestbo trial reported similar withdrawals due to adverse in the budesonide and placebo groups (11.0% vs. 11.7%; statistical testing not reported).131 The subanalysis of mild to moderate COPD patients from the TORCH trial reported high withdrawal rates for any reason in both the fluticasone and placebo groups, without specifying reason for withdrawal (32.0% vs. 35.0%).126 Additionally, the Lapperre trial reported similar withdrawal rates, without reason, in both the fluticasone and placebo groups (13.0% vs. 18.1% vs. 20.0%).132

##### Composite and Individual Adverse Events

Three treatment effectiveness RCTs reported composite outcomes of any adverse event or serious adverse events in the ICS group compared to the placebo group (Table 32).126,130,131 The EUROSCOP trial reported no differences in serious adverse events between the budesonide and placebo groups (29.8% vs. 27.7%; p=0.37).130 Conversely, the Vestbo trial reported a significantly higher rate of serious adverse events in the placebo group compared to the budesonide group (9.7% vs. 28.3%; p=0.001); however, none of the serious adverse events were thought to be related to treatment or treatment failure.131 The TORCH trial subanalysis reported similar rates of any adverse event, serious adverse events, and fatal adverse events in both the fluticasone and placebo groups, without statistical testing (88.4% vs. 86.6%, 31.1% vs. 36.2%, and 6.9% vs. 6.8%, respectively).126 Similarly, the LHS II reported no statistically significant difference in thrush, easy bruising, cataracts, diabetes, or myopathy between the triamcinalone and placebo groups, but did report more moderate or severe mouth irritation in the triamcinalone group compared to the placebo group (2.3% vs. 1.1%; p=0.02).134 Common adverse events (incidence of ≥3% of study population) reported on FDA labels were generally mild and ranged from headache and rash to vomiting and respiratory infection (Appendix E).

##### Pneumonia

Two treatment effectiveness RCTs reported the rates of pneumonia among patients with mild to moderate COPD as an adverse event, but did not provide any statistical significance testing (Table 32).126,131 The subanalysis of the TORCH trial reported a Kaplan-Meier probability of developing pneumonia of 12.8 percent in the fluticasone group and 10.6 percent in the placebo group; however, when the authors reexamined Kaplan-Meier probability and time to first pneumonia, there was no evidence of treatment differences by COPD severity (p=0.402).126 Additionally, there was a higher incidence rate of pneumonia in the treatment group (58 cases per 1,000 treatment-years) than in the control group (43 cases per 1,000 treatment-years). Conversely, the Vestbo trial reported a higher incidence of pneumonia in the placebo group than in the budesonide group (11.0% vs. 16.6%).131

##### Additional Adverse Events

One treatment effectiveness RCT in patients with mild to moderate COPD reported fractures130 and one RCT with a mean postbronchodilator baseline FEV_1_ of 67.8 percent reported bone mineral change as an intermediate measure of harm (Table 32).134 The EUROSCOP trial reported no difference in new lumbar fractures, based on radiography, for a subset of the population in the budesonide group compared to the placebo group (5 vs. 3 new lumbar fractures for a subset of 653 patients with x-rays; p=0.50). The LHS II reported similar bone mineral density at the femoral neck for the triamcinalone and placebo groups at all timepoints; however, the percent bone mineral change from baseline to 36 months was statistically significantly different between treated and control groups, although it is unclear if this change is clinically meaningful (−2.00% vs. −0.22%; p<0.001).134

One post hoc subanalysis by Lofdahl of the EUROSCOP trial reported cardiac events experienced by participants during followup (Table 32).142 Results found that there were fewer ischemic cardiac events in the budesonide group compared to the placebo group; however, caution should be taken in interpreting this post hoc analysis, as the ascertainment of cardiac events was collected only if spontaneously reported by a primary care physician (3.0% vs. 5.3%; p=0.048).