# Methods

## Scope and Purpose

This systematic review addresses the benefits and harms of screening for COPD using spirometry, the diagnostic accuracy of associated screening instruments, the effect of spirometric screening on uptake of targeted preventive services, and the effectiveness and associated harms of treating mild to moderate COPD. The USPSTF will use this review to update its 2008 recommendation on this topic.96 This review included all trials from the previous review that met current inclusion and exclusion criteria as well as newly identified studies.

## Key Questions and Analytic Framework

Using the USPSTF’s methods,97 we developed an analytic framework (Figure 1) and eight Key Questions (KQs) in consultation with the Agency for Healthcare Research and Quality (AHRQ) Medical Officer and members of the USPSTF. These KQs were adapted from questions addressed in the previous review.98 The KQs related to the diagnostic accuracy of prescreening questionnaires and pulmonary function tests are unique to this review.

Figure 1 Analytic Framework

Abbreviations: COPD = chronic obstructive pulmonary disease; HRQoL = health-related quality of life.

The figure is an analytic framework that depicts the eight Key Questions of the evidence review. In general, it illustrates the overarching questions: whether screening asymptomatic adults age 40 years and older for COPD with prescreening bronchodilator screening spirometry leads to improved health outcomes or potential harms. The analytic framework also illustrates Key Questions related to screening modalities used to identify adults who are more likely to test positive on screening and the test performance of prebronchodilator screening spirometry in predicting COPD diagnostic confirmation. In addition, the analytic framework outlines intermediate Key Questions investigating if identifying asymptomatic adults with fixed airway obstruction results in improved delivery of targeted preventive services, specifically smoking cessation interventions and/or influenza or pneumococcal immunizations, and the potential related harms. Also, if treating screen-identified patients with asymptomatic COPD improves health outcomes and what harms are associated with COPD treatment in this population.

### KQs

1. Does screening for COPD with prebronchodilator screening spirometry in asymptomatic adults age 40 years and older improve HrQOL or reduce morbidity or mortality?
  a. Does the effect of screening among asymptomatic adults vary across strategy (i.e., selective subgroups [age, presence of certain comorbid conditions, sex, race/ethnicity, smoking history, or others] vs. general population)?
2. Do prescreening questionnaires reliably identify high-risk asymptomatic adults who are more likely to test positive on screening for COPD?
3. What is the test performance of screening pulmonary function tests (e.g., prebronchodilator screening spirometry, peak flow [PEF] meter) in predicting diagnosis of COPD in asymptomatic adults, based on confirmation with postbronchodilator spirometry to identify fixed airflow obstruction?
4. What are the adverse effects of screening for COPD with prescreening questionnaires or screening pulmonary function tests?
5. Does identifying asymptomatic adults with fixed airflow obstruction through screening improve the delivery and uptake of targeted preventive services?
  a. Does screening for COPD increase smoking cessation rates among asymptomatic adults compared to usual care?
  b. Does screening for COPD increase relevant immunization rates among asymptomatic adults compared to usual care?
6. What are the adverse effects of COPD screening, including the impact of targeted preventive services in this population (e.g., false reassurance for screen-negative smokers)?
7. Does treatment of asymptomatic adults identified with mild to moderate COPD through screening improve HrQOL or reduce morbidity or mortality?
8. What are the adverse effects of COPD treatment in this population?

## Data Sources and Searches

In addition to considering all studies from the previous review for inclusion in the current review, we performed a comprehensive search of MEDLINE, PubMed Publisher-Supplied Records, the Cumulative Index to Nursing and Allied Health Literature, and the Cochrane Collaboration Registry of Controlled Trials.

For evidence related to the effect of screening on health outcomes literature, we searched for studies published between January 2005 and January 31, 2015, building on the literature published in the previous review. For evidence related to the use of prescreening questionnaires and pulmonary function tests, we searched for studies published between January 2000 and January 31, 2015. The literature related to the use of screening questionnaires and pulmonary function tests are new to this review. Our search on this literature, however, is limited to literature published beginning in the year 2000. This is based on the introduction of the requirement for obstruction to be not fully reversible in the 2001 GOLD guidelines, which introduced the need for postbronchodilator spirometry (our gold standard in the review).99 For evidence related to the effect of spirometry on smoking cessation rates, we searched between January 2012 and January 31, 2015 and built this search on a previously published evidence review on the topic.100 We searched for evidence related to the effect of spirometry on vaccination rates between database inception and January 31, 2015. For evidence related to the treatment of mild to moderate COPD, we searched for evidence published from January 2010 to January 31, 2015. This search was built upon two previous published reviews on COPD treatment.101,102 In the cases where we based our KQs off previously published reviews, we evaluated all of the included studies in the review for inclusion in the current review and bridged forward for new primary literature.

We worked with a medical librarian to develop our search strategies (Appendix A). All searches were limited to articles published in the English language. We managed literature search results using version 12.0 of Reference Manager® (Thomson Reuters, New York, NY), a bibliographic management software database. For a complete summary of our searches by KQ and the associated rationale, please see Table 2.

Table 2 Search Summary and Rationale for Search Dates

Key Question | Search Dates | Rationale
1 | January 2005 – January 31, 2015 | Bridging from previous USPSTF review
2 to 4 | January 2000 – January 31, 2015 | Based on introduction of the requirement for post-bronchodilator diagnostic testing in the GOLD 2001 guidelines
5 and 6 (smoking) | January 2012 – January 31, 2015 | Building off a recently published evidence review100
5 and 6 (immunization) | Database inception – January 31, 2015 | New key question with no previous reviews to build from
7 and 8 | January 2010 – January 31, 2015 | Building on two recently published reviews on COPD treatment101,102

To ensure comprehensiveness of our retrieval strategy, we reviewed the reference lists of included studies and relevant systematic reviews and meta-analyses to identify relevant articles that were published before our search dates or were not identified in our literature searches. We also obtained references from outside experts. We also searched federal agency trial registries for ongoing trials (Appendix B).

## Study Selection

Two reviewers independently reviewed the title and abstract of all identified articles using Abstrackr103 to determine if the study met our inclusion and exclusion criteria for design, population, intervention, and outcomes (Appendix A Table 1). Two reviewers then independently evaluated the full-text article(s) of all potentially relevant studies against the complete inclusion and exclusion criteria. Disagreements in the abstract and/or full-text review were resolved by discussion and consultation with a third reviewer, if necessary. Excluded studies and reasons for exclusion are listed in Appendix C.

We developed an a priori set of criteria for inclusion and exclusion of studies based on criteria from the previous review and our understanding of the literature (Appendix A Table 1). For KQs 1 to 6, we considered studies including asymptomatic adults age 40 years and older (limited to current smokers for KQ 5a). For KQs 7 and 8, we restricted the population further to only include asymptomatic adults age 40 years and older who were also diagnosed (preferably based on screening) with mild (FEV_1_ ≥80% of normal) to moderate (FEV_1_ 50% to 79% of normal) COPD or a mean population FEV_1_ greater than or equal to 60 percent of predicted to approximate a population of mild to moderate COPD. We defined asymptomatic patients as those in one of the following states: those who are free of the disease; those in whom the disease is present but who have physical symptoms that are undetected by the patient or the clinician (e.g., have mild dyspnea that goes unnoticed); or those who have nonspecific symptoms (e.g., sporadic sputum production or cough) that have gone unrecognized as being related to COPD. For KQs 1 to 6, we excluded studies of patients with previously diagnosed COPD or other respiratory conditions (KQ 1 only), patients with identified α_1_-antitrypsin deficiency, and pregnant women. For KQs 7 and 8, we excluded patients diagnosed with severe (FEV_1_ ≥30% to 49% of normal) or very severe (FEV_1_ <30% of normal) COPD, pregnant women, and patients with identified α_1_-antitrypsin deficiency. While the ideal literature related to treatment would focus on screen-detected patients, we recognized that many studies would be population based. As such, we included some proportion of patients with previously diagnosed disease, making the criteria of excluding patients with COPD-related symptoms not pragmatic (e.g., persistent dyspnea, chronic sputum production, and/or cough). Additionally, we looked for risk factor–based prescreening questionnaires for KQ 2, but were not able to locate any such questionnaires. As a result, we included screening questionnaires that used a combination of risk factors and symptom-based questions.

For KQs 1 to 4, we examined studies that used prebronchodilator screening spirometry, screening questionnaires, or risk assessment tools, PEF meters, and confirmatory postbronchodilator spirometry. For KQs 5 and 6, we focused on studies providing pulmonary function testing with the addition of smoking cessation or immunization intervention/counseling. For KQs 7 and 8, we focused on pharmacotherapy interventions appropriate for mild to moderate COPD (including short- and long-acting β-agonists, anticholinergics, ICS, or combinations of these treatments).6 For KQ 7, we required studies to have at least 6 months of followup.

We considered a broad range of outcomes for each KQ, including all-cause mortality and COPD-related morbidity (KQs 1 and 7); test performance, including sensitivity, specificity, and positive/negative predictive values compared to the gold standard of pre- or postbronchodilator screening (KQ 2) or postbronchodilator screening only (KQ 3); and self-reported or biologically validated smoking abstinence or immunization rates (KQ 5). For KQ 7, we did not consider evidence related to disease progression as measured by pulmonary function (i.e., stable FEV_1_). Instead, we focused on more patient-centered outcomes. For the KQs that examined harms of screening (KQs 4 and 6), we considered the false-positive rate, the proportion of diagnoses missed by screening, and adverse events associated with the uptake of targeted preventive services (e.g., false reassurance for screen-negative smokers). For the harms associated with treatment (KQ 8), we included serious adverse events as defined by study authors, as well as individual incidence rates of any adverse events. Additionally, we considered adverse events reported by 3 percent or more of the study population, as reported on the U.S. Food and Drug Administration (FDA) drug labels of included COPD treatments.

For KQs 1, 5, and 7, we limited the study design to randomized, controlled trials (RCTs). For KQs 2 and 3, we limited our studies to diagnostic accuracy studies (including observational/cohort studies). For KQs 4 and 6, we considered RCTs, large screening registry or database observational studies, and cohort studies. When evaluating harms associated with the treatment of COPD (KQ 8), we limited the data to those reported in the included efficacy trials for KQ 7, large screening registries, and systematic reviews, and supplemented the data with information reported by the FDA. For all KQs, we considered all systematic reviews of included study designs. We limited our included studies to those published in English that we rated as good or fair quality using USPSTF quality rating standards.104 We excluded studies that we rated as poor quality and those that did not publish results in English. The outcomes that were reviewed are fully listed in Appendix A Table 1.

## Quality Assessment and Data Abstraction

Two reviewers independently assessed the methodological quality of each study using predefined criteria developed by the USPSTF104 and supplemented with National Institute for Health and Care Excellence methodology checklists for observational studies and the Quality Assessment of Diagnostic Accuracy Studies (QUADAS I and II) tool for diagnostic accuracy (Appendix A Table 2).105–107 Disagreements in quality were resolved by discussion. Each study was given a final quality rating of good, fair, or poor.

Good-quality RCTs had adequate randomization procedures and allocation concealment, blinded outcome assessment, reliable outcome measures, similar groups at baseline (i.e., little to no statistically significant differences between groups in baseline characteristics), low attrition (≥90% of participants had followup data with <10 percentage point difference in loss to followup between groups), used intention-to-treat (ITT) analysis, and reported diagnostic criteria for outcome ascertainment. We rated trials as fair quality if they were unable to meet the majority of the good-quality criteria. We rated trials as poor quality if attrition was greater than 40 percent or differed between groups by 20 percentage points, or if there were any other “fatal” flaws that seriously affected internal validity, as agreed upon by two independent investigators.

We abstracted data from all included studies into standard evidence tables using Microsoft Word® (Microsoft Corporation, Redmond, WA). A second reviewer checked the data for accuracy. We abstracted information on study design, baseline data, intervention details, diagnostic accuracy outcomes, behavioral outcomes (smoking cessation, vaccination rates), health outcomes, and adverse events.

## Data Synthesis and Analysis

We created separate tables for the results for each KQ and additional summary tables that included key study characteristics. We qualitatively examined these tables to identify a range of results. Given the heterogeneity of studies, meta-analyses were not conducted for any of the KQs in this report.

For studies of diagnostic accuracy, we used 2×2 tables constructed from data reported in the primary studies. In cases where 95 percent CIs were not reported for diagnostic accuracy estimates, we calculated these intervals in Stata using Jeffrey’s CIs. For diagnostic accuracy studies, in addition to the standard test performance characteristics (i.e., sensitivity, specificity, positive predictive value [PPV], negative predictive value [NPV]), we calculated the following outcomes: COPD prevalence in the population (true positives plus false negatives, divided by the number of patients screened, multiplied by 100), percent of patients screening positive (true positives plus false positives, divided by the number of patients screened, multiplied by 100), false-positive rate (false positives divided by the false positives plus the true negatives, multiplied by 100), and the percent of diagnoses missed by screening (false negatives divided by the true positives plus false negatives, multiplied by 100).

## Expert Review and Public Comment

A draft of the analytic framework, KQs, and inclusion/exclusion criteria was posted on the USPSTF Web site for public comment from February 20, 2014 to March 19, 2014. We received comments from nine individuals or organizations. All comments were reviewed and addressed as appropriate. The final research plan was posted on the USPSTF Web site on May 29, 2014. The full draft report was reviewed by invited experts from January 30, 2015 through February 13, 2015. We compiled and addressed (where appropriate) the comments received from invited reviewers. Additionally, a draft of the full report was posted on the USPSTF Web site from August 18, 2015 to September 15, 2015. A few comments were received during this public comment period; no changes were made to the report based on these comments.

## USPSTF Involvement

AHRQ funded this research under a contract to support the work of the USPSTF. The authors worked with three USPSTF liaisons at key points throughout the review process to develop and refine the scope, analytic framework, and KQs; to resolve issues around the review process; and to finalize the evidence synthesis. AHRQ had no role in study selection, quality assessment, or evidence synthesis. AHRQ staff provided project oversight, reviewed the draft evidence synthesis, and distributed the initial evidence report for external review of content by outside experts, including representatives of professional societies and federal agencies.