# Introduction

## Condition Definition

Chronic obstructive pulmonary disease (COPD) is defined by a reduction in airflow that is not entirely reversible.1–6 This reduction in airflow is typically progressive and is related to an inflammatory response of the lungs to harmful particles or vapors, principally caused by cigarette smoking. While COPD mainly impacts the lungs, it can also result in substantial systemic consequences, such as progressive dyspnea, chronic cough, and chronic production of sputum.1–6 Asthma has distinct pathogenic causes and responds differently to treatment than COPD, and, while some overlap occurs, should be considered a different condition.6

Both current guidelines and the community standard for diagnostic spirometry in the United States require that fixed obstructive physiology be identified by a postbronchodilator forced expiratory volume in 1 second to forced vital capacity (FEV_1_/FVC) ratio of less than 0.70.^6^ The severity of obstruction is further characterized by the postbronchodilator FEV_1_ percent predicted. This is calculated as a ratio of volume exhaled in the first second over the volume predicted by any of a number of reference equations based on age, sex, race, and height.6,7 The classification of severity in patients is described in Table 1.

Table 1 Classification of Severity as Defined by Global Initiative for Chronic Obstructive Lung Disease (GOLD)6

COPD Severity | FEV_1_ Percent Predicted
Mild | FEV_1_ ≥80% predicted
Moderate | FEV_1_ ≥50% predicted but <80% predicted
Severe | FEV_1_ ≥30% predicted but <50% predicted
Very severe | FEV_1_ <30% predicted

Although the fixed ratio of FEV_1_/FVC of less than 0.70 is the current standard for diagnostic confirmation of obstructive physiology, it has been demonstrated that this fixed ratio results in underestimation of airflow obstruction among young adults and an overdiagnosis of obstruction in the elderly due to normal aging processes.8–10 An alternative approach has been proposed using a statistically derived lower limit of normal (LLN) FEV_1_/FVC criteria for a threshold determination of obstruction, which is usually defined by the lower fifth percentile or more complex statistical variations against some healthy reference population.8,10,11 While the LLN is anticipated to be more physiologically accurate, and some epidemiological studies support its clinical utility in adults younger than ages 45 to 50 years or older than age 70 years, experts disagree on the utility of the LLN and the preferred methodology of this measure. Misidentification of obstruction using LLN is generally limited to approximately 5 to 15 percent if these individuals are at the age extremes.8,10,12–14 Generally, the LLN has little advantage over the fixed ratio for diagnostic accuracy in a typical adult screening population with a medium age in the 5th to 6th decades.11,15–17

## Prevalence and Burden of Disease

It is estimated that approximately 13.7 million adults in the United States are impacted annually by COPD, and in 2010 the disease was responsible for approximately 10.3 million visits to physicians, 1.5 million visits to the emergency room, and 699,000 hospital discharges.18 In 2013, the Centers for Disease Control and Prevention (CDC) reported that chronic lower respiratory disease, composed chiefly of COPD, was the third leading cause of death in the United States.19 COPD also has significant economic consequences. The national health care costs related to COPD in the United States, for example, are estimated to be approximately $32.1 billion per year. After adding the total absenteeism related to the disease ($3.9 billion annually), the total annual burden of COPD-attributable costs are estimated at $36 billion per year.20

The prevalence of COPD in U.S. adults varies from approximately 5 to 20 percent, depending on the geographic location and the disease definition used. The highest prevalence of COPD is seen in states grouped along the Ohio and lower Mississippi rivers.3,6,21–25 Measurements of the prevalence and burden of COPD are variable because prevalence estimates rely on a mix of self-report, lung function testing, and administrative sources. Data from the U.S. National Health and Nutrition Examination Survey (NHANES) from 2007 to 2010 estimated a COPD prevalence of 14 percent among adults ages 40 to 79 years based on postbronchodilator spirometry. The prevalence was highest for mild disease (7.2%) followed by moderate (5.0%) and severe/very severe disease (0.8%).25

Recent data from the 2011 Behavioral Risk Factor Surveillance System show that 6.3 percent of U.S. adults reported that their physician or other health professional told them they had COPD.26 A subset of this survey data from 21 states, the District of Columbia, and Puerto Rico found that 76.0 percent of respondents with COPD reported completing a diagnostic breathing test, 64.2 percent felt that shortness of breath negatively impacted their quality of life, and 55.6 percent took at least one daily COPD medication. Approximately 43.2 percent of respondents with COPD reported visiting a physician for COPD-related symptoms in the preceding 12 months, and 17.7 percent had either visited an emergency department or been admitted to a hospital for their COPD during that time. An American Lung Association survey discovered that half of all COPD patients reported restrictions to their ability to work, participate in normal physical activities (70%), complete chores around the house (56%), participate in social events (53%), sleep (50%), and participate in activities with their families (46%).27

Deterioration of lung function over time is associated with a decline in health-related quality of life (HrQOL) among COPD patients. Studies examining this relationship have focused on patients with advanced disease and unsurprisingly have shown a substantial decline in HrQOL related to COPD.6,28–30 Studies assessing the impact on HrQOL among COPD patients with mild disease have found similar results, although this impact is not as significant as in those with advanced disease.31,32

The St. George’s Respiratory Questionnaire (SGRQ) is the primary HrQOL measurement tool used in studies of COPD. The SGRQ is a standardized self-administered 50-item questionnaire designed to measure impaired health and perceived well-being in patients with obstructive airway disease.33 The SGRQ is a two-part questionnaire with three components that assess the frequency and severity of symptoms, activities that cause or are limited by breathlessness, and “impacts” such as social functioning and psychological disturbances.34 A score is calculated for each section and the total score ranges from 0 to 100, with higher scores indicating higher levels of limitations.34 Clinically significant thresholds were established based on empirical data and interviews with patients, with a mean change score of 4 considered the minimum threshold for clinically meaningful change.35

We can estimate COPD screening yield and disease severity distribution using studies of screen-detected patients examining COPD case-finding. A 2011 primary care screening study of adults older than age 40 years with no medically confirmed obstructive lung disease (n=1,250) found that the majority of cases were found to be mild to moderate COPD, as defined by the Global Initiative for Chronic Obstructive Lung Disease (GOLD) (36% mild, 48% moderate), and 14 percent were found to have severe COPD.36 Additionally, a Belgian screening study of adults seen in primary care, ages 35 to 70 years, included only adults who did not use bronchodilators or inhaled steroids during the previous 12 weeks (n=3,158). This study found similar results, with the majority of patients having mild (39.0%) or moderate COPD (51.0%). The study found that 9 percent had severe COPD.37 Severity results among high-risk patients (based on age and smoking status) appear to have a similar distribution. A recently published U.S.- and U.K.-based COPD screening study (n=818) focused on asymptomatic patients with a history of smoking and no prior diagnosis of any chronic respiratory disease who were seen in primary care reported case-finding results by disease severity.38 Among the 155 patients diagnosed with COPD, 57.4 percent had mild disease as defined by GOLD, 36.8 percent had moderate disease, and 5.8 percent had severe disease. None of the participants had very severe disease. Further, a 2011 Australian screening study focused on primary care patients with a history of smoking and no prior diagnosis of COPD (n=237) found a COPD prevalence of 27.9 percent. Fewer patients showed mild COPD (33.3%), 61.4 percent were found to have moderate COPD, 5.2 percent had severe COPD, and no participants had very severe COPD.39 Thus, screening yield in the general primary and asymptomatic population would be very unlikely to identify more than 5 to 14 percent of the population as having severe COPD, even among high-risk patients.

## Etiology and Natural History

COPD is a progressive, chronic condition without a known cure. COPD is characterized by continual respiratory decline associated with acute exacerbations that often result in hospitalization and ultimately death.6,28,40 Although lung function that declines over time is a characteristic of the disease, the trajectory of decline can vary significantly among patients. Some patients experience a higher rate of exacerbations than is typical, while others have lung function that remains relatively stable for extended periods of time. Others experience a decrease in lung function at a more rapid rate than the rest of the COPD population.2,40 While the reasons behind these differences are not precisely known, researchers suspect that environmental and genetic factors likely play a role.6,28,41

As a result of the slow progression of disease and the risk associated with long-time smoking, COPD is more common in patients older than age 40 years.42–44 Recent data from NHANES examining pre- and postbronchodilator results found COPD present in 9.2 percent of 40- to 59-year-olds compared to 22.6 percent of 60- to 79-year-olds.25 If a patient younger than age 45 years is identified as having COPD, national guidelines recommend that they undergo testing for α_1_-antitrypsin deficiency.6,45

Although the pathobiology of COPD involves systemic abnormal inflammation, inflammation is principally centered in the lungs.1–6 Changes can be characterized in the peripheral airways, central airways, pulmonary vasculature, and lung parenchyma. These changes vary across individuals with the disease and suggest different clinical phenotypes.2,6,28 The pathogenesis includes chronic inflammation that involves an imbalance of proteinases and antiproteinase, as well as oxidative stress resulting in physiological irregularities that include: hypersecretion of mucous and ciliary dysfunction; restricted airflow and hyperinflation; abnormalities in gas exchange; pulmonary hypertension; and other systemic effects.2,6

## Risk Factors

Given that the primary risk factors for COPD are modifiable (i.e., exposure to smoke or fumes), the disease could be preventable by eliminating such exposures.2,6 A history of exposure to cigarette smoke, either directly or indirectly, has been highly correlated with developing COPD and with COPD mortality.6,21,23,27,46 Data from the Burden of Obstructive Lung Disease (BOLD) project found that more than 70 percent of COPD cases occurred among current or former smokers and that this result had a dose-response relationship (odds ratio [OR], 1.24 [95% confidence interval (CI), 1.05 to 1.47] for each 10 pack-year increase).46,47 Screening data from the third NHANES identified obstructive lung disease (including COPD and asthma) in 12.5 percent of current smokers and 9.4 percent of former smokers.21 Historically, researchers have estimated that 15 to 20 percent of smokers develop COPD. A more recent study, however, found that this number may be closer to 50 percent.48 An epidemiological study evaluating 50-year trends in smoking-related mortality using data from longitudinal cohort studies found that current smokers were 4 to 22 times more likely to die from COPD-related causes than those who had never smoked.49

COPD prevalence and mortality have been increasing more rapidly among women than men over the past 20 years. This is thought to be due to a variety of factors, including increasing smoking rates among women, differences in environmental exposures, and potential biological or hormonal mechanisms affecting the susceptibility to COPD. Additionally, epidemiological studies have demonstrated that women may be more vulnerable to the negative health effects of smoking than men.6 A recent report summarizing data from the National Health Interview Survey of adults older than age 18 years, for example, found that from 1998 to 2009 women had a consistently higher prevalence of self-reported COPD than men (about 6% vs. 4%).50 This trend was true across the lifespan, except for those ages 75 to 84 years, where more men than women reported having the disease (11.2% vs. 9.7%). Similarly, data from the 2011 Behavioral Risk Factor Surveillance System reported more women age 18 years or older who self-reported receiving a diagnosis of COPD compared to men (6.7% vs. 5.2%).26 Some of these numbers may reflect a gender bias in the self-reporting of a COPD diagnosis. Recent data based on postbronchodilator spirometry (not self-reported diagnoses) in the nationally representative NHANES sample of adults ages 40 to 79 years found a higher prevalence in men than women (about 17% vs. 10%).25

COPD prevalence also appears to vary by racial/ethnic group. Data based on postbronchodilator spirometry in the 2007–2010 NHANES found the highest prevalence of COPD among non-Hispanic whites (14.9%) followed by non-Hispanic blacks (12.8). Mexican Americans were least likely to have COPD with a prevalence of 5.8 percent.25 After adjustment for demographic factors, socioeconomic status, and COPD risk factors, Mexican Americans have been found to have decreased odds of obstructive lung disease (including COPD and asthma) compared to non-Hispanic whites (OR, 0.72 [95% CI, 0.54 to 0.95]). This decreased risk, however, has not been shown to provide any COPD mortality advantage.51 Other groups, including Asians, Native Hawaiians/Pacific Islanders, American Indians, Alaska Natives, and multiracial persons have been found to have a rate between that of Hispanics and non-Hispanic whites.26

While smoking is associated with the majority of COPD cases, research has shown that several occupational and environmental exposures increase the risk of developing COPD. Certain occupations, such as farming and industrial work, which expose employees to irritants (e.g., toxins, dust, industrial chemicals), have been associated with the development of COPD. These occupational sources are estimated to contribute to 15 percent of COPD cases. The most common environmental exposures linked to COPD include traffic pollutants and wood smoke.52 Additionally, exposure to secondhand smoke, heredity, a history of childhood respiratory infections, asthma, and low socioeconomic status have been shown to increase the risk of developing the disease.3,6,52–55

## Rationale for Screening/Screening Strategies

Primary care providers can identify COPD by screening asymptomatic persons or targeting a high-risk asymptomatic population, such as patients with a history of smoking, by using screening spirometry administered without medication (i.e., prebronchodilator testing).6 The diagnosis of COPD requires persistent airway obstruction after an additional step of spirometry testing following the administration of an inhaled medication like albuterol (i.e., postbronchodilator spirometry).4,6 Screening strategies using spirometry can be conducted sequentially in medical settings, which will allow both tests (pre- and postbronchodilator) to be combined into a single screening episode. They can also be conducted as separate screening steps, allowing the prebronchodilator screening to be done by personnel not authorized to administer medications (e.g., medical assistants). After identifying obstruction with screening, patients can then be administered diagnostic spirometry in primary care or be referred to pulmonary specialty clinics for diagnostic spirometry, including postbronchodilator testing. Spirometry testing in primary care settings must be administered by trained individuals using equipment that may require maintenance and/or calibration to achieve acceptable testing quality.7,38,56,57 Additionally, spirometry requires technical expertise to maximize the FVC maneuver, including proficiency in coaching the participant; reproducibility standards set for repeated measurements can be difficult to achieve in primary care settings.7,38,58–60 Concerns have been raised over the yield, complexity, and quality of spirometric measures in primary care settings.38,56,57,59,61 The reliability and quality of measures in nonspecialty settings, however, can be improved by sufficient training and quality control measures.58,62–64 Recent population- and primary care–based screenings using FEV_1_/FVC spirometry, for example, have achieved greater than 90 percent reliability and acceptability.58,63 An alternative approach to FEV_1_/FVC using the exhaled volume after 6 seconds of maximal effort expiration (FEV_6_) for a ratio (FEV_1_/FEV_6_) is being considered for screening. This is because this ratio is more explicitly defined and the breathing measure is easier to achieve by patients and nonspecialized practitioners administering the test. Additionally, some devices are handheld and require minimal maintenance and calibration (e.g., COPD-6, PiKo-6). While research has shown that the FEV_1_/FEV_6_ may be a reliable screening index in less sophisticated settings, it is not sufficient for diagnostic criteria.9,11,15,65–67

Full-reference spirometry, including postbronchodilator testing, requires 40 minutes to administer and has the above mentioned requirements. Prebronchodilator handheld screening devices, however, require less than 10 minutes to administer in an examination room and can be administered by medical assistant personnel with 10 hours or less of training and minimal (≤5 minutes) daily calibration time. Using these devices, providers can obtain valid results in more than 85 to 95 percent of prebronchodilator tests.7,38,56,57 Additionally, questionnaires to rule out those who would not need screening spirometry require less than 5 to 10 minutes to self-administer and score, which can easily be accomplished in an examination room.

Less than half of the estimated 24 million U.S. adults who have airflow obstruction after spirometry testing were previously diagnosed with COPD.21,22,68 This is the result of the often indeterminate symptoms experienced in the earlier stages of COPD. Consequently, patients are typically diagnosed with the disease in the advanced stages, which leads to poorer treatment outcomes and higher economic costs.2,6,69,70 Earlier COPD diagnosis using spirometry testing might, therefore, potentially have a substantial impact on patient outcomes if better disease management and treatment in earlier stages of COPD was shown to result in fewer exacerbations, less dyspnea, and an overall improvement in HrQOL. Additionally, the benefits of screening could include an increase in smoking cessation for current smokers, an increase in targeted preventive services (e.g., influenza and pneumococcal vaccines), and possibly the initiation or optimization of therapies that could reduce disease progression. Recently, some authors have developed and internally validated 10-year COPD prediction models in primary care.71

This systematic review targeted asymptomatic persons, defined as those who are free of the disease; those in whom the disease is present but who have physical symptoms that are undetected by the patient or the clinician (e.g., mild dyspnea that goes unnoticed); or those who have nonspecific symptoms (e.g., sporadic sputum production or cough) that have gone unrecognized as being related to COPD. The distinction between patients who are symptomatic and those who are undetected or who present with nonspecific symptoms is difficult to determine from available clinical research. This is particularly true for smokers, many of whom have a chronic cough and some limited activity without presenting these complaints to their physicians. Additionally, identifying asymptomatic persons may also be challenging for clinical practice until screening/case-finding tools can be developed to identify persons based on sociodemographic characteristics, such as age or a particular smoking history.

## Interventions/Treatment

Smoking cessation interventions should play an integral part in the medical management of COPD in all stages of the disease because exposure to cigarette smoke is the primary risk factor for developing COPD and accelerates the deterioration of lung function in patients with the disease.6,72,73 Patients with COPD also have greater resistance to smoking cessation interventions than other smoking adults, which is likely due to their advanced age and increased pack-year history.74 Additionally, patients with COPD have reported increased rates of depression compared to general smokers, which can lead to more failed quit attempts and higher relapse rates.75 A 2012 systematic review assessed the effectiveness of smoking cessation interventions in this population and found that cessation interventions can be successful if they are high intensity and combined with nicotine replacement therapies.76

Pharmacotherapy can be used to alleviate symptoms and reduce the incidence and severity of exacerbations in patients with symptomatic COPD, while improving overall HrQOL.6 Currently, joint guidelines from the American College of Physicians, American College of Chest Physicians, American Thoracic Society (ATS), and European Respiratory Society (ERS) recommend against treating asymptomatic persons, with or without spirometric evidence of airflow obstruction, regardless of the presence or absence of risk factors for airflow obstruction.4 The guidelines recommend using inhaled bronchodilators for stable COPD patients with respiratory symptoms and moderate to very severe disease (FEV_1_ <60% of predicted).4 For symptomatic moderate disease (FEV_1_ 60% to 80% of predicted), inhaled bronchodilator therapy may also be used to aid in the reduction of symptoms.4 For symptomatic patients with moderate to very severe disease (FEV_1_ <60%), monotherapy with long-acting β-agonists (LABAs) or long-acting inhaled anticholinergics are recommended.4 Combining bronchodilators of varying pharmacologic classes may increase efficacy, while reducing the risk of side effects, compared to increasing the dose of a single bronchodilator.6,70 Other primary pharmacologic therapies for COPD include inhaled corticosteroids (ICS) and phosphodiesterase-4 inhibitors (specifically for severe to very severe COPD with chronic bronchitis and a history of exacerbations).

The effectiveness of treatments for COPD patients with severe or very severe disease (FEV_1_ <50% of predicted) has been well-studied, while the effectiveness of COPD treatments in patients with mild to moderate COPD (FEV_1_ ≥50% of predicted) have been less robustly studied. Treatments specific to patients with more advanced COPD include pulmonary rehabilitation, oxygen therapy, surgery, and lung transplantation. Pulmonary rehabilitation is recommended for symptomatic patients with an FEV_1_ of less than 50 percent of predicted and can be comprised of a multitude of services, including exercise training, nutritional counseling, training on breathing strategies, and energy conservation methods.4,77 Evidence has demonstrated that COPD patients who receive these services can experience reduced hospitalizations and improved HrQOL.77 Oxygen therapy is recommended for COPD patients with severe resting hypoxemia and typically involves the continuous administration of oxygen for more than 15 hours a day. Although this type of therapy has been found to be mildly disruptive to the patient, evidence suggests that it can lead to improved survival.6,78 For patients with very severe COPD, surgical treatment aimed at reducing lung volume and lung transplantation can offer a survival benefit and improvements in HrQOL.6,79 Observational studies, for example, have shown that COPD patients with severe or very severe disease constitute a very small minority of those identified by asymptomatic spirometry screening (<5%).22,38,61 Therefore, we will not consider treatment modalities recommended specifically for these patients (i.e., pulmonary rehabilitation, oxygen therapy, surgical treatment, and lung transplantation) in this review.

## Current Clinical Practice

In 2011, the American College of Physicians, American College of Chest Physicians, ATS, and ERS issued a joint clinical practice guideline on the diagnosis and management of COPD.4 After reviewing the evidence related to the value of screening asymptomatic patients for COPD using spirometry, the panel recommended against this practice, citing there was no evidence of benefit based on moderate-quality evidence. It did recommend case-finding with spirometry, however, in patients reporting COPD-related symptoms. Similarly, in 2010 the National Institute for Health and Care Excellence recommended against screening asymptomatic patients for COPD using spirometry.3 It went on to recommend that only patients who are age 35 years and older with an established risk factor (e.g., a history of smoking, family history of lung disease, exposure to occupational pollutants) and who present with respiratory symptoms associated with the disease should be evaluated with spirometry. The GOLD guidelines, updated in 2015, include similar recommendations related to the appropriate case-finding population.6

Generally, screening for COPD using prebronchodilator testing is not widely used in primary care practice in the United States. Additionally, data suggests that using spirometry for case-finding in a manner consistent with guideline recommendations is vastly underutilized.3,6,21,22 In the NHANES III, for example, 63.3 percent of adults who were found to have airflow obstruction reported never having received a previous diagnosis of COPD.21 This lack of use stems from a number of causes, including its low diagnostic yield and complexity of the testing.38,61,68,80–82 In work conducted by the U.K. National Screening Committee to update COPD screening policy, for example, both patients and providers noted low acceptability of spirometry.83 Additionally, concerns over test characteristics and alternate spirometric measures have been raised.84,85 The reliability, reduced quality of measures in nonspecialty settings, and the risk of overdiagnosis further decrease the use of spirometry in primary care.57,58,62

As current guidelines support the use of spirometry for case-finding in those with symptoms, researchers and practitioners are employing strategies to increase the identification of patients with unreported respiratory symptoms using a variety of screening questionnaires and sending those who prescreen positive to screening spirometry or diagnostic spirometry.86–89 Two possible strategies for targeted screening spirometry include basic risk factor questionnaires that are easily and quickly administered to patients or the identification of high-risk subpopulations through patient history inquirees,83,90–92 and several prescreening or risk identification tools have been developed to increase the efficacy of case-finding. These include the Lung Function Questionnaire (LFQ),86,93 the COPD Diagnostic Questionnaire (CDQ),94,95 and the COPD Population Screener (COPD-PS).88

## Previous U.S. Preventive Services Task Force Recommendation

In 2008, the U.S. Preventive Services Task Force (USPSTF) recommended against screening asymptomatic adults for COPD using spirometry (D recommendation).96 The USPSTF concluded that there was at least moderate certainty that this method had no net benefit and had large associated opportunity costs. It also found good-quality evidence demonstrating that patient history and clinical examination are not often accurate predictors of airflow limitation. Additionally, it reported fair-quality evidence demonstrating that giving smokers the results of spirometry screening does not independently improve smoking cessation rates. Further, the USPSTF found fair-quality evidence that annual influenza vaccination may reduce COPD exacerbations, but did not identify any studies that examined whether screening with spirometry results in an increased rate of influenza vaccination. Additionally, the USPSTF found good-quality evidence indicating that pharmacologic therapy prevents the worsening of symptoms and need for medical interventions related to COPD. It also found, however, that pharmacologic therapy does not impact hospitalization rates or all-cause mortality in symptomatic patients who have ever smoked, are age 40 years or older, and have severe or very severe COPD (FEV_1_ <50% of predicted). Further, fair-quality evidence demonstrated that both pharmacotherapy and pulmonary rehabilitation improve health status measures related to respiration and that supplemental oxygen reduces mortality among patients with resting hypoxia. Overall, the incremental benefits of screening asymptomatic patients for COPD using spirometry were judged to be minimal.