# Adverse Events Reported on FDA Labels of Drugs Included in KQ7

Drug Class | Drug | Black Box Warning | Brand | Approved indication(s) | FDA common adverse events: incidence ≥3% (and higher than placebo group)
Long-Lasting Anticholinergics | Tiotropium | None | Spiriva Respimat | COPD | Pharyngitis, cough, dry mouth, and sinusitis.
Long-Lasting Anticholinergics | Tiotropium | None | Spiriva | COPD | Chest pain, edema (dependent), dry mouth, dyspepsia, abdominal pain, constipation, vomiting, myalgia, infection, moniliasis, upper respiratory tract infection, sinusitis, pharyngitis, rhinitis, epistaxis, rash, urinary tract infection
Inhaled Corticosteroids | Budesonide | None | Pulmicort Flexhaler | Asthma | Respiratory infection, sinusitis, headache, pain, back pain, fever
Inhaled Corticosteroids | Budesonide | None | Pulmicort Respules | Asthma | Respiratory infection, rhinitis, coughing, otitis media, viral infection, moniliasis, gastroenteritis, vomiting, diarrhea, abdominal pain, ear infection, epistaxis, conjunctivitis, rash
Inhaled Corticosteroids | Budesonide | None | Pulmicort Turbuhaler (discontinued) | Asthma | Respiratory infection, pharyngitis, sinusitis, voice alteration, headache, flu syndrome, pain, back pain, fever, oral candidiasis, dyspepsia, gastroenteritis, nausea
Inhaled Corticosteroids | Fluticasone propionate | None | Flovent (discontinued) | Asthma | Pharyngitis, nasal congestion, sinusitis, nasal discharge, dysphonia, allergic rhinitis, oral candidiasis, upper respiratory infection, influenza, headache
Inhaled Corticosteroids | Fluticasone propionate | None | Flovent Rotadisk (discontinued) | Asthma | Pharyngitis, nasal congestion, sinusitis, rhinitis, dysphonia, oral candidiasis, upper respiratory infection, influenza, bronchitis, headache, diarrhea, back problems, fever
Inhaled Corticosteroids | Fluticasone propionate | None | Flovent diskus | Asthma | Upper respiratory tract infection or inflammation, throat irritation, sinusitis, rhinitis, oral candidiasis, nausea and vomiting, gastrointestinal discomfort, fever, cough, bronchitis, and headache.
Inhaled Corticosteroids | Fluticasone propionate | None | Flovent HFA | Asthma | Upper respiratory tract infection or inflammation, throat irritation, sinusitis, dysphonia, candidiasis, cough, bronchitis, and headache.
Inhaled Corticosteroids | Mometasone furoate | None | Asmanex twisthaler | Asthma | Headache, allergic rhinitis, pharyngitis, upper respiratory infection, sinusitis, candidiasis (oral), dysmenorrhea, musculoskeletal pain, back pain, dyspepsia, myalgia, abdominal pain, nausea
Inhaled Corticosteroids | Mometasone furoate | None | Asmanex HFA | Asthma | Nasopharyngitis, headache, sinusitis, bronchitis, and influenza.
Inhaled Corticosteroids | Triamcinolone acetonide | None | Azmacort (discontinued) | Asthma | Sinusitis, pharyngitis, headache, flu syndrome, back pain
Inhaled corticosteroid/Long-acting Beta-agonist | Salmeterol/Fluticasone propionate | Yes: Asthma Only^*^ | Advair Diskus | Asthma, COPD | Pneumonia, oral candidiasis, throat irritation, dysphonia, viral respiratory infections, headaches, musculoskeletal pain.
Inhaled corticosteroid/Long-acting Beta-agonist | Salmeterol/Fluticasone propionate | Yes: Asthma Only^*^ | Advair HFA | Asthma | Upper respiratory tract infection or inflammation, throat irritation, dysphonia, headache, dizziness, nausea and vomiting.
Long-acting Beta-agonist | Formoterol Fumarate | Yes: Asthma only^*^ | Foradil | Asthma, COPD | Upper respiratory tract infection, back pain, pharyngitis, chest pain
Long-acting Beta-agonist | Formoterol Fumarate | Yes: Asthma only^*^ | Foradil certihaler (discontinued) | Asthma | Nasopharyngitis, headache, upper respiratory tract infection, cough, pyrexia, vomiting
Long-acting Beta-agonist | Formoterol Fumarate | Yes: Asthma only^*^ | Perforomist | COPD | Diarrhea, nausea, nasopharyngitis, dry mouth
Long-acting Beta-agonist | Indacaterol maleate | Yes: Asthma Only^*^ | Arcapta neohaler | COPD | Cough, nasopharyngitis, headache
Long-acting Beta-agonist | Salmeterol | None^†^ | Serevent | Asthma, COPD | Upper respiratory tract infection, nasopharyngitis, disease of nasal cavity/sinus, sinus headache, stomach ache, headache, tremor, cough lower respiratory infection

* Black box warning on long-acting beta2-adrenergic agonists (LABA) warns of an increased risk of asthma-related death.

† Ongoing FDA investigation does not appear to be related to COPD.