# Scoring Details for Externally Validated Prescreening Questionnaires

Screening Questionnaire | Questionnaire Items | Answers (points assigned) | Scoring & Interpretation
Lung Function Questionnaire (LFQ) | How often do you cough up mucus? | Never (5) Rarely (4) Sometimes (3) Often (2) Very often (1) | If score is 18 or less, person may be at risk for COPD93
Lung Function Questionnaire (LFQ) | How often does your chest sound noisy (wheezy, whistling, rattling) when you breathe? | Never (5) Rarely (4) Sometimes (3) Often (2) Very often (1) | If score is 18 or less, person may be at risk for COPD93
Lung Function Questionnaire (LFQ) | How often do you experience shortness of breath during physical activity (walking up a flight of stairs or walking up an incline without stopping to rest)? | Never (5) Rarely (4) Sometimes (3) Often (2) Very often (1) | If score is 18 or less, person may be at risk for COPD93
Lung Function Questionnaire (LFQ) | How many years have you smoked? | Never smoked (5) 10 years or less (4) 11–20 years (3) 21–30 years (2) More than 30 years (1) | If score is 18 or less, person may be at risk for COPD93
Lung Function Questionnaire (LFQ) | What is your age? | Less than 40 years (5) 40–49 years (4) 50–59 years (3) 60–69 years (2) 70 years or older (1) | If score is 18 or less, person may be at risk for COPD93
COPD Diagnostic Questionnaire (CDQ) Also known as: International Primary Care Airways Guidelines (IPAG) | How old are you? | 40–49 (0) 50–59 (4) 60–69 (8) 70+ (10) | Total score ≥17 suggests increased risk of COPD being present36
COPD Diagnostic Questionnaire (CDQ) Also known as: International Primary Care Airways Guidelines (IPAG) | What is your weight? What is your height? BMI = weight/height | <25.4 (5) 25.4–29.7 (1) >29.7 (0) | Total score ≥17 suggests increased risk of COPD being present36
COPD Diagnostic Questionnaire (CDQ) Also known as: International Primary Care Airways Guidelines (IPAG) | How many cigarettes do you smoke daily (if you are an ex-smoker how many cigarettes did you used to smoke daily)? How many years did/do you smoke? Packs per day = cigarettes per day/20 cigarettes per pack Pack-years = packs per day × years smoked | 0–14 pack-years (0) 15–24 pack-years (2) 25–49 pack-years (3) 50+ pack-years (7) | Total score ≥17 suggests increased risk of COPD being present36
COPD Diagnostic Questionnaire (CDQ) Also known as: International Primary Care Airways Guidelines (IPAG) | Does the weather affect your cough? | Yes (3) No (0) | Total score ≥17 suggests increased risk of COPD being present36
COPD Diagnostic Questionnaire (CDQ) Also known as: International Primary Care Airways Guidelines (IPAG) | Do you ever cough up phlegm (sputum) from your chest when you don’t have a cold? | Yes (3) No (0) | Total score ≥17 suggests increased risk of COPD being present36
COPD Diagnostic Questionnaire (CDQ) Also known as: International Primary Care Airways Guidelines (IPAG) | Do you usually cough up phlegm (sputum) from your chest first thing in the morning? | Yes (0) No (3) | Total score ≥17 suggests increased risk of COPD being present36
COPD Diagnostic Questionnaire (CDQ) Also known as: International Primary Care Airways Guidelines (IPAG) | How frequently do you wheeze? | Sometimes or often (4) Never (0) | Total score ≥17 suggests increased risk of COPD being present36
COPD Diagnostic Questionnaire (CDQ) Also known as: International Primary Care Airways Guidelines (IPAG) | Do you have or have you had any allergies? | Yes (0) No (3) | Total score ≥17 suggests increased risk of COPD being present36
COPD Population Screener (COPD-PS) | During the past 4 weeks, how much of the time did you feel short of breath? | None of the time (0) A little of the time (0) Some of the time (1) Most of the time (2) All of the time (2) | Total score scale ranges from 0 (unlikely to have fixed airflow obstruction) to 10 (likely to have fixed airflow obstruction). Development study suggests a cut point in the range of 5 to 6 provides a good trade-off between sensitivity and specificity. 88
COPD Population Screener (COPD-PS) | Do you ever cough up any “stuff”, such as mucus or phlegm? | No, never (0) Only with occasional colds or chest infections (0) Yes, a few days a month (1) Yes, most days a week (1) Yes, every day (2)
COPD Population Screener (COPD-PS) | Please select the answer that best describes you in the past 12 months. I do less than I used to because of my breathing problems. | Strongly disagree (0) Disagree (0) Unsure (0) Agree (1) Strongly agree (2)
COPD Population Screener (COPD-PS) | Have you smoked at least 100 cigarettes in your entire life? | No (0) Yes (2) Don’t know (0)
COPD Population Screener (COPD-PS) | How old are you? | Age 35 to 49 (0) Age 50 to 59 (1) Age 60 to 69 (2) Age 70+ (2)