# Excluded Studies

Exclusion Code | Definition
E1 | Study relevance
E2 | Setting; a. Not HDI > 0.9; b. Not generalizable to primary care
E3 | Population; a. Majority not mild –to-moderate disease; b. Doesn’t meet asymptomatic criteria; c. Not Adults 40+; d. Not COPD
E4 | Study quality
E5 | Study design; a. Not an approved study design for the KQ; b. Comparative effectiveness; c. Not appropriate reference standard; d. Effectiveness, not uptake (KQ5); e. Not a screening tool (e.g., prognostic assessment); f. KQ5–8- Preventive service uptake not prompted by spirometry; g. Uses preBD as the reference standard; h. No subanalysis by disease severity (KQ7); i. N too small (≤ 10 per arm)
E6 | No relevant outcomes
E7 | Intervention; a. Not a questionnaire (KQ2); b. Not a device (KQ3); c. Treatment not considered in our review (e.g. P4-inhibitors); d. Follow-up less than 6 months (KQ7)
E8 | Article not in English
I1 | Study included for designated Key Question

1 In chronic obstructive pulmonary disease, a combination of ipratropium and albuterol is more effective than either agent alone. An 85-day multicenter trial. COMBIVENT Inhalation Aerosol Study Group. Chest. May. 1994;105(5):1411-9. KQ7E7d. [pmid: 8181328].
2 Routine nebulized ipratropium and albuterol together are better than either alone in COPD. The COMBIVENT Inhalation Solution Study Group. Chest. Dec. 1997;112(6):1514-21. KQ7E7d. [pmid: 9404747].
3 Aalbers R, Ayres J, Backer V, et al. Formoterol in patients with chronic obstructive pulmonary disease: a randomized, controlled, 3-month trial. Eur Respir J. May. 2002;19(5):936-43. KQ7E7d. [pmid: 12030736].
4 Aaron SD, Vandemheen KL, Fergusson D, et al. Tiotropium in combination with placebo, salmeterol, or fluticasone-salmeterol for treatment of chronic obstructive pulmonary disease: a randomized trial. Ann Intern Med. Apr. 17. 2007;146(8):545-55. KQ7E5b. [pmid: 17310045].
5 Abrahams R, Ramsdell J, Moroni ZP, et al. Comparison of BEA2180 to tiotropium and placebo via respimat in patients with chronic obstructive pulmonary disease (COPD). Respirology. 2012;17:46. PMID: None. KQ7E5h.
6 Abrahams R, Moroni-Zentgraf P, Ramsdell J, et al. Safety and efficacy of the once-daily anticholinergic BEA2180 compared with tiotropium in patients with COPD. Respiratory Medicine. Jun. 2013;107(6):854-62. KQ7E5h. [pmid: 23490224].
7 Abramson M, Schattner R, Lucas K, et al. Spirometry and regular follow-up are not associated with improved quality of life in General Practice patients. [Abstract]. Respirology. 2009;14:A30. PMID: None. KQ1E3b.
8 Abramson M, Schattner R, Lucas K, et al. Spirometry with regular review is not associated with improved outcomes in general practice patients. [Abstract]. European Respiratory Society Annual Congress. Vienna, Austria. September 12 16 2009. 1381. PMID: None. KQ1E3b.
9 Agado B, Bowen D. Periodontal disease and respiratory disease: A systematic review of the evidence. Canadian Journal of Dental Hygiene. May. 2012;46(2):103-14. PMID: None. KQ2E6.
10 Agusti A, Jones PW, Bateman E, et al. Improvement in symptoms and rescue medication use with aclidinium bromide in patients with chronic obstructive pulmonary disease: Results from ATTAIN. [Abstract]. European Respiratory Society Annual Congress. Amsterdam, The Netherlands. September 24 28 2011. 38(suppl 55):874. PMID: None. KQ7E5h.
11 Akkoca YO, Onen ZP, Demir G, et al. Is there any difference between effects of ipratropium bromide and formoterol on exercise capacity in moderate COPD patients?. Tuberkuloz ve Toraks. 2006;54(2):105-13. KQ7E7d. [pmid: 16924565].
12 Albers F, Shaikh A, Iqbal A. Design, rationale, and baseline demographics of SEARCH I: a prospective cluster-randomized study. International Journal of COPD. 2012;7:437-45. KQ2E5a, KQ3E5a. [pmid: 22848157].
13 Alfageme I, Vazquez R, Reyes N, et al. Clinical efficacy of anti-pneumococcal vaccination in patients with COPD. Thorax. Mar. 2006;61(3):189-95. KQ5bE5d. [pmid: 16227328].
14 Anar C, Bicmen C, Yapicioglu S, et al. Evaluation of clinical data and antibody response following influenza vaccination in patients with chronic obstructive pulmonary disease. New Microbiologica. Apr. 2010;33(2):117-27. KQ5bE5d. [pmid: 20518273].
15 Anthonisen NR, Connett JE, Kiley JP, et al. Effects of smoking intervention and the use of an inhaled anticholinergic bronchodilator on the rate of decline of FEV1. The Lung Health Study. JAMA. Nov. 16. 1994;272(19):1497-505. KQ7E6. [pmid: 7966841].
16 Arinez-Fernandez MC, Carrasco-Garrido P, Garcia-Carballo M, et al. Determinants of pneumococcal vaccination among patients with chronic obstructive pulmonary disease in Spain. Human Vaccines. May. 2006;2(3):99-104. KQ5bE5f. [pmid: 17012893].
17 Aung MN, Yuasa M, Lorga T, et al. Evidence-based new service package vs. routine service package for smoking cessation to prevent high risk patients from cardiovascular diseases (CVD): study protocol for randomized controlled trial. Trials. 2013;14:419. KQ5aE2a. [pmid: 24308874].
18 Averame G, Bonavia M, Ferri P, et al. Office spirometry can improve the diagnosis of obstructive airway disease in primary care setting. Respiratory Medicine. Jun. 2009;103(6):866-72. KQ2E7a, KQ3E5c. [pmid: 19200705].
19 Backer J, Vos W, Claes R, et al. A double blind placebo controlled study to assess the effect of roflumilast in addition to LABA/LAMA/ICS treatment in COPD patients using novel biomarkers (Abstract). American journal of respiratory and critical care medicine. 2014;189:A3773. KQ7E5h.
20 Balamurugan S, Mehta R, Bhargava S, et al. Efficacy and safety of two HFA formulations of ipratropium bromide MDI in patients with mild to moderate chronic obstructive pulmonary disease. 7th International Primary Care Respiratory Group World Conference. Athens. 21 24 May, 2014. 2014. O012-OTHU. PMID: None. KQ7E5b.
21 Balkan A, Bulut Y, Fuhrman CR, et al. COPD phenotypes in a lung cancer screening population. Clin Respir J. 2014. Jul. 3. KQ2E7a, KQ3E7a.
22 Balkissoon R. Concurrent use of indacaterol plus tiotropium in patients with COPD provides superior bronchodilation compared with tiotropium alone: A randomised, double-blind comparison. Copd: Journal of Chronic Obstructive Pulmonary Disease. 2012;9:441. PMID: None. KQ7E7d.
23 Barnes TA, Fromer L. Spirometry use: detection of chronic obstructive pulmonary disease in the primary care setting. Clinical Interventions In Aging. 2011;6:47-52. KQ2E5a. [pmid: 21472091].
24 Bateman ED, Tashkin D, Siafakas N, et al. A one-year trial of tiotropium Respimat plus usual therapy in COPD patients. Respiratory Medicine. Oct. 2010;104(10):1460-72. KQ7E5a. [pmid: 20620037].
25 Bateman ED, Welte T, Hashimoto S, et al. Dual bronchodilation with once-daily QVA149 provides superior bronchodilation compared to its mono-components and tiotropium in all subgroups of patients with COPD: the SHINE study. American journal of respiratory and critical care medicine. 2013;187:A4263. PMID: None. KQ7E6.
26 Bateman ED, Ferguson GT, Barnes N, et al. Dual bronchodilation with QVA149 versus single bronchodilator therapy: the SHINE study. European Respiratory Journal. Dec. 2013;42(6):1484-94. KQ7E5h. [pmid: 23722616].
27 Baumgartner RA, Hanania NA, Calhoun WJ, et al. Nebulized arformoterol in patients with COPD: a 12-week, multicenter, randomized, double-blind, double-dummy, placebo- and active-controlled trial. Clinical Therapeutics. Feb. 2007;29(2):261-78. KQ7E7d. [pmid: 17472819].
28 Beaumont JL, Victorson D, Curtice TG, et al. A web equivalence and subgroup study of the chronic obstructive pulmonary disease population screener. Chest. 2009;136:62S-g. PMID: None. KQ2E5c, KQ3E7b.
29 Beaumont JL, Victorson D, Su J, et al. Examining web equivalence and risk factor sensitivity of the COPD population screener. Value in Health. Jun. 2011;14(4):506-12. KQ2E5c. [pmid: 21669376].
30 Bedard ME, Brouillard C, Pepin V, et al. Tiotropium Improves Walking Endurance In Chronic Obstructive Pulmonary Disease Patients. American journal of respiratory and critical care medicine. 2011;183:A1590. PMID: None. KQ7E7d.
31 Bednarek M, Maciejewski J, Wozniak M, et al. Prevalence, severity and underdiagnosis of COPD in the primary care setting. Thorax. May. 2008;63(5):402-7. KQ3E6, KQ4E6. [pmid: 18234906].
32 Bednarek M, Gorecka D, Wielgomas J, et al. Smokers with airway obstruction are more likely to quit smoking. Thorax. Oct. 2006;61(10):869-73. KQ5aE5a. [pmid: 16809415].
33 Beeh KM, Watz H, Magnussen H, et al. Aclidinium bromide improves exercise endurance and dynamic hyperinflation and decreases exertional dyspnoea in patients with moderate-to-severe COPD. American journal of respiratory and critical care medicine. 2013;187:A2430. PMID: None. KQ7E7d.
34 Beeh KM, Watz H, Magnussen H, et al. Effects of aclidinium bromide on exercise endurance, dynamic hyperinflation, physical activity and exertional dyspnoea in patients with moderate to severe COPD. European Respiratory Society Annual Congress. 2013 Sept 7 11. Barcelona, Spain. 2013;42:636s. PMID: None. KQ7E7d.
35 Beier J, Kirsten AM, Mróz R, et al. Efficacy and safety of aclidinium bromide vs placebo and tiotropium in COPD: A phase IIIb study. European Respiratory Society Annual Congress. 2013 Sept 7 11. Barcelona, Spain. 2013;42:4s. PMID: None. KQ7E7d.
36 Beier J, Kirsten AM, Mroz R, et al. Efficacy of aclidinium bromide compared with tiotropium and placebo in patients with moderate to severe COPD: a phase IIIb study. Thorax. 2012;67(suppl 2):A26. PMID: None. KQ7E7d.
37 Beier J, Kirsten AM, Mróz R, et al. Improvement in COPD symptoms with aclidinium bromide vs placebo and tiotropium: A phase IIIb study. European Respiratory Society Annual Congress. 2013 Sept 7 11. Barcelona, Spain. 2013;42:4s. PMID: None. KQ7E7d.
38 Beier J, Kirsten AM, Mroz R, et al. Improvements In COPD symptoms and rescue medication use with aclidinium bromide compared with tiotropium and placebo: a phase IIIb study. American journal of respiratory and critical care medicine. 2013;187:A4276. PMID: None. KQ7E7d.
39 Beier J, Chanez P, Martinot JB, et al. Safety, tolerability and efficacy of indacaterol, a novel once-daily beta(2)-agonist, in patients with COPD: a 28-day randomised, placebo controlled clinical trial. Pulmonary Pharmacology & Therapeutics. 2007;20(6):740-9. KQ7E7d. [pmid: 17088091].
40 Bertens LC, Reitsma JB, van MY, et al. COPD detected with screening: impact on patient management and prognosis. European Respiratory Journal. Dec. 2014;44(6):1571-8. KQ1E3b. [pmid: 24925924].
41 Bhatt SP, Kim YI, Wells JM, et al. FEV(1)/FEV(6) to diagnose airflow obstruction. Comparisons with computed tomography and morbidity indices. Annals of the American Thoracic Society. Mar. 2014;11(3):335-41. KQ3E5a. [pmid: 24450777].
42 Bleecker ER, Meyers DA, Bailey WC, et al. ADRB2 polymorphisms and budesonide/formoterol responses in COPD. Chest. Aug. 2012;142(2):320-8. KQ7E5h. [pmid: 22383665].
43 Bogdan MA, Kudo T, Umemiya M. Efficacy And Safety Of Inhaled Formoterol 4.5 And 9 1/4g Twice Daily In Japanese And European Patients With COPD: Results Of A Phase III Study. American journal of respiratory and critical care medicine. 2010;181:A4494. PMID: None. KQ7E7d.
44 Boggia B, Farinaro E, Grieco L, et al. Burden of smoking and occupational exposure on etiology of chronic obstructive pulmonary disease in workers of Southern Italy. Journal of Occupational & Environmental Medicine. Mar. 2008;50(3):366-70. KQ2E7a. [pmid: 18332787].
45 Booker R. COPD: Prevention, screening and case finding. Practice Nurse. Jun. 13. 2014;44(6):12-6. PMID: None. KQ5aE5a.
46 Bourbeau J, Tan WC, Benedetti A, et al. Canadian Cohort Obstructive Lung Disease (CanCOLD): Fulfilling the need for longitudinal observational studies in COPD. Copd: Journal of Chronic Obstructive Pulmonary Disease. Apr. 2014;11(2):125-32. KQ2E7a. [pmid: 22433011].
47 Bourbeau J, Rouleau MY, Boucher S. Randomised controlled trial of inhaled corticosteroids in patients with chronic obstructive pulmonary disease. Thorax. Jun. 1998;53(6):477-82. KQ7E5h. [pmid: 9713447].
48 Boyd G, Morice AH, Pounsford JC, et al. An evaluation of salmeterol in the treatment of chronic obstructive pulmonary disease (COPD). Eur Respir J. Apr. 1997;10(4):815-21. KQ7E7d. [pmid: 9150318].
49 Braun SR, McKenzie WN, Copeland C, et al. A comparison of the effect of ipratropium and albuterol in the treatment of chronic obstructive airway disease. Arch Intern Med. Mar. 1989;149(3):544-7. KQ7E7d. [pmid: 2521997].
50 Briggs DD Jr, Covelli H, Lapidus R, et al. Improved daytime spirometric efficacy of tiotropium compared with salmeterol in patients with COPD. Pulm Pharmacol Ther. 2005;18(6):397-404. KQ7E7d. [pmid: 16179215].
51 Broekhuizen BD, Sachs A, Janssen K, et al. Does a decision aid help physicians to detect chronic obstructive pulmonary disease?. British Journal of General Practice. Oct. 2011;61(591):e674-e679. KQ2E3b. [pmid: 22152850].
52 Brouillard C, Pepin V, Milot J, et al. Endurance shuttle walking test: responsiveness to salmeterol in COPD. European Respiratory Journal. Mar. 2008;31(3):579-84. KQ7E7d. [pmid: 18057052].
53 Brusasco V, Hodder R, Miravitlles M, et al. Health outcomes following treatment for six months with once daily tiotropium compared with twice daily salmeterol in patients with COPD. Thorax. May. 2003;58(5):399-404. KQ7E5h. [pmid: 12728159].
54 Bruske I, Thiering E, Heinrich J, et al. Biopersistent granular dust and chronic obstructive pulmonary disease: a systematic review and meta-analysis. PLoS One. 2013;8(11):e80977. KQ2E7a. [pmid: 24278358].
55 Buffels J, Degryse J, Decramer M, et al. Spirometry and smoking cessation advice in general practice: a randomised clinical trial. Respir Med. Nov. 2006;100(11):2012-7. KQ5aE4. [pmid: 16580189].
56 Burge PS, Calverley PM, Jones PW, et al. Randomised, double blind, placebo controlled study of fluticasone propionate in patients with moderate to severe chronic obstructive pulmonary disease: the ISOLDE trial. BMJ. May. 13. 2000;320(7245):1297-303. KQ7E5h. [pmid: 10807619].
57 Burgel PR, Paillasseur JL, Dusser D, et al. Tiotropium might improve survival in subjects with COPD at high risk of mortality. Respiratory Research. 2014;15:64. KQ7I1a, KQ8E6. [pmid: 24913266].
58 Calverley P, Pauwels R, Vestbo J, et al. Combined salmeterol and fluticasone in the treatment of chronic obstructive pulmonary disease: a randomised controlled trial. Lancet. Feb. 8. 2003;361(9356):449-56. KQ7E5h. [pmid: 12583942].
59 Calverley PM, Nordyke RJ, Halbert RJ, et al. Development of a population-based screening questionnaire for COPD. Copd: Journal of Chronic Obstructive Pulmonary Disease. Jun. 2005;2(2):225-32. KQ2E7a. [pmid: 17136949].
60 Calverley PM, Boonsawat W, Cseke Z, et al. Maintenance therapy with budesonide and formoterol in chronic obstructive pulmonary disease. Eur Respir J. Dec. 2003;22(6):912-9. KQ7E3a. [pmid: 14680078].
61 Calverley PM, Rennard S, Nelson HS, et al. One-year treatment with mometasone furoate in chronic obstructive pulmonary disease. Respir Res. 2008;9:73. KQ7I1, KQ8E6. [pmid: 19014549].
62 Campbell M, Eliraz A, Johansson G, et al. Formoterol for maintenance and as-needed treatment of chronic obstructive pulmonary disease. Respir Med. Dec. 2005;99(12):1511-20. KQ7E5h. [pmid: 16199148].
63 Canals-Borrajo G, Martinez-Andion B, Ciguenza-Fuster ML, et al. Spirometry for detection of undiagnosed chronic obstructive pulmonary disease in primary care. European Journal of General Practice. Dec. 2010;16(4):215-21. KQ3E7b. [pmid: 20849314].
64 Casaburi R, Mahler DA, Jones PW, et al. A long-term evaluation of once-daily inhaled tiotropium in chronic obstructive pulmonary disease. Eur Respir J. Feb. 2002;19(2):217-24. KQ7E5h. [pmid: 11866001].
65 Casaburi R, Maltais F, Celli B, et al. Aclidinium bromide improves exercise endurance and decreases exertional dyspnoea in patients with COPD. European Respiratory Society Annual Congress. Barcelona, Spain. September 18 22 2010. 5558. PMID: None. KQ7E7d.
66 Casaburi R, Maltais F, Porszasz J, et al. Effects of tiotropium on hyperinflation and treadmill exercise tolerance in mild to moderate chronic obstructive pulmonary disease. Annals of the American Thoracic Society. 2014;11(9):1351-61. KQ7E7d. [pmid: 25289942].
67 Casaburi R, Kukafka D, Cooper CB, et al. Improvement in exercise tolerance with the combination of tiotropium and pulmonary rehabilitation in patients with COPD. Chest. Mar. 2005;127(3):809-17. KQ7E5h. [pmid: 15764761].
68 Casado V, Navarro SM, Alvarez AE, et al. Laryngeal measurements and diagnostic tools for diagnosis of chronic obstructive pulmonary disease. ANN FAM MED. Jan. 2015;13(1):49-52. KQ2E4. [pmid: 25583892].
69 Cazzola M, Rogliani P, Ruggeri P, et al. Chronic treatment with indacaterol and airway response to salbutamol in stable COPD. Respiratory Medicine. Jun. 2013;107(6):848-53. KQ7E5b. [pmid: 23490225].
70 Celli B, Maltais F, Casaburi R, et al. Aclidinium bromide improves resting lung function in patients with moderate to severe COPD. European Respiratory Society Annual Congress. Barcelona, Spain. September 18 22 2010. 1183. PMID: None. KQ7E7d.
71 Celli B, Crater G, Kilbride S, et al. Once-daily umeclidinium/vilanterol 125/25 mug therapy in COPD. Chest. 2014;145:981-91. PMID: None. KQ7E5b. [pmid: 24385182].
72 Celli B, Halpin D, Hepburn R, et al. Symptoms are an important outcome in chronic obstructive pulmonary disease clinical trials: results of a 3-month comparative study using the Breathlessness, Cough and Sputum Scale (BCSS). Respir Med. Jan. 2003;97(Suppl A):S35-S43. KQ7E7d. [pmid: 12564609].
73 Celli BR, Crater G, Kilbride S, et al. A 24-week randomized, double-blind, placebo-controlled study of the efficacy and safety of once-daily umeclidinium/vilanterol 125/25 mcg in COPD. American journal of respiratory and critical care medicine. 2013;187:A2435. PMID: None. KQ7E5h.
74 Chan-Yeung M, Carlsten C. Reasonable alternatives to spirometry for diagnosing chronic obstructive pulmonary disease: is the peak flow meter the answer?. International Journal of Tuberculosis & Lung Disease. Mar. 2009;13(3):279-80. KQ2E7a, KQ3E5a. [pmid: 19275785].
75 Chan CK, Maltais F, Sigouin C, et al. A randomized controlled trial to assess the efficacy of tiotropium in Canadian patients with chronic obstructive pulmonary disease. Can Respir J. Nov. 2007;14(8):465-72. KQ7E5h. [pmid: 18060091].
76 Chapman KR, Beeh KM, Beier J, et al. A blinded evaluation of the efficacy and safety of glycopyrronium, a once-daily long-acting muscarinic antagonist, versus tiotropium, in patients with COPD: the GLOW5 study. BMC Pulmonary Medicine. 2014;14:4. KQ7E7d. [pmid: 24438744].
77 Chapman KR, Bateman ED, Beeh KM, et al. A blinded evaluation of the efficacy and safety of once-daily glycopyrronium via breezhaler® device versus tiotropium in patients with COPD: the GLOW5 study. 7th International Primary Care Respiratory Group World Conference. Athens. 21 24 May, 2014. 2014. OR-066. KQ7E7d.
78 Chapman KR, Rennard SI, Dogra A, et al. Long-term safety and efficacy of indacaterol, a long-acting beta2-agonist, in subjects with COPD: a randomized, placebo-controlled study. Chest. Jul. 2011;140(1):68-75. KQ7E5h. [pmid: 21349928].
79 Chapman KR, Arvidsson P, Chuchalin AG, et al. The addition of salmeterol 50 microg bid to anticholinergic treatment in patients with COPD: a randomized, placebo controlled trial. Chronic obstructive pulmonary disease. Can Respir J. May. 2002;9(3):178-85. KQ7E5h. [pmid: 12068339].
80 Ching SM, Pang YK, Price D, et al. Detection of airflow limitation using a handheld spirometer in a primary care setting. Respirology. 2014. Apr. 7. KQ3E2a. [pmid: 24708063].
81 Choudhury AB, Dawson CM, Kilvington HE, et al. Withdrawal of inhaled corticosteroids in people with COPD in primary care: a randomised controlled trial. Respir Res. 2007;8:93. KQ7E7. [pmid: 18162137].
82 Connolly CK. Peak flow meters still useful but require consistency rather than accuracy. Thorax. Jan. 2004;59(1):82-3. KQ3E5a. [pmid: 14694259].
83 Cooper B. Spirometry standards and FEV1/FVC repeatability. Primary Care Respiratory Journal. Sep. 2010;19(3):292-4. KQ3E5a. [pmid: 20676591].
84 Cooper CB, Celli B, Wise RA, et al. “Treadmill Endurance During 2 Years” Treatment With Tiotropium In Patients With COPD. American journal of respiratory and critical care medicine. 2011;183:A4586. PMID: None. KQ7E5a.
85 Cooper CB, Celli BR, Wise R, et al. Relationship Between Quality Of Life And Exercise Endurance In A Long-Term Study Of Tiotropium In COPD Patients. American journal of respiratory and critical care medicine. 2012;185:A1534. PMID: None. KQ7E5h.
86 Cooper CB, Celli BR, Jardim JR, et al. Treadmill endurance during 2-year treatment with tiotropium in patients with COPD: a randomized trial. Chest. Aug. 2013;144(2):490-7. KQ7E5h. [pmid: 23558890].
87 Cope G. Long-acting medications for chronic obstructive pulmonary disease. British Journal of Healthcare Management. 2015;21(1):18-20. KQ7E5a.
88 Cope S, Zhang J, Williams J, et al. Efficacy of once-daily indacaterol 75 mug relative to alternative bronchodilators in COPD: a study level and a patient level network meta-analysis. BMC Pulm Med. 2012;12:29. KQ7E7d. [pmid: 22732017].
89 D’Elia C, Sechi F. Neltenexine versus carbocysteine in the treatment of exacerbations of mild chronic obstructive pulmonary disease: A randomized, controlled, open-label study. Current Therapeutic Research Clinical and Experimental. 2001;62:851-61. PMID: None. KQ7E7c.
90 D’Urzo A, Kerwin E, Donohue J, et al. Effects of twice-daily aclidinium bromide in COPD patients: A long-term extension of ACCORD-COPD I. European Respiratory Journal: European Respiratory Society Annual Congress. Vienna, Austria. September 1 5 2012. 40:528s. PMID: None. KQ7E5b.
91 D’Urzo A, Mergel V, Leselbaum A, et al. Efficacy and safety of fixed-dose combination aclidinium bromide/formoterol fumarate in patients with COPD: results from the AUGMENT COPD trial. Chest. 2013;144:1025A. PMID: None. KQ7E6.
92 D’Urzo A, Ferguson GT, van Noord JA, et al. Efficacy and safety of once-daily NVA237 in patients with moderate-to-severe COPD: the GLOW1 trial. Respiratory Research. 2011;12:156. KQ7E7c. [pmid: 22151296].
93 D’Urzo A, Kerwin E, Rennard S, et al. Improvements in lung function with twice-daily aclidinium bromide: results of a long-term, phase 3 trial in patients with chronic obstructive pulmonary disease. Chest. 2012;142:740A. PMID: None. KQ7E5b.
94 D’Urzo A, Noord JA, Martin C, et al. Once-daily NVA237 improves symptoms, and reduces COPD exacerbations and associated hospitalisations: The glow1 trial. Thorax Conference: British Thoracic Society Winter Meeting 2011 London United Kingdom Conference Start: 20111207 Conference End: 20111209 Conference Publication. 2011;66:A170. PMID: None. KQ7E7c.
95 D’Urzo A, Kerwin E, Overend T, et al. Once daily glycopyrronium for the treatment of COPD: pooled analysis of the GLOW1 and GLOW2 studies. Current Medical Research & Opinion. Mar. 2014;30(3):493-508. KQ7E7c. [pmid: 24156566].
96 D’Urzo A, Kerwin E, Rennard S, et al. One-year extension study of ACCORD COPD I: safety and efficacy of two doses of twice-daily aclidinium bromide in patients with COPD. Copd: Journal of Chronic Obstructive Pulmonary Disease. Aug. 2013;10(4):500-10. KQ7E5b. [pmid: 23679347].
97 D’Urzo A, Rennard S, Mergel V, et al. The AUGMENT COPD Trial: Efficacy and Safety of a Fixed-Dose Combination of Aclidinium Bromide and Formoterol Fumarate in COPD Patients. Chest. 2014;145:426A. PMID: None. KQ7E6.
98 D’Urzo AD, Rennard SI, Kerwin EM, et al. Efficacy of fixed-dose combination aclidinium bromide/formoterol fumarate on bronchodilation over 1 year: AUGMENT COPD extension trial in patients with moderate to severe COPD (Abstract). American journal of respiratory and critical care medicine. 2014;189:A6006. KQ7E5h.
99 D’Urzo AD, Jugovic P, Jhirad R, et al. Four-year trial of tiotropium in chronic obstructive pulmonary disease. Canadian Family Physician. Aug. 2012;58(8):848-9. KQ7E5a. [pmid: 22893337].
100 D’Urzo AD, Salvo MC, Ramirez RA, et al. In patients with COPD, treatment with a combination of formoterol and ipratropium is more effective than a combination of salbutamol and ipratropium: a 3-week, randomized, double-blind, within-patient, multicenter study. Chest. 2001;119:1347-56. KQ7E7d. [pmid: 11348938].
101 D’Urzo AD, Kerwin EM, Donohue JF, et al. Long-Term Extension Study Of ACCORD COPD I: Effects Of Two Doses Of Twice-Daily Aclidinium Bromide In COPD Patients. American journal of respiratory and critical care medicine. 2012;185:A2913. PMID: None. KQ7E5b.
102 D’Urzo AD, Rennard SI, Kerwin EM, et al. Twice-daily aclidinium bromide/formoterol fumarate fixed-dose combination: lung function improvements in the AUGMENT COPD trial in patients with moderate to severe COPD (Abstract). American journal of respiratory and critical care medicine. 2014;189:A3776. KQ7E5h.
103 D’Urzo T, Ferguson G, Martin C, et al. NVA237 once daily offers rapid and clinically meaningful bronchodilation in COPD patients that is maintained for 24 H: The glow1 trial. Thorax Conference: British Thoracic Society Winter Meeting 2011 London United Kingdom Conference Start: 20111207 Conference End: 20111209 Conference Publication. 2011;66:A170. PMID: None. KQ7E7c.
104 Dahl R, Greefhorst LA, Nowak D, et al. Inhaled formoterol dry powder versus ipratropium bromide in chronic obstructive pulmonary disease. Am J Respir Crit Care Med. Sep. 1. 2001;164(5):778-84. KQ7E7d. [pmid: 11549532].
105 Dal NR, Visconti M, Trevisan F, et al. Erdosteine enhances airway response to salbutamol in patients with mild-to-moderate COPD. Therapeutic Advances in Respiratory Disease. Oct. 2008;2(5):271-7. KQ7E7c. [pmid: 19124377].
106 Dalal AA, Demuro-Mercon C, Lewis S, et al. Validation of alternate modes of administration of the lung function questionnaire (LFQ) in subjects with smoking history. International Journal of COPD. 2010;5:425-34. KQ2E5c. [pmid: 21191437].
107 de MR, Accordini S, Marcon A, et al. Risk factors for chronic obstructive pulmonary disease in a European cohort of young adults. American Journal of Respiratory & Critical Care Medicine. Apr. 1. 2011;183(7):891-7. KQ2E3c. [pmid: 20935112].
108 Decramer M, Maltais F, Feldman G, et al. Dose-related efficacy of GSK573719, a new long-acting muscarinic receptor antagonist (LAMA) offering sustained 24-hour bronchodilation, in COPD. European Respiratory Society Annual Congress. Amsterdam, The Netherlands. September 24 28 2011. 38:150s. PMID: None. KQ7E7d.
109 Decramer M, Rossi A, Lawrence D, et al. Indacaterol therapy in patients with COPD not receiving other maintenance treatment. [Erratum appears in Respir Med. 2013 Jan;107(1):160 Note: Dosage error in article text]. Respiratory Medicine. Dec. 2012;106(12):1706-14. KQ7E5h. [pmid: 23031496].
110 Di Lorenzo G, Morici G, Drago A, et al. Efficacy, tolerability, and effects on quality of life of inhaled salmeterol and oral theophylline in patients with mild-to-moderate chronic obstructive pulmonary disease. Clinical Therapeutics. Nov. 1998;20(6):1130-48. KQ7E7c. [pmid: 9916607].
111 Dirven JA, Muris JW, van Schayck CP. COPD screening in general practice using a telephone questionnaire. Copd: Journal of Chronic Obstructive Pulmonary Disease. Oct. 2010;7(5):352-9. KQ2E4, KQ3E7b. [pmid: 20854050].
112 Dirven JA, Tange HJ, Muris JW, et al. Early detection of COPD in general practice: implementation, workload and socioeconomic status. A mixed methods observational study. Prim Care Respir J. Sep. 2013;22(3):338-43. KQ2I1, KQ4E4. [pmid: 23966213].
113 Dirven JA, Tange HJ, Muris JW, et al. Early detection of COPD in general practice: patient or practice managed? A randomised controlled trial of two strategies in different socioeconomic environments. Primary Care Respiratory Journal. Sep. 2013;22(3):331-7. KQ2E6.
114 Disantostefano RL, Sampson T, Le HV, et al. Risk of pneumonia with inhaled corticosteroid versus long-acting bronchodilator regimens in chronic obstructive pulmonary disease: a new-user cohort study. PLoS ONE. 2014;9(5):e97149. KQ8E5h. [pmid: 24878543].
115 Doherty DE, Kerwin E, Tashkin DP, et al. Combined Mometasone Furoate and Formoterol in Patients With Moderate to Very Severe Chronic Obstructive Pulmonary Disease (COPD): Phase 3 Efficacy and Safety Study. Journal of allergy and clinical immunology. 2012;129:AB75. PMID: None. KQ7E6.
116 Doherty DE, Tashkin DP, Kerwin E, et al. Effects of mometasone furoate/formoterol fumarate fixed-dose combination formulation on chronic obstructive pulmonary disease (COPD): results from a 52-week Phase III trial in subjects with moderate-to-very severe COPD. International Journal of COPD. 2012;7:57-71. KQ7E5h. [pmid: 22334769].
117 Dong YH, Chang CH, Lin Wu FL, et al. Use of inhaled corticosteroids in patients with COPD and the risk of TB and influenza: A systematic review and meta-analysis of randomized controlled trials. a systematic review and meta-analysis of randomized controlled trials. Chest. Jun. 2014;145(6):1286-97. KQ8E5h. [pmid: 24504044].
118 Donner CF, Lusuardi M, Benedetto F, et al. Office spirometry in asthma and COPD: role and feasibility in standard practice. Preliminary data of the “SPACE” Italian study. European Respiratory Journal. 2003;22. Abstract. PMID: None. KQ3E3b.
119 Donner F, Lusuardi M, Benedetto F, et al. General practice and office spirometry in asthma and COPD preliminary data from the prospective randomised comparative SPACE Italian study. European Respiratory Journal. 2004;24:87s. PMID: None. KQ3E3b.
120 Donohue J, Bollu V, Hanania N. Improved health related quality of life outcomes in subjects with moderate to severe COPD treated with nebulized arformoterol tartrate: results from A 52-week trial. Chest. 2013;144:736A. PMID: None. KQ7E5a.
121 Donohue JF, van Noord JA, Bateman ED, et al. A 6-month, placebo-controlled study comparing lung function and health status changes in COPD patients treated with tiotropium or salmeterol. Chest. Jul. 2002;122(1):47-55. KQ7E5h. [pmid: 12114338].
122 Donohue JF, Siler T, Kerwin EM, et al. Efficacy and safety of indacaterol 75 mug once daily in patients with moderate-to-severe COPD: Pooled analysis of two phase III trials. Pharmacotherapy. 2012;32(10):e242-e243. PMID: None. KQ7E7d.
123 Donohue JF, Maleki-Yazdi MR, Kilbride S, et al. Efficacy and safety of once-daily umeclidinium/vilanterol 62.5/25 mcg in COPD. Respiratory Medicine. Oct. 2013;107(10):1538-46. KQ7E5h. [pmid: 23830094].
124 Donohue JF, Maleki-Yazdi MR, Kilbride S, et al. Efficacy and safety of once-daily umeclidinium/vilanterol 62.5/25 mcg in COPD: a randomized, placebo-controlled, 24-week study. American journal of respiratory and critical care medicine. 2013;187:A4275. PMID: None. KQ7E5h.
125 Donohue JF, Parsey MV, Andrews C, et al. Evaluation of the efficacy and safety of levalbuterol in subjects with COPD. Copd: Journal of Chronic Obstructive Pulmonary Disease. Aug. 2006;3(3):125-32. KQ7E7d. [pmid: 17240614].
126 Donohue JF, Hanania NA, Make B, et al. One-year safety and efficacy study of arformoterol tartrate in patients with moderate to severe COPD. Chest. 2014;146(6):1531-42. KQ7E5h. [pmid: 25451347].
127 Down G, Buck H, O’Connor G, et al. Efficacy, tolerability and safety of a range of doses of an orally inhaled, particle engineered, drug-only, suspension of glycopyrronium bromide in male and female patients with moderate or severe chronic obstructive pulmonary disease (COPD) (Abstract). American journal of respiratory and critical care medicine. 2014;189:A6724. KQ7E7d.
128 Drummond MB, Astemborski J, Lambert AA, et al. A randomized study of contingency management and spirometric lung age for motivating smoking cessation among injection drug users. BMC Public Health. 2014;14:761. KQ5aE3. [pmid: 25074396].
129 Dullinger D, Kronenberg R, Niewoehner DE. Efficacy of inhaled metaproterenol and orally-administered theophylline in patients with chronic airflow obstruction. Chest. Feb. 1986;89(2):171-3. KQ7E7d. [pmid: 3510820].
130 Dusser D, Bravo ML, Iacono P. The effect of tiotropium on exacerbations and airflow in patients with COPD. Eur Respir J. Mar. 2006;27(3):547-55. KQ7E4. [pmid: 16507855].
131 Enright P. Does screening for COPD by primary care physicians have the potential to cause more harm than good?. Chest. Apr. 2006;129(4):833-5. KQ1E5a, KQ4E5a. [pmid: 16608923].
132 Ernst P, Saad N, Suissa S. Inhaled corticosteroids in COPD: the clinical evidence. European Respiratory Journal. Feb. 2015;45(2):525-37. KQ7E5c. [pmid: 25537556].
133 Estes TS, Short N, Bowser D, et al. An evidence-based quality improvement perspective for a chronic obstructive pulmonary disease case-finding program. Chron Respir Dis. Jun. 19. 2014;11(3):131-8. KQ2E5c. [pmid: 24948387].
134 Faria AC, Lopes AJ, Jansen JM, et al. Evaluating the forced oscillation technique in the detection of early smoking-induced respiratory changes. Biomedical Engineering Online. 2009;8:22. KQ3E2a. [pmid: 19781078].
135 Faria AC, Costa AA, Lopes AJ, et al. Forced oscillation technique in the detection of smoking-induced respiratory alterations: diagnostic accuracy and comparison with spirometry. Clinics (Sao Paulo, Brazil). 2010;65(12):1295-304. KQ3E2a. [pmid: 21340218].
136 Feldman G, Walker RR, Brooks J, et al. Safety And Tolerability Of The GSK573719/Vilanterol Combination In Patients With COPD. American journal of respiratory and critical care medicine. 2012;185:A2938. PMID: None. KQ7E7d.
137 Ferguson G, Feldman G, Hofbauer P, et al. Lung function efficacy of olodaterol QD delivered via Respimat® in COPD patients: Results from two 48-week studies. European Respiratory Society Annual Congress. 2013 Sept 7 11. Barcelona, Spain. 2013;42:5s. PMID: None. KQ7E6.
138 Fields CL, Byrd RP Jr, Ossorio MA, et al. Cardiac arrhythmias during performance of the flow-volume loop. Chest. Apr. 1993;103(4):1006-9. KQ4E6. [pmid: 8131430].
139 Fogarty C, Hattersley H, Scala L, et al. A Randomized, Double-blind, Placebo-controlled, Multi-center, Two-period Crossover Study To Investigate The Bronchodilatory Effect Of NVA237 50ng Inhaled Once Daily In Patients With COPD. [Abstract]. American journal of respiratory and critical care medicine. 2010;181:A4437. PMID: None. KQ7E7d.
140 Fogarty C, Banerji D, Hattersley H, et al. The bronchodilatory effect of NVA237 inhaled once daily in patients with COPD. [Abstract]. European Respiratory Society Annual Congress. Barcelona, Spain. September 18 22 2010. 1216. PMID: None. KQ7E7d.
141 Fonseca Wald EL, van den Borst B, Gosker HR, et al. Dietary fibre and fatty acids in chronic obstructive pulmonary disease risk and progression: a systematic review. Respirology. 2013. Dec. 24. KQ2E7a. [pmid: 24372903].
142 Frank TL, Frank PI, Cropper JA, et al. Identification of adults with symptoms suggestive of obstructive airways disease: validation of a postal respiratory questionnaire. BMC Family Practice. Apr. 25. 2003;4:5. KQ2E7a. [pmid: 12716458].
143 Frantz S, Nihlen U, Dencker M, et al. Impulse oscillometry may be of value in detecting early manifestations of COPD. Respiratory Medicine. 2012;106(8):1116-23. KQ3E5c. [pmid: 22613172].
144 Freeman D, Nordyke RJ, Isonaka S, et al. Questions for COPD diagnostic screening in a primary care setting. Respiratory Medicine. Oct. 2005;99(10):1311-8. KQ2E3b, KQ3E7b. [pmid: 16140231].
145 Frith P, Thompson P, Wark P, et al. Benefits of dual bronchodilation with QVA149 once daily versus placebo, indacaterol, NVA237 and tiotropium in patients with COPD: the Shine study. Respirology. 2013;18(S4):20. PMID: None. KQ7E6. [pmid: 24188200].
146 Fuhr R, Magnussen H, Ribera A, et al. Efficacy and safety of twice-daily aclidinium bromide 400 μg compared with placebo and tiotropium 18 μg qd in moderate to severe COPD patients. Chest. 2010;138:465A. PMID: None. KQ7E7d.
147 Fujimoto K, Yamazaki H, Ura M. Efficacy of mono-therapy with tiotropium or indacaterol or the combination of the two drugs on dynamic lung hyperinflation and exercise tolerance in copd. Respirology. 2014;19:101. KQ7E5h.
148 Fukuchi Y, Fernandez L, Kuo HP, et al. Efficacy of tiotropium in COPD patients from Asia: a subgroup analysis from the UPLIFT trial. [Erratum appears in Respirology. 2011 Nov;16(8):1281]. Respirology. Jul. 2011;16(5):825-35. KQ7E5h. [pmid: 21539680].
149 Furumoto A, Ohkusa Y, Chen M, et al. Additive effect of pneumococcal vaccine and influenza vaccine on acute exacerbation in patients with chronic lung disease. Vaccine. Aug. 5. 2008;26(33):4284-9. KQ5aE5d. [pmid: 18585831].
150 Gagnon P, Saey D, Provencher S, et al. Walking exercise response to bronchodilation in mild COPD: a randomized trial. Respiratory Medicine. Dec. 2012;106(12):1695-705. KQ7E7d. [pmid: 22999808].
151 Gainet M, Thaon I, Westeel V, et al. Twelve-year longitudinal study of respiratory status in dairy farmers. European Respiratory Journal. Jul. 2007;30(1):97-103. KQ2E7a. [pmid: 17392318].
152 Gan WQ, Man SF, Postma DS, et al. Female smokers beyond the perimenopausal period are at increased risk of chronic obstructive pulmonary disease: a systematic review and meta-analysis. Respiratory Research. 2006;7:52. KQ2E7a. [pmid: 16571126].
153 Garcia-Pachon E. Can pulse oximetry select patients for screening spirometry?. Primary Care Respiratory Journal. Sep. 2004;13(3):155-8. KQ3E3b. [pmid: 16701659].
154 Geake JB, Dabscheck EJ, Wood-Baker R, et al. Indacaterol, a once-daily beta2-agonist, versus twice-daily beta2-agonists or placebo for chronic obstructive pulmonary disease. Cochrane Database of Systematic Reviews. 2015;(1). KQ7E5a, KQ8E5h.
155 Geijer RM, Sachs AP, Verheij TJ, et al. Are patient characteristics helpful in recognizing mild COPD (GOLD I) in daily practice?. Scandinavian Journal of Primary Health Care. Dec. 2006;24(4):237-42. KQ2E7a. [pmid: 17118864].
156 Geijer RM, Sachs AP, Verheij TJ, et al. Incidence and determinants of moderate COPD (GOLD II) in male smokers aged 40–65 years: 5-year follow up. British Journal of General Practice. Sep. 2006;56(530):656-61. KQ2E7a. [pmid: 16953996].
157 Gelb A, Donohue J, D’Urzo A, et al. ACCORD COPD I: Twice-daily aclidinium bromide improves quality of life and dyspnea in COPD patients. European Respiratory Society Annual Congress. Amsterdam, The Netherlands. September 24 28 2011. 38:149s. PMID: None. KQ7E7d.
158 Gelb A, D’Urzo A, Tashkin D, et al. Effects of aclidinium bromide in patients with chronic obstructive pulmonary disease: Clinically significant improvements in health status in two 1-year studies. Chest. 2012;142:691A. PMID: None. KQ7E5b.
159 Gelb AF, Make BJ, Tashkin DP, et al. Long-Term Efficacy And Safety Of Twice-Daily Aclidinium Bromide In COPD Patients: A One-Year Study. American journal of respiratory and critical care medicine. 2012;185:A2256. PMID: None. KQ7E5b.
160 Glaab T, Vogelmeier C, Buhl R, et al. Prevention of COPD exacerbations with tiotropium versus salmeterol: Pooled analysis from clinical studies. American journal of respiratory and critical care medicine. 2011;183. KQ7E5h.
161 Godoy I, Tanni SE, Coelho LS, et al. Smoking cessation program as a tool for the early diagnosis of chronic obstructive pulmonary disease. Jornal Brasileiro De Pneumologia: Publicacao Oficial Da Sociedade Brasileira De Pneumologia E Tisilogia. May. 2007;33(3):282-6. KQ2E7a, KQ5aE2a. [pmid: 17906789].
162 Gorse GJ, O’connor TZ, Young SL, et al. Impact of a winter respiratory virus season on patients with COPD and association with influenza vaccination. Chest. Oct. 2006;130(4):1109-16. KQ5bE5d. [pmid: 17035445].
163 Guenette JA, Raghavan N, Harris-McAllister V, et al. Effect of adjunct fluticasone propionate on airway physiology during rest and exercise in COPD. Respiratory Medicine. Dec. 2011;105(12):1836-45. KQ7E7d. [pmid: 21917440].
164 Guyatt GH, Townsend M, Nogradi S, et al. Acute response to bronchodilator. An imperfect guide for bronchodilator therapy in chronic airflow limitation. Arch Intern Med. Sep. 1988;148(9):1949-52. KQ7E7d. [pmid: 3046537].
165 Guyatt GH, Townsend M, Pugsley SO, et al. Bronchodilators in chronic air-flow limitation. Effects on airway function, exercise capacity, and quality of life. Am Rev Respir Dis. May. 1987;135(5):1069-74. KQ7E7d. [pmid: 3579005].
166 Guyatt GH, Townsend M, Keller JL, et al. Should study subjects see their previous responses: data from a randomized control trial. J Clin Epidemiol. 1989;42(9):913-20. KQ7E7d. [pmid: 2778469].
167 Hanania NA, Feldman G, Zachgo W, et al. Dose-related efficacy of vilanterol trifenatate (VI) in COPD. European Respiratory Society Annual Congress. Barcelona, Spain. September 18 22 2010. 1227. PMID: None. KQ7E7d.
168 Hanania NA, Mannino DM, Yawn BP, et al. Predicting risk of airflow obstruction in primary care: Validation of the lung function questionnaire (LFQ). Respiratory Medicine. Aug. 2010;104(8):1160-70. KQ2I1, KQ3E5c. [pmid: 20226647].
169 Hanania NA, Darken P, Horstman D, et al. The efficacy and safety of fluticasone propionate (250 microg)/salmeterol (50 microg) combined in the Diskus inhaler for the treatment of COPD. Chest. Sep. 2003;124(3):834-43. KQ7E5h. [pmid: 12970006].
170 Hanrahan JP, Grogan DR, Baumgartner RA, et al. Arrhythmias in patients with chronic obstructive pulmonary disease (COPD): occurrence frequency and the effect of treatment with the inhaled long-acting beta2-agonists arformoterol and salmeterol. Medicine. Nov. 2008;87(6):319-28. KQ7E7d. [pmid: 19011503].
171 Hansen NC, May O. Domiciliary nebulized terbutaline in severe chronic airways obstruction. Eur Respir J. Apr. 1990;3(4):463-4. KQ7E7d. [pmid: 2365041].
172 Harber P, Tashkin DP, Simmons M, et al. Effect of occupational exposures on decline of lung function in early chronic obstructive pulmonary disease. American Journal of Respiratory & Critical Care Medicine. Nov. 15. 2007;176(10):994-1000. KQ7E6, KQ5aE5d. [pmid: 17626912].
173 Hardie JA, Buist AS, Vollmer WM, et al. Risk of over-diagnosis of COPD in asymptomatic elderly never-smokers. Eur Respir J. Nov. 2002;20(5):1117-22. KQ4E2b. [pmid: 12449163].
174 Haroon S, Adab P, Griffin C, et al. Case finding for chronic obstructive pulmonary disease in primary care: a pilot randomised controlled trial. British Journal of General Practice. Jan. 2013;63(606):e55-e62. KQ2E6. [pmid: 23336474].
175 Hetherington J, Coutts R, Davison K. An evaluation of a novel biomarker feedback intervention on smoking cessation: A pilot study. Journal of Smoking Cessation. 2012;7:80-8. PMID: None. KQ5aE5i.
176 Higgins BG, Powell RM, Cooper S, et al. Effect of salbutamol and ipratropium bromide on airway calibre and bronchial reactivity in asthma and chronic bronchitis. Eur Respir J. Apr. 1991;4(4):415-20. KQ7E5i. [pmid: 1830277].
177 Hilberink SR, Jacobs JE, Bottema BJ, et al. Smoking cessation in patients with COPD in daily general practice (SMOCC): six months’ results. Preventive Medicine. Nov. 2005;41(5–6):822-7. KQ5aE5f. [pmid: 16203030].
178 Hill K, Goldstein RS, Guyatt GH, et al. Prevalence and underdiagnosis of chronic obstructive pulmonary disease among patients at risk in primary care. CMAJ Canadian Medical Association Journal. Apr. 20. 2010;182(7):673-8. KQ2E7a, KQ3E7b. [pmid: 20371646].
179 Hiller FC, Alderfer V, Goldman M. Long-term use of Viozan (sibenadet HCl) in patients with chronic obstructive pulmonary disease: results of a 1-year study. Respir Med. Jan. 2003;97(Suppl A):S45-S52. KQ7E5h. [pmid: 12564610].
180 Hnizdo E. The value of periodic spirometry for early recognition of long-term excessive lung function decline in individuals. Journal of Occupational & Environmental Medicine. Dec. 2012;54(12):1506-12. KQ2E7a, KQ3E7b. [pmid: 23114387].
181 Humerfelt S, Eide GE, Kvale G, et al. Effectiveness of postal smoking cessation advice: a randomized controlled trial in young men with reduced FEV1 and asbestos exposure. Eur Respir J. Feb. 1998;11(2):284-90. KQ5aE5f. [pmid: 9551726].
182 Ichinose M, Aizawa H, Fukuchi Y, et al. Patient-reported outcomes (PROs) and reliever use in Japanese and European patients with chronic obstructive pulmonary disease receiving formoterol 4.5 and 9 microg twice daily: Results of the OCEAN phase III study. European Respiratory Society Annual Congress. 2010 Sep 18 22. Barcelona. 2010:4591. 4591. PMID: None. KQ7E7d.
183 Ichinose M, Nakamura H, Shijubo N, et al. Tolerability and efficacy of budesonide/formoterol via TurbuhalerĀ® vs standard treatment in Japanese patients with moderate to severe COPD: 52-week phase III study results. European Respiratory Journal: European Respiratory Society Annual Congress. Vienna, Austria. September 1 5 2012. 40:392s. PMID: None. KQ7E5b.
184 Ikeda A, Nishimura K, Koyama H, et al. Bronchodilating effects of combined therapy with clinical dosages of ipratropium bromide and salbutamol for stable COPD: comparison with ipratropium bromide alone. Chest. Feb. 1995;107(2):401-5. KQ7E7d. [pmid: 7842768].
185 Ikeda A, Nishimura K, Koyama H, et al. Comparative dose-response study of three anticholinergic agents and fenoterol using a metered dose inhaler in patients with chronic obstructive pulmonary disease. Thorax. Jan. 1995;50(1):62-6. KQ7E7d. [pmid: 7886652].
186 Irizar-Aramburu MI, Martinez-Eizaguirre JM, Pacheco-Bravo P, et al. Effectiveness of spirometry as a motivational tool for smoking cessation: a clinical trial, the ESPIMOAT study. BMC Family Practice. 2013;14:185. KQ5aE5a. [pmid: 24308728].
187 Jackson H, Hubbard R. Detecting chronic obstructive pulmonary disease using peak flow rate: cross sectional survey. BMJ. Sep. 20. 2003;327(7416):653-4. KQ3E5g. [pmid: 14500437].
188 Jaeschke R, Guyatt GH, Singer J, et al. Mechanism of bronchodilator effect in chronic airflow limitation. CMAJ. Jan. 1. 1991;144(1):35-9. KQ7E7d. [pmid: 1984814].
189 Jayaram L, Wong C, McAuley S, et al. Combined therapy with tiotropium and formoterol in chronic obstructive pulmonary disease: effect on the 6-minute walk test. Copd: Journal of Chronic Obstructive Pulmonary Disease. Aug. 2013;10(4):466-72. KQ7E7d. [pmid: 23875741].
190 Jiang YP, Zhao YF, Yang Y. Effect of seretide on quality of life in COPD: Measured with COPD assessment test. Respirology Conference: 16th Congress of the Asian Pacific Society of Respirology Shanghai China Conference Start: 20111103 Conference End: 20111106 Conference Publication. 2011;16:99. PMID: None. KQ7E2a.
191 Jithoo A, Enright PL, Burney P, et al. Case-finding options for COPD: results from the Burden of Obstructive Lung Disease study. European Respiratory Journal. Mar. 2013;41(3):548-55. KQ2E7a, KQ3I1, KQ4I1. [pmid: 22743668].
192 Johannessen A, Omenaas ER, Bakke PS, et al. Implications of reversibility testing on prevalence and risk factors for chronic obstructive pulmonary disease: a community study. Thorax. Oct. 2005;60(10):842-7. KQ3E3c, KQ4E3c. [pmid: 16085729].
193 Johannessen A, Eagan TM, Omenaas ER, et al. Socioeconomic risk factors for lung function decline in a general population. European Respiratory Journal. Sep. 2010;36(3):480-7. KQ2E6. [pmid: 20150201].
194 Johansson G, Lindberg A, Romberg K, et al. Bronchodilator efficacy of tiotropium in patients with mild to moderate COPD. Primary Care Respiratory Journal. Sep. 2008;17(3):169-75. KQ7E7d.
195 Jones PW, Agusti A, Bateman ED, et al. Aclidinium bromide in patients with chronic obstructive pulmonary disease: Improvement in health status in ATTAIN. Chest. 2011;140:547A. PMID: None. KQ7E5h.
196 Jones PW, Singh D, Agusti A, et al. Aclidinium bromide reduces COPD exacerbations as defined by healthcare utilisation and EXACT: Results from ATTAIN. European Respiratory Journal: European Respiratory Society Annual Congress. Vienna, Austria. September 1 5 2012. 40:9s. PMID: None. KQ7E5h.
197 Jones PW, Donohue JF, Nedelman J, et al. Correlating changes in lung function with patient outcomes in chronic obstructive pulmonary disease: a pooled analysis. Respir Res. 2011;12:161. KQ7E6. [pmid: 22206353].
198 Jones PW, Harding G, Berry P, et al. Development and first validation of the COPD Assessment Test. Eur Respir J. Sep. 2009;34(3):648-54. KQ2E3b. [pmid: 19720809].
199 Jones PW, Rennard SI, Agusti A, et al. Efficacy and safety of once-daily aclidinium in chronic obstructive pulmonary disease. Respiratory Research. 2011;12:55. KQ7E5h. [pmid: 21518460].
200 Jones PW, Singh D, Bateman ED, et al. Efficacy and safety of twice-daily aclidinium bromide in COPD patients: the ATTAIN study. European Respiratory Journal. Oct. 2012;40(4):830-6. KQ7E5h. [pmid: 22441743].
201 Jones PW, Anderson JA, Calverley PM, et al. Health status in the TORCH study of COPD: treatment efficacy and other determinants of change. Respiratory Research. 2011;12:71. KQ7E5h. [pmid: 21627828].
202 Jones PW, Mahler DA, Gale R, et al. Profiling the effects of indacaterol on dyspnoea and health status in patients with COPD. Respiratory Medicine. Jun. 2011;105(6):892-9. KQ7E5h. [pmid: 21397482].
203 Jones PW, Bosh TK. Quality of life changes in COPD patients treated with salmeterol. Am J Respir Crit Care Med. Apr. 1997;155(4):1283-9. KQ7E7d. [pmid: 9105068].
204 Jones PW, Singh D, Bateman ED, et al. The effect of aclidinium/formoterol fixed-dose combination on COPD symptoms and health status in patients with COPD: results from the ACLIFORM/COPD study (Abstract). American journal of respiratory and critical care medicine. 2014;189:A3764. KQ7E5h.
205 Jones RC, Dickson-Spillmann M, Mather MJ, et al. Accuracy of diagnostic registers and management of chronic obstructive pulmonary disease: the Devon primary care audit. Respiratory Research. 2008;9:62. KQ3E6. [pmid: 18710575].
206 Jordan RE, Lam KB, Cheng KK, et al. Case finding for chronic obstructive pulmonary disease: a model for optimising a targeted approach. Thorax. Jun. 2010;65(6):492-8. KQ2E5a. [pmid: 20522845].
207 Jordan RE, Adab P, Jowett S, et al. TargetCOPD: a pragmatic randomised controlled trial of targeted case finding for COPD versus routine practice in primary care: protocol. BMC Pulmonary Medicine. 2014;14:157. KQ2E6, KQ3E6. [pmid: 25280869].
208 Kaminsky DA, Marcy TW, Solomon LJ, et al. Spirometry to motivate quit smoking attempts: Use in the pulmonary function testing lab. American journal of respiratory and critical care medicine. 2011;183. KQ5aE4.
209 Kanehara M, Yokoyama A, Tomoda Y, et al. Anti-inflammatory effects and clinical efficacy of theophylline and tulobuterol in mild-to-moderate chronic obstructive pulmonary disease. Pulmonary Pharmacology & Therapeutics. Dec. 2008;21(6):874-8. KQ7E7c. [pmid: 18983928].
210 Kanner RE, Anthonisen NR, Connett JE. American journal of respiratory and critical care medicine. 2001;164(3):358-64. KQ5aE5d, KQ7E6. [pmid: 11500333].
211 Kanner RE, Connett JE, Williams DE, et al. Effects of randomized assignment to a smoking cessation intervention and changes in smoking habits on respiratory symptoms in smokers with early chronic obstructive pulmonary disease: the Lung Health Study. Am J Med. Apr. 1999;106(4):410-6. KQ5ae5d, KQ7E6. [pmid: 10225243].
212 Kanner RE, Connett JE, Altose MD, et al. Gender difference in airway hyperresponsiveness in smokers with mild COPD. The Lung Health Study. Am J Respir Crit Care Med. Oct. 1994;150(4):956-61. KQ5ae5d, KQ7E6. [pmid: 7921469].
213 Karbasi-Afshar R, Aslani J, Ghanei M. Efficacy and safety of inhaler steroids in COPD patients: Systematic review and meta-analysis of randomized placebo-controlled trials. Caspian Journal of Internal Medicine. 2014;5(3):130-6. KQ7E5a, KQ8E5h. [pmid: 25202439].
214 Kardos P, Wencker M, Glaab T, et al. Impact of salmeterol/fluticasone propionate versus salmeterol on exacerbations in severe chronic obstructive pulmonary disease. Am J Respir Crit Care Med. Jan. 15. 2007;175(2):144-9. KQ7E5b. [pmid: 17053207].
215 Karner C, Chong J, Poole P. Tiotropium versus placebo for chronic obstructive pulmonary disease. [Update of Cochrane Database Syst Rev. 2012;7:CD009285; PMID: 22786525]. Cochrane Database of Systematic Reviews. 2014;7:CD009285. KQ7E5a, KQ8E5h. [pmid: 25046211].
216 Kato B, Gulsvik A, Vollmer W, et al. Can spirometric norms be set using pre- or post- bronchodilator test results in older people?. Respiratory Research. 2012;13:102. KQ3E3b. [pmid: 23157675].
217 Kato M, D’Urzo A, Martin C, et al. NVA237 once daily improves symptoms and reduces exacerbations of COPD and associated hospitalizations: The glow1 trial. Respirology Conference: 16th Congress of the Asian Pacific Society of Respirology Shanghai China Conference Start: 20111103 Conference End: 20111106 Conference Publication. 2011;16:105-6. PMID: None. KQ7E7c.
218 Kawayama T, Minakata Y, Matsunaga K, et al. Validation of symptom-based COPD questionnaires in Japanese subjects. Respirology. May. 2008;13(3):420-6. KQ2E4. [pmid: 18399866].
219 Kelleher D, Preece A, Mehta R, et al. Phase II study of once-daily GSK573719 inhalation powder, a new long-acting muscarinic antagonist, in patients with chronic obstructive pulmonary disease (COPD). European Respiratory Society Annual Congress. Amsterdam, The Netherlands. September 24 28 2011. 38:140s. PMID: None. KQ7E7d.
220 Kempsford R, Norris V, Siederer S. GW642444, a Novel Inhaled Long-acting Beta2 Adrenoceptor Agonist (LABA), At Single Doses Of 25, 50 And 100mcg, Is Well Tolerated And Demonstrates Prolonged Bronchodilation In COPD Patients. American journal of respiratory and critical care medicine. 2010;181:A4447. PMID: None. KQ7E7d.
221 Kerwin E, Rennard S, Gelb A, et al. ACCORD COPD I: Improvements in nighttime symptoms and rescue medication use in COPD with twice-daily aclidinium bromide. European Respiratory Society Annual Congress. Amsterdam, The Netherlands. September 24 28 2011. 38:149s. PMID: None. KQ7E7d.
222 Kerwin E, Tashkin DP, Matiz-Bueno CE, et al. Clinical Efficacy and Safety of Combined Mometasone Furoate and Formoterol in Patients With Moderate to Very Severe Chronic Obstructive Pulmonary Disease (COPD). Journal of allergy and clinical immunology. 2012;129(2):AB201. PMID: None. KQ7E5h.
223 Kerwin E, Hebert J, Gallagher N, et al. Efficacy and safety of NVA237 versus placebo and tiotropium in patients with COPD: the GLOW2 study. European Respiratory Journal. Nov. 2012;40(5):1106-14. KQ7E7c. [pmid: 23060624].
224 Kerwin E, D’Urzo A, Gelb A, et al. Efficacy and safety of twice-daily aclidinium bromide in patients with COPD: results from ACCORD COPD 1. Chest. 2010;138:469A. PMID: None. KQ7E7d. [pmid: 20822982].
225 Kerwin E, Shah P, Singletary K, et al. Efficacy and safety of umeclidinium added to fluticasone propionate/salmeterol in patients with COPD: results of a randomized, double-blind study (Abstract). American journal of respiratory and critical care medicine. 2014;189:A3769. KQ7E7d.
226 Kerwin E, D’Urzo A, Rekeda L, et al. Twice-daily aclidinium bromide 400 mcg in elderly patients with chronic obstructive pulmonary disease (COPD): Pooled efficacy and safety results. Journal of the American Geriatrics Society. 2014;62:S38. PMID: None. KQ7E5h.
227 Kerwin E, D’Urzo A, Gelb A, et al. Twice-daily aclidinium bromide in COPD patients: Efficacy and safety results from ACCORD COPD I. European Respiratory Society Annual Congress. Barcelona, Spain. September 18 22 2010. 1235. PMID: None. KQ7E7d.
228 Kerwin EM, Scott-Wilson C, Sanford L, et al. A randomised trial of fluticasone furoate/vilanterol (50/25 mug; 100/25 mug) on lung function in COPD. Respiratory Medicine. Apr. 2013;107(4):560-9. KQ7E5h. [pmid: 23352226].
229 Kerwin EM, Meli J, Peckitt C, et al. Efficacy And Safety Of Indacaterol 75 G Once Daily In Patients With Moderate-To-Severe COPD. American journal of respiratory and critical care medicine. 2011;183:A1595. PMID: None. KQ7E7d.
230 Kerwin EM, Scott WC, Sanford L, et al. Lung function effects and safety of fluticasone furoate (FF)/vilanterol (VI) in patients with COPD: Low-mid dose assessment. [Abstract]. European Respiratory Journal: European Respiratory Society Annual Congress. Vienna, Austria. September 1 5 2012. 40:545s. PMID: None. KQ7E5h.
231 Kerwin EM, Hebert J, Pedinoff A, et al. NVA237 Once Daily Provides Rapid And Sustained Bronchodilation In COPD Patients, With Efficacy Similar To Tiotropium: The GLOW2 Trial. [Abstract]. American journal of respiratory and critical care medicine. 2012;185:A2920. PMID: None. KQ7E7c.
232 Kerwin EM, Pedinoff A, Casale TB, et al. NVA237 Once Daily Reduces COPD Exacerbations With Similar Rates To Tiotropium: The GLOW2 Trial. American journal of respiratory and critical care medicine. 2012;185:A2255. PMID: None. KQ7E7c.
233 Kida K, Wakabayashi R, Mizuuchi T, et al. Screening for suspected chronic obstructive pulmonary disease with an eleven-item pre-interview questionnaire (11-Q). Internal Medicine. 2006;45(21):1201-7. KQ2E5a, KQ3E5a. [pmid: 17139118].
234 Klock LE, Miller TD, Morris AH, et al. A comparative study of atropine sulfate and isoproterenol hydrochloride in chronic bronchitis. Am Rev Respir Dis. Sep. 1975;112(3):371-6. KQ7E7d. [pmid: 1099948].
235 Koch A, Pizzichini E, Hamilton A, et al. Lung function efficacy and symptomatic benefit of olodaterol once daily delivered via Respimat versus placebo and formoterol twice daily in patients with GOLD 2–4 COPD: results from two replicate 48-week studies. International Journal of COPD. 2014;9:697-714. KQ7E5h. [pmid: 25045258].
236 Kojima S, Sakakibara H, Motani S, et al. Incidence of chronic obstructive pulmonary disease, and the relationship between age and smoking in a Japanese population. Journal of Epidemiology. Mar. 2007;17(2):54-60. KQ2E7a. [pmid: 17420613].
237 Korn S, Gebner C, Schurmann W, et al. Once-daily QVA149 improves dyspnea, quality of life and reduces the rate of exacerbations compared to tiotropium plus formoterol in COPD patients: the QUANTIFY study (Abstract). American journal of respiratory and critical care medicine. 2014;189:A5982. KQ7E5b.
238 Koskela RS, Mutanen P, Sorsa JA, et al. Respiratory disease and cardiovascular morbidity. Occupational & Environmental Medicine. Sep. 2005;62(9):650-5. KQ2E7a. [pmid: 16109822].
239 Kotz D, Simpson CR, Viechtbauer W, et al. Development and validation of a model to predict the 10-year risk of general practitioner-recorded COPD. NPJ Prim Care Respir Med. 2014;24:14011. KQ2E7a. [pmid: 24841327].
240 Kotz D, van Schayck OC. Interpreting the diagnostic accuracy of tools for early detection of COPD. Primary Care Respiratory Journal. Jun. 2011;20(2):113-5. KQ2E5a, KQ3E5a. [pmid: 21597660].
241 Kotz D, Wesseling G, Aveyard P, et al. Smoking cessation and development of respiratory health in smokers screened with normal spirometry. Respiratory Medicine. Feb. 2011;105(2):243-9. KQ5aE5a, KQ6E4. [pmid: 20850286].
242 Kotz D, Huibers MJH, West RJ, et al. The effect of confrontational counseling on smoking cessation in smokers with COPD. European Respiratory Society Annual Congress. Berlin, Germany. October 4 8 2008. E444. KQ5aE6.
243 Kryger M, Wang-Weigand S, Zhang J, et al. Effect of ramelteon, a selective MT(1)/MT (2)-receptor agonist, on respiration during sleep in mild to moderate COPD. Sleep & Breathing. Aug. 2008;12(3):243-50. KQ7E7c. [pmid: 18060441].
244 Kryger M, Roth T, Wang-Weigand S, et al. The effects of ramelteon on respiration during sleep in subjects with moderate to severe chronic obstructive pulmonary disease. Sleep & Breathing. Mar. 2009;13(1):79-84. KQ7E7c. [pmid: 18584227].
245 Kurashima K, Takayanagi N, Sato N, et al. High resolution CT and bronchial reversibility test for diagnosing COPD. Respirology. Jun. 2005;10(3):316-22. KQ3E3b. [pmid: 15955144].
246 Lamprecht B, Schirnhofer L, Tiefenbacher F, et al. Six-second spirometry for detection of airway obstruction: a population-based study in Austria. Am J Respir Crit Care Med. Sep. 1. 2007;176(5):460-4. PMID:. KQ3E2b, KQ4E2b. [pmid: 17556719].
247 Lapperre TS, Snoeck-Stroband JB, Gosman MM, et al. Effect of fluticasone with and without salmeterol on pulmonary outcomes in chronic obstructive pulmonary disease: a randomized trial. Ann Intern Med. Oct. 20. 2009;151(8):517-27. KQ7I1, KQ8E6. [pmid: 19841453].
248 Lau AC, Ip MS, Lai CK, et al. Variability of the prevalence of undiagnosed airflow obstruction in smokers using different diagnostic criteria. Chest. Jan. 2008;133(1):42-8. KQ3E2a. [pmid: 17989159].
249 Laursen LC, Lindqvist A, Hepburn T, et al. The role of the novel D2/beta2-agonist, Viozan (sibenadet HCl), in the treatment of symptoms of chronic obstructive pulmonary disease: results of a large-scale clinical investigation. Respir Med. Jan. 2003;97(Suppl A):S23-S33. KQ7E7d. [pmid: 12564608].
250 Lee DK. Pre- and post-bronchodilator spirometric values and the degree of reversibility in patients with COPD. European Respiratory Journal. Aug. 2004;24(2):332-3. KQ3E5a, KQ7E7d. [pmid: 15332409].
251 Lehmann S, Bakke PS, Eide GE, et al. Clinical data discriminating between adults with positive and negative results on bronchodilator testing. International Journal of Tuberculosis & Lung Disease. Feb. 2008;12(2):205-13. KQ3E3d, KQ2E3d. [pmid: 18230255].
252 Li VC, Kim YJ, Ewart CK, et al. Effects of physician counseling on the smoking behavior of asbestos-exposed workers. Prev Med. Sep. 1984;13(5):462-76. KQ5aE2b. [pmid: 6527988].
253 Liesker JJ, Van DV V, Meysman M, et al. Effects of formoterol (Oxis Turbuhaler) and ipratropium on exercise capacity in patients with COPD. Respir Med. Aug. 2002;96(8):559-66. KQ7E7d. [pmid: 12195835].
254 Light RW, Summer WR, Luchsinger PC. Response of patients with chronic obstructive lung disease to the regular administration of nebulized isoproterenol. A double-blind crossover study. Chest. Jun. 1975;67(6):634-9. KQ7E7d. [pmid: 1092531].
255 Llordes M, Jaen A, Almagro P, et al. Prevalence, Risk Factors and Diagnostic Accuracy of COPD Among Smokers in Primary Care. COPD. 2014. Dec. 4. KQ2E7a.
256 Lundback B, Lindberg A, Lindstrom M, et al. Not 15 but 50% of smokers develop COPD?--Report from the Obstructive Lung Disease in Northern Sweden Studies. Respiratory Medicine. Feb. 2003;97(2):115-22. KQ2E3b, KQ3E3b. [pmid: 12587960].
257 Lusuardi M, Donner CF, Benedetto F, et al. A randomised controlled trial on office spirometry in asthma and COPD in standard general practice: the SPACE Italian study. European Respiratory Journal. 2005;26. PMID: None. KQ1E6, KQ2E7a, KQ3E7b.
258 Lusuardi M, De BF, Paggiaro P, et al. A randomized controlled trial on office spirometry in asthma and COPD in standard general practice: data from spirometry in Asthma and COPD: a comparative evaluation Italian study. Chest. Apr. 2006;129(4):844-52. KQ3E7b. [pmid: 16608929].
259 Magnussen H, Ribera LA, Kirsten AM, et al. Efficacy And Safety Of Aclidinium Bromide 400 {micro}g BID Compared With Placebo And Tiotropium In Patients With Moderate To Severe COPD. American journal of respiratory and critical care medicine. 2010;181:A4440. PMID: None. KQ7E7d.
260 Magnussen H, Watz H, Zimmermann I, et al. Peak inspiratory flow through the Genuair inhaler in patients with moderate or severe COPD. Respiratory Medicine. Dec. 2009;103(12):1832-7. KQ7E6. [pmid: 19651504].
261 Mahboub B, Alzaabi A, Soriano JB, et al. Case-finding of chronic obstructive pulmonary disease with questionnaire, peak flow measurements and spirometry: a cross-sectional study. BMC Research Notes. 2014;7(1):241. KQ2E7a, KQ3E5g. [pmid: 24739210].
262 Mahler DA, Wire P, Horstman D, et al. Effectiveness of fluticasone propionate and salmeterol combination delivered via the Diskus device in the treatment of chronic obstructive pulmonary disease. Am J Respir Crit Care Med. Oct. 15. 2002;166(8):1084-91. KQ7E5h. [pmid: 12379552].
263 Mahler DA, Donohue JF, Barbee RA, et al. Efficacy of salmeterol xinafoate in the treatment of COPD. Chest. Apr. 1999;115(4):957-65. KQ7E7d. [pmid: 10208192].
264 Mahler DA, Dunn LJ, Gotfried MH, et al. Indacaterol 75 mug once daily improves health status in patients with moderate-to-severe COPD: Responder analysis. Pharmacotherapy. 2012;32(10):e242. KQ7E7d.
265 Mahler DA, Decramer M, D’Urzo AD, et al. Superior lung function with once-daily QVA149 translates into improvements in patient-reported breathlessness compared with placebo and tiotropium in COPD patients: the BLAZE study. American journal of respiratory and critical care medicine. 2013;187:A6070. PMID: None. KQ7E7d.
266 Maleki-Yazdi MR, Kaelin T, Richard N, et al. Efficacy and safety of umeclidinium/vilanterol 62.5/25 mcg and tiotropium 18 mcg in chronic obstructive pulmonary disease: Results of a 24-week, randomized, controlled trial. Respiratory Medicine. 2014;108:1752-60. KQ7E5b. [pmid: 25458157].
267 Maltais F, Celli B, Porszasz J, et al. Aclidinium Bromide Improves Exercise Endurance, Dyspnea And Inspiratory Capacity In Patients With Moderate To Severe COPD. American journal of respiratory and critical care medicine. 2010;181:A4428. PMID: None. KQ7E7d.
268 Maltais F, Mahler DA, Pepin V, et al. Effect Of Fluticasone-Salmeterol Combination+Tiotropium Vs Tiotropium On Exercise Tolerance, The Cause Of Exercise Limitation And Lung Volumes In COPD. American journal of respiratory and critical care medicine. 2012;185:A2267. PMID: None. KQ7E7d.
269 Maltais F, Mahler DA, Pepin V, et al. Effect of fluticasone propionate/salmeterol plus tiotropium versus tiotropium on walking endurance in COPD. European Respiratory Journal. Aug. 2013;42(2):539-41. KQ7E7d. [pmid: 23904549].
270 Maltais F, Singh S, Donald AC, et al. Effects of a combination of umeclidinium/vilanterol on exercise endurance in patients with chronic obstructive pulmonary disease: two randomized, double-blind clinical trials. Therapeutic Advances in Respiratory Disease. 2014;8:169-81. KQ7E7d. [pmid: 25452426].
271 Maltais F, Singh S, Donald A, et al. Effects of a combination of vilanterol and umeclidinium on exercise endurance in subjects with COPD: Two randomised clinical trials. European Respiratory Society Annual Congress. 2013 Sept 7 11. Barcelona, Spain. 2013;42:145s. PMID: None. KQ7E7d.
272 Mannino DM, Sonia BA, Vollmer WM. Chronic obstructive pulmonary disease in the older adult: what defines abnormal lung function?. Thorax. Mar. 2007;62(3):237-41. KQ2E7a, KQ4E6. [pmid: 17090573].
273 Martin-Lujan F, Pinol-Moreso JL, Martin-Vergara N, et al. Effectiveness of a structured motivational intervention including smoking cessation advice and spirometry information in the primary care setting: the ESPITAP study. BMC Public Health. 2011;11:859. KQ5aE5a. [pmid: 22078490].
274 Martinez F, Boscia J, Feldman G, et al. Lung function effects and safety of fluticasone furoate (FF)/vilanterol (VI) in patients with COPD: Mid-high dose assessment. European Respiratory Journal: European Respiratory Society Annual Congress. Vienna, Austria. September 1 5 2012. 40:527s. PMID: None. KQ7E5h.
275 Martinez FJ, Boscia J, Feldman G, et al. Fluticasone furoate/vilanterol (100/25; 200/25 mug) improves lung function in COPD: a randomised trial. Respiratory Medicine. Apr. 2013;107(4):550-9. KQ7E5h. [pmid: 23332861].
276 Matera MG, Rogliani P, Cazzola M. Indacaterol for the treatment of chronic obstructive pulmonary disease. Expert Opinion on Pharmacotherapy. Jan. 2015;16(1):107-15. KQ7E5a. [pmid: 25418284].
277 Mintz ML, Yawn BP, Mannino DM, et al. Prevalence of airway obstruction assessed by lung function questionnaire. Mayo Clinic Proceedings. May. 2011;86(5):375-81. KQ2I1, KQ3E6, KQ4I1. [pmid: 21531880].
278 Mirabelli MC, London SJ, Charles LE, et al. Occupation and three-year incidence of respiratory symptoms and lung function decline: the ARIC Study. Respiratory Research. 2012;13:24. KQ2E7a. [pmid: 22433119].
279 Mohamed Hoesein FA, Zanen P, Sachs AP, et al. Spirometric thresholds for diagnosing COPD: 0.70 or LLN, pre- or post-dilator values?. Copd: Journal of Chronic Obstructive Pulmonary Disease. Aug. 2012;9(4):338-43. KQ3E3b. [pmid: 22489910].
280 Morice AH, Celli B, Kesten S, et al. COPD in young patients: a pre-specified analysis of the four-year trial of tiotropium (UPLIFT). Respir Med. Nov. 2010;104(11):1659-67. KQ7E5h. [pmid: 20724131].
281 Mowls DS, Cheruvu VK, Zullo MD. Influenza vaccination in adults with chronic obstructive pulmonary disease: the impact of a diagnostic breathing test on vaccination rates. PLoS One. 2013;8(6):e67600. KQ5bE5f. [pmid: 23840746].
282 Mullerova H, Wedzicha J, Soriano JB, et al. Validation of a chronic obstructive pulmonary disease screening questionnaire for population surveys. Respiratory Medicine. Jan. 2004;98(1):78-83. KQ2E3b, KQ7E6. [pmid: 14959817].
283 Murgia N, Brisman J, Claesson A, et al. Validity of a questionnaire-based diagnosis of chronic obstructive pulmonary disease in a general population-based study. BMC Pulmonary Medicine. 2014;14:49. KQ2E3b. [pmid: 24650114].
284 Naik S, Rebello J, Morde N, et al. Evaluation of the efficacy and safety of two formulations of Ipratropium bromide HFA pMDI in patients with mild to moderate chronic obstructive pulmonary disease (COPD). European Respiratory Society Annual Congress. Barcelona, Spain. September 18 22 2010. 1318. PMID: None. KQ7E7d.
285 Nelson HS, Gross NJ, Levine B, et al. Cardiac safety profile of nebulized formoterol in adults with COPD: a 12-week, multicenter, randomized, double- blind, double-dummy, placebo- and active-controlled trial. Clinical Therapeutics. 2007;29(10):2167-78. KQ7E7d. [pmid: 18042473].
286 Nelson SB, LaVange LM, Nie Y, et al. Questionnaires and pocket spirometers provide an alternative approach for COPD screening in the general population. Chest. Aug. 2012;142(2):358-66. KQ3E5g. [pmid: 22194590].
287 Neuner JS, Knecht MI, Stey SC, et al. Acceptance and practicability of a visual communication tool in smoking cessation counselling: A randomised controlled trial. Primary Care Respiratory Journal. 2013;22(4):412-6. KQ5aE7. [pmid: 24105269].
288 Ni H, Soe Z, Moe S. Aclidinium bromide for stable chronic obstructive pulmonary disease. Cochrane Database of Systematic Reviews. Sep. 2014;(9). KQ7E5a, KQ8E5h.
289 Nieri D, Costa F, Malagrino L, et al. Effects Of Acute Administration Of Bronchodilators And Inhaled Corticosteroids On The Exercise Tolerance In Patients With Chronic Obstructive Pulmonary Disease. American journal of respiratory and critical care medicine. 2010;181:A4462. PMID: None. KQ7E7d.
290 Niewoehner DE, Rice K, Cote C, et al. Prevention of exacerbations of chronic obstructive pulmonary disease with tiotropium, a once-daily inhaled anticholinergic bronchodilator: a randomized trial. Ann Intern Med. Sep. 6. 2005;143(5):317-26. KQ7I1, KQ8E6. [pmid: 16144890].
291 Niewoehner DE, Lokhnygina Y, Rice K, et al. Risk indexes for exacerbations and hospitalizations due to CO PD. Chest. Jan. 2007;131(1):20-8. KQ7E6. [pmid: 17218552].
292 Nishimura K, Nakayasu K, Kobayashi A, et al. Case identification of subjects with airflow limitations using the handheld spirometer “Hi-Checker”: comparison against an electronic desktop spirometer. Copd: Journal of Chronic Obstructive Pulmonary Disease. Dec. 2011;8(6):450-5. KQ3E5g. [pmid: 22149406].
293 O’Donnell DE, Casaburi R, Swales J, et al. Effect Of Indacaterol On Exercise Endurance In Patients With Moderate-to-severe COPD. American journal of respiratory and critical care medicine. 2010;181:A4431. PMID: None. KQ7E7d.
294 O’Donnell DE, Voduc N, Fitzpatrick M, et al. Effect of salmeterol on the ventilatory response to exercise in chronic obstructive pulmonary disease. Eur Respir J. Jul. 2004;24(1):86-94. KQ7E7d. [pmid: 15293609].
295 O’Donnell DE, Laveneziana P, Ora J, et al. Evaluation of acute bronchodilator reversibility in patients with symptoms of GOLD stage I COPD. Thorax. Mar. 2009;64(3):216-23. KQ7E7D. [pmid: 19052054].
296 O’Donnell DE, Webb KA. Impact Of Inhaled Fluticasone/Salmeterol Combination On Respiratory Physiology In Patients With Milder COPD. [Abstract]. American journal of respiratory and critical care medicine. 2011;183:A1594. PMID: None. KQ7E7d.
297 O’Donnell DE, Preston M, Webb KA. Improvement In Exertional Dyspnea And Cycle Exercise Endurance With Short-Term Administration Of Inhaled Corticosteroid Monotherapy In Patients With COPD. [Abstract]. American journal of respiratory and critical care medicine. 2011;183:A3097. PMID: None. KQ7E7d.
298 Oba Y, Lone NA. Comparative efficacy of long-acting muscarinic antagonists in preventing COPD exacerbations: a network meta-analysis and meta-regression. Ther Adv Respir Dis. 2015. Jan. 12. KQ7E5h.
299 Ohar JA, Sadeghnejad A, Meyers DA, et al. Do symptoms predict COPD in smokers?. Chest. Jun. 2010;137(6):1345-53. KQ2E7a. [pmid: 20363841].
300 Ojedokun J, Keane S, O’Connor K. Journal of General Practice. 2013;1(3). PMID: None. KQ5aE4.
301 Ojedokun J, Keane S, O’Connor K. The effect of lung age feedback with brief smoking cessation advice during routine consultations on smoking habit-Know2quit multicenter randomized control trial. European Journal of General Practice. 2013;19:39. PMID: None. KQ5aE5a.
302 Oostveen E, Claus L, Backer W. Spirometry in general practice (Un)reliability of some handheld spirometers. [Abstract]. Proceedings of the American Thoracic Society. 2006:A496. PMID: None. KQ3E3b.
303 Orevillo C, Rose E, Strom S, et al. Glycopyrrolate MDI demonstrates comparable efficacy and safety to tiotropium DPI in a randomized, double-blind, placebo-controlled phase 2b study in patients with COPD. [Abstract]. European Respiratory Society Annual Congress. 2011 September 24 28. Amsterdam, The Netherlands. 2011;38:724s. PMID: None. KQ7E7d.
304 Oshaug K, Halvorsen PA, Melbye H. Should chest examination be reinstated in the early diagnosis of chronic obstructive pulmonary disease?. International Journal of COPD. 2013;8:369-77. KQ3E3b, KQ2E3b. [pmid: 23983462].
305 Overend T, Lu Y, Dolker M, et al. Dose Response Of NVA237, A Long-acting Muscarinic Antagonist For The Treatment Of COPD. [Abstract]. American journal of respiratory and critical care medicine. 2010;181:A4422. PMID: None. KQ7E7d.
306 Ozol D, Aysan T, Solak ZA, et al. The effect of inhaled corticosteroids on bronchoalveolar lavage cells and IL-8 levels in stable COPD patients. Respir Med. Dec. 2005;99(12):1494-500. KQ7E2a. [pmid: 15946834].
307 Paggiaro PL, Dahle R, Bakran I, et al. Multicentre randomised placebo-controlled trial of inhaled fluticasone propionate in patients with chronic obstructive pulmonary disease. International COPD Study Group. Lancet. Mar. 14. 1998;351(9105):773-80. KQ7E5h. [pmid: 9519948].
308 Parkes G, Pluddemann A, Heneghan C, et al. Spirometry in primary care for case finding and management of chronic obstructive pulmonary disease primary care diagnostic technology update. British Journal of General Practice. Nov. 2011;61(592):698-9. KQ1E5a, KQ3E5a. [pmid: 22054331].
309 Pedersen OF. FEV6: a shortcut in spirometry?. European Respiratory Journal. Feb. 2006;27(2):245-7. KQ3E5a. [pmid: 16452574].
310 Petty TL. Harm from spirometry?. Chest. Nov. 2006;130(5):1629-30. KQ4E5a. [pmid: 17099055].
311 Pinto LM, Gupta N, Tan W, et al. Derivation of normative data for the COPD assessment test (CAT). Respiratory Research. 2014;15:68. KQ2E6. [pmid: 24957783].
312 Powrie DJ, Wilkinson TM, Donaldson GC, et al. Effect of tiotropium on sputum and serum inflammatory markers and exacerbations in COPD. Eur Respir J. Sep. 2007;30(3):472-8. KQ7E5h. [pmid: 17504798].
313 Rabe KF, Timmer W, Sagkriotis A, et al. Comparison of a combination of tiotropium plus formoterol to salmeterol plus fluticasone in moderate COPD. Chest. Aug. 2008;134(2):255-62. KQ7E7d. [pmid: 18403672].
314 Reisner C, Gotfried M, Denenberg MB, et al. Low doses of Pearl Therapeutics’ LAMA/LABA Combination MDI (GFF MDI, PT003) provide superior bronchodilation compared to components and to open-label spiriva handihaler in a randomized, double-blind, placebo-controlled phase IIb study in patients with COPD. American journal of respiratory and critical care medicine. 2013;187:A2434. PMID: None. KQ7E7d.
315 Reisner C, Fogarty C, Spangenthal S, et al. Novel Combination Of Glycopyrrolate And Formoterol MDI (GFF-MDI) Provides Superior Bronchodilation Compared To Its Components Administered Alone, Tiotropium DPI, And Formoterol DPI In A Randomized, Double-Blind, Placebo-Controlled Phase 2b Study In Patients With COPD. [Abstract]. American journal of respiratory and critical care medicine. 2011;183:A6435. PMID: None. KQ7E7d.
316 Reisner C, Rennard SI, Fogarty C, et al. Pearl Therapeutics’ Combination LAMA/LABA MDI (GFF-MDI, PT003) Provides A Significant Benefit On Home Peak Expiratory Flow Rate (PEFR) And Reduces The Need For Rescue Albuterol Use Compared To Its Components Administered Alone, Spiriva(R) Handihaler(R), And Foradil(R) Aerolizer(R) In A Randomized, Double-Blind, Placebo-Controlled Phase 2b Study In Patients With COPD. [Abstract]. American journal of respiratory and critical care medicine. 2012;185:A2259. PMID: None. KQ7E7d.
317 Reisner C, Kerwin EM, Spangenthal S, et al. Pearl Therapeutics’ LAMA MDI (GP MDI, PT001) provides a significant benefit in forced expiratory volume in 1 second (FEV1) in doses ranging from 36 Ć‚Āμg to 4.6 Ć‚Āμg compared to atrovent HFA, and placebo in a randomized, double-blind, placebo-controlled phase IIb study in patients with COPD. American journal of respiratory and critical care medicine. 2013;187:A4267. PMID: None. KQ7E7d.
318 Renkema TE, Schouten JP, Koeter GH, et al. Effects of long-term treatment with corticosteroids in COPD. Chest. May. 1996;109(5):1156-62. KQ7E5i. [pmid: 8625660].
319 Rennard SI, Fogarty C, Ferguson GT, et al. A Novel Glycopyrrolate Metered Dose Inhaler Formulation Demonstrates Superior Bronchodilator Efficacy Relative To Placebo And Comparable Efficacy And Safety To Spiriva(R) Handihaler(R) In Patients With COPD. [Abstract]. American journal of respiratory and critical care medicine. 2010;181:A4450. PMID: None. KQ7E7d.
320 Rennard SI, Tashkin DP, McElhattan J, et al. Efficacy and tolerability of budesonide/formoterol in one hydrofluoroalkane pressurized metered-dose inhaler in patients with chronic obstructive pulmonary disease: results from a 1-year randomized controlled clinical trial. Drugs. 2009;69(5):549-65. KQ7E5h. [pmid: 19368417].
321 Rennard SI, Fogarty C, Kelsen S, et al. The safety and efficacy of infliximab in moderate to severe chronic obstructive pulmonary disease. American Journal of Respiratory & Critical Care Medicine. May. 1. 2007;175(9):926-34. KQ7E7c. [pmid: 17290043].
322 Rennard SI, Anderson W, ZuWallack R, et al. Use of a long-acting inhaled beta2-adrenergic agonist, salmeterol xinafoate, in patients with chronic obstructive pulmonary disease. Am J Respir Crit Care Med. Apr. 2001;163(5):1087-92. KQ7E7d. [pmid: 11316640].
323 Richmond R, Webster I. Evaluation of general practitioners’ use of a smoking intervention programme. Int J Epidemiol. Sep. 1985;14(3):396-401. KQ5aE5f. [pmid: 4055206].
324 Ripoll J, Girauta H, Ramos M, et al. Clinical trial on the efficacy of exhaled carbon monoxide measurement in smoking cessation in primary health care. BMC Public Health. 2012;12:322. KQ5aE7. [pmid: 22551017].
325 Ristovska R, Stavric K. COPD screening: validation of the IPAG questionnaire and PiKo-6R flow meter in the primary care setting. [Abstract]. 7th International Primary Care Respiratory Group World Conference. Athens. 21 24 May, 2014. 2014. OLB003-OLBSAT. KQ2E2a, KQ3E2a.
326 Roche N, Gaillat J, Garre M, et al. Acute respiratory illness as a trigger for detecting chronic bronchitis in adults at risk of COPD: a primary care survey. Prim Care Respir J. Dec. 2010;19(4):371-7. KQ2E3b, KQ3E3b. [pmid: 20842324].
327 Rose G, Hamilton PJ. A randomised controlled trial of the effect on middle-aged men of advice to stop smoking. J Epidemiol Community Health. Dec. 1978;32(4):275-81. KQ5aE5f. [pmid: 370171].
328 Rossi A, Kristufek P, Levine BE, et al. Comparison of the efficacy, tolerability, and safety of formoterol dry powder and oral, slow-release theophylline in the treatment of COPD. Chest. Apr. 2002;121(4):1058-69. KQ7E5h. [pmid: 11948033].
329 Rytila P, Helin T, Kinnula V. The use of microspirometry in detecting lowered FEV1 values in current or former cigarette smokers. Primary Care Respiratory Journal. Dec. 2008;17(4):232-7. KQ3E4. [pmid: 18830521].
330 Sahin D, Ubeyli ED, Ilbay G, et al. Diagnosis of airway obstruction or restrictive spirometric patterns by multiclass support vector machines. Journal of Medical Systems. Oct. 2010;34(5):967-73. KQ3E6. [pmid: 20703611].
331 Salameh P, Khayat G, Waked M. Could symptoms and risk factors diagnose COPD? Development of a Diagnosis Score for COPD. Clinical Epidemiology. 2012;4:247-55. KQ2E2a, KQ3E2a. [pmid: 23071403].
332 Sansores RH, Ramirez-Venegas A, Hernandez-Zenteno R, et al. Prevalence and diagnosis of chronic obstructive pulmonary disease among smokers at risk. A comparative study of case-finding vs. screening strategies. Respiratory Medicine. Apr. 2013;107(4):580-6. KQ1E2a, KQ2E2a. [pmid: 23313037].
333 Santra CK. Treatment of moderate chronic obstructive pulmonary disease (stable) with doxofylline compared with slow release theophylline--a multicentre trial. Journal of the Indian Medical Association. Dec. 2008;106(12):791-2. KQ7E7c. [pmid: 19370950].
334 Sarac P, Sayiner A. Comparison of the efficacy and safety of long-acting anticholinergic and a combination of inhaled steroids and long-acting beta-2 agonist in moderate chronic obstructive pulmonary disease. [Abstract]. European Respiratory Society Annual Congress. 2013 Sept 7 11. Barcelona, Spain. 2013;42:879s. PMID: None. KQ7E2a.
335 Satake M, Shioya T, Takahashi H, et al. Inhibitory effect of SABA on exercise dynamic lung hyperinflation during 6-min walk test in stable COPD patients. European Respiratory Society Annual Congress. Amsterdam, The Netherlands. September 24 28 2011. 38:225s. PMID: None. KQ7E7d.
336 Scanlon PD, Connett JE, Waller LA, et al. Smoking cessation and lung function in mild-to-moderate chronic obstructive pulmonary disease. The Lung Health Study. Am J Respir Crit Care Med. Feb. 2000;161(2 Pt 1):381-90. KQ5ae5d, KQ7E6. [pmid: 10673175].
337 Schermer T, Chavannes N, Dekhuijzen R, et al. Fluticasone and N-acetylcysteine in primary care patients with COPD or chronic bronchitis. Respir Med. Apr. 2009;103(4):542-51. KQ7E3d. [pmid: 19138505].
338 Schermer TR, Smeele IJ, Thoonen BP, et al. Current clinical guideline definitions of airflow obstruction and COPD overdiagnosis in primary care. European Respiratory Journal. Oct. 2008;32(4):945-52. KQ3E2b. [pmid: 18550607].
339 Schirnhofer L, Lamprecht B, Firlei N, et al. Using targeted spirometry to reduce non-diagnosed chronic obstructive pulmonary disease. Respiration. 2011;81(6):476-82. KQ2E7a. [pmid: 20720402].
340 Schneider A, Dinant GJ, Maag I, et al. The added value of C-reactive protein to clinical signs and symptoms in patients with obstructive airway disease: results of a diagnostic study in primary care. BMC Family Practice. 2006;7:28. KQ3E3b. [pmid: 16670014].
341 Segnan N, Ponti A, Battista RN, et al. A randomized trial of smoking cessation interventions in general practice in Italy. Cancer Causes Control. Jul. 1991;2(4):239-46. KQ5aE4. [pmid: 1873454].
342 Senderovitz T, Vestbo J, Frandsen J, et al. Steroid reversibility test followed by inhaled budesonide or placebo in outpatients with stable chronic obstructive pulmonary disease. The Danish Society of Respiratory Medicine. Respir Med. Oct. 1999;93(10):715-8. KQ7E6. [pmid: 10581660].
343 Setoguchi Y, Izumi S, Hanada G, et al. The effects and safety of standard therapy for COPD patients who were not previously receiving maintenance treatment (Abstract). American journal of respiratory and critical care medicine. 2014;189:A3024. KQ7E5h, KQ8E5h.
344 Shah SS, Johnston D, Woodcock AA, et al. Breathlessness and exercise tolerance in chronic airflow obstruction: 2-hourly versus 4-hourly salbutamol by inhalation. Curr Med Res Opin. 1983;8(5):345-9. KQ7E7d. [pmid: 6340975].
345 Shaker SB, Dirksen A, Ulrik CS, et al. The effect of inhaled corticosteroids on the development of emphysema in smokers assessed by annual computed tomography. COPD. Apr. 2009;6(2):104-11. KQ7E5h. [pmid: 19378223].
346 Siler T, Gotfried M, Kianifard F, et al. Efficacy and tolerability of once-daily indacaterol 75 mcg in patients with chronic obstructive pulmonary disease in subgroups defined by age, sex, severity of airflow limitation, and smoking status. Journal of the American Pharmacists Association: JAPhA. 2013;53:e107-e108. PMID: None. KQ7E7d.
347 Silins RA, Marlin GE. Evaluation of domiciliary treatment with terbutaline by wet nebulisation in patients with chronic bronchitis and emphysema. Aust N Z J Med. Apr. 1985;15(2):230-4. KQ7E7d. [pmid: 3896217].
348 Sin DD, Man SF, Marciniuk DD, et al. The effects of fluticasone with or without salmeterol on systemic biomarkers of inflammation in chronic obstructive pulmonary disease. American Journal of Respiratory & Critical Care Medicine. Jun. 1. 2008;177(11):1207-14. KQ7E7d. [pmid: 18310480].
349 Singh D, Jones PW, Bateman ED, et al. Attain: Twice-daily aclidinium bromide in patients with moderate to severe chronic obstructive pulmonary disease. Thorax Conference: British Thoracic Society Winter Meeting 2011 London United Kingdom Conference Start: 20111207 Conference End: 20111209 Conference Publication. 2011;66:A171-A172. PMID: None. KQ7E5h.
350 Singh D, Leaker B, Tutuncu A. Efficacy and safety of nebulized glycopyrrolate (EP-101) for administration using high efficiency nebulizer in patients with COPD. [Abstract]. European Respiratory Society Annual Congress. Amsterdam, The Netherlands. September 24 28 2011. 38:147s. PMID: None. KQ7E7d.
351 Singh D, Jones P, Bateman E, et al. Evaluation of the Efficacy and Safety of Two Doses of Aclidinium and Formoterol in Fixed-Dose Combination in Patients With COPD: The ACLIFORM Study. Chest. 2014;145:375A. PMID: None. KQ7E6.
352 Singh D, Bateman ED, Jones PW, et al. The ATTAIN study: Bronchodilatory effect of aclidinium bromide in chronic obstructive pulmonary disease (COPD). [Abstract]. European Respiratory Society Annual Congress. Amsterdam, The Netherlands. September 24 28 2011. 38:149s. PMID: None. KQ7E6.
353 Sliwinski P, Perng DW, Chuchalin A, et al. Efficacy and safety of once-daily aclidinium bromide 200 mg in combination with formoterol in patients with COPD. [Abstract]. Thorax. 2010;65:A136. PMID: None. KQ7E7d.
354 Smidth M, Sokolowski I, Kaersvang L, et al. Developing an algorithm to identify people with Chronic Obstructive Pulmonary Disease (COPD) using administrative data. BMC Medical Informatics & Decision Making. 2012;12:38. KQ2E3b. [pmid: 22616576].
355 Soler N, Martin A, Ballester E, et al. Correlation between pulmonary function data recorded in clinical history and pulmonary function data measured by a portable device in COPD patients treated in primary care. [Abstract]. American Thoracic Society 2005 International Conference. May 20 25. San Diego, California. 2005:C36. PMID: None. KQ3E6.
356 Sridevi K, MohanaRao V, Vijaya N, et al. Safety and efficacy of Tiotropium bromide in bronchial asthma and COPD patients, cross over studies by placebo. International Journal of Life Sciences Biotechnology and Pharma Research. 2012;1:250-62. PMID: None. KQ7E2a.
357 Stanley AJ, Hasan I, Crockett AJ, et al. Validation of the COPD Diagnostic Questionnaire in an Australian general practice cohort: a cross-sectional study. Primary Care Respiratory Journal. Mar. 2014;23(1):92-7. KQ2I1, KQ3E7b, KQ4I1. [pmid: 24570082].
358 Stockley RA, Chopra N, Rice L. Addition of salmeterol to existing treatment in patients with COPD: a 12 month study. Thorax. Feb. 2006;61(2):122-8. KQ7E5h. [pmid: 16443706].
359 Stratelis G, Molstad S, Jakobsson P, et al. Diagnosis of COPD combined with brief smoking cessation advice increases smoking cessation rate in comparison with those with normal lung function. [Abstract]. European Respiratory Journal. 2005;26. Abstract. PMID: None. KQ5aE3a.
360 Stratelis G, Molstad S, Jakobsson P, et al. Diagnosis of COPD combined with brief smoking cessation advice increases smoking cessation rate in comparison with those with normal lung function. [Abstract]. Primary Care Respiratory Journal. 2006;15:210. PMID: None. KQ5aE3a.
361 Stratelis G, Molstad S, Jakobsson P, et al. The impact of repeated spirometry and smoking cessation advice on smokers with mild COPD. Scandinavian Journal of Primary Health Care. Sep. 2006;24(3):133-9. KQ5aE3a. [pmid: 16923621].
362 Straus SE, McAlister FA, Sackett DL, et al. Accuracy of history, wheezing, and forced expiratory time in the diagnosis of chronic obstructive pulmonary disease. Journal of General Internal Medicine. Sep. 2002;17(9):684-8. KQ2E3b, KQ3E3b. [pmid: 12220364].
363 Sundblad BM, Larsson K, Nathell L. Lung function testing influences the attitude toward smoking cessation. Nicotine & Tobacco Research. Jan. 2010;12(1):37-42. KQ5aE5a. [pmid: 19926685].
364 Swanney MP, Jensen RL, Crichton DA, et al. FEV(6) is an acceptable surrogate for FVC in the spirometric diagnosis of airway obstruction and restriction. American Journal of Respiratory & Critical Care Medicine. Sep. 2000;162(3:Pt 1):t-9. KQ3E7b. [pmid: 10988105].
365 Szafranski W, Cukier A, Ramirez A, et al. Efficacy and safety of budesonide/formoterol in the management of chronic obstructive pulmonary disease. Eur Respir J. Jan. 2003;21(1):74-81. KQ7E5h. [pmid: 12570112].
366 Tandon MK, Kailis SG. Bronchodilator treatment for partially reversible chronic obstructive airways disease. Thorax. Apr. 1991;46(4):248-51. KQ7E7d. [pmid: 2038732].
367 Tashkin D, Celli B, Kesten S, et al. Effect of tiotropium in men and women with COPD: results of the 4-year UPLIFT trial. Respiratory Medicine. Oct. 2010;104(10):1495-504. KQ7E5h. [pmid: 20418083].
368 Tashkin D, Rennard S, Uryniak T, et al. Efficacy outcomes with budesonide/formoterol pressurized metered-dose inhaler (BUD/FM pMDI) according to global initiative for chronic obstructive lung disease (GOLD) classification at baseline in patients with chronic obstructive pulmonary disease (COPD). Chest. 2013:144. PMID: None. KQ7E6.
369 Tashkin D, Doherty D, Kerwin E, et al. The effect of mometasone furoate/formoterol combination therapy on Chronic Obstructive Pulmonary Disease (COPD) exacerbations: Results from two phase three trials in subjects with moderate to very severe COPD. Chest Conference: CHEST 2011 Honolulu, HI United States Conference Start: 20111022 Conference End: 20111026 Conference Publication. 2011;140:549A. PMID: None. KQ7E5h.
370 Tashkin DP, Ashutosh K, Bleecker ER, et al. Comparison of the anticholinergic bronchodilator ipratropium bromide with metaproterenol in chronic obstructive pulmonary disease. A 90-day multi-center study. Am J Med. Nov. 14. 1986;81(5A):81-90. KQ7E7d. [pmid: 2947465].
371 Tashkin DP, Doherty DE, Kerwin E, et al. Efficacy and safety characteristics of mometasone furoate/formoterol fumarate fixed-dose combination in subjects with moderate to very severe COPD: findings from pooled analysis of two randomized, 52-week placebo-controlled trials. International Journal of COPD. 2012;7:73-86. KQ7E5h. [pmid: 22334770].
372 Tashkin DP, Doherty DE, Kerwin E, et al. Efficacy and safety of a fixed-dose combination of mometasone furoate and formoterol fumarate in subjects with moderate to very severe COPD: results from a 52-week Phase III trial. [Erratum appears in Int J Chron Obstruct Pulmon Dis. 2012;7:765]. International Journal of COPD. 2012;7:43-55. KQ7E5h. [pmid: 22334768].
373 Tashkin DP, Rennard SI, Martin P, et al. Efficacy and safety of budesonide and formoterol in one pressurized metered-dose inhaler in patients with moderate to very severe chronic obstructive pulmonary disease: results of a 6-month randomized clinical trial. Drugs. 2008;68(14):1975-2000. KQ7E5h. [pmid: 18778120].
374 Tashkin DP. Impact of tiotropium on the course of moderate-to-very severe chronic obstructive pulmonary disease: the UPLIFT trial. [Review] [51 refs]. Expert Review of Respiratory Medicine. Jun. 2010;4(3):279-89. KQ7E5a. [pmid: 20524910].
375 Tashkin DP, Celli B, Kesten S, et al. Long-term efficacy of tiotropium in relation to smoking status in the UPLIFT trial. The European respiratory journal. 2010;35(5):287-94. KQ7E5h. [pmid: 19717481].
376 Tashkin DP, Altose MD, Connett JE, et al. Methacholine reactivity predicts changes in lung function over time in smokers with early chronic obstructive pulmonary disease. The Lung Health Study Research Group. Am J Respir Crit Care Med. Jun. 1996;153(6 Pt 1):1802-11. KQ5ae5d, KQ7E6. [pmid: 8665038].
377 Tashkin DP, Celli B, Kesten S, et al. Reduced reporting of respiratory failure in the UPLIFT trial. American journal of respiratory and critical care medicine. 2010:181. KQ7E5h. [pmid: 19833826].
378 Tashkin DP, Altose MD, Bleecker ER, et al. The lung health study: airway responsiveness to inhaled methacholine in smokers with mild to moderate airflow limitation. The Lung Health Study Research Group. Am Rev Respir Dis. Feb. 1992;145(2 Pt 1):301-10. KQ5aE5d, KQ7E6. [pmid: 1736734].
379 Taylor DR, Buick B, Kinney C, et al. The efficacy of orally administered theophylline, inhaled salbutamol, and a combination of the two as chronic therapy in the management of chronic bronchitis with reversible air-flow obstruction. Am Rev Respir Dis. May. 1985;131(5):747-51. KQ7E7d. [pmid: 4003919].
380 Teramoto S, Matsuse T, Sudo E, et al. Long-term effects of inhaled anticholinergic drug on lung function, dyspnea, and exercise capacity in patients with chronic obstructive pulmonary disease. Intern Med. Oct. 1996;35(10):772-8. KQ7E5h. [pmid: 8933184].
381 Theerthakarai R, Khan MA. Spirometry in the diagnosis of small airways obstruction. Chest. Mar. 2000;117(3):922-3. KQ3E5a. [pmid: 10713036].
382 Thorn J, Tilling B, Lisspers K, et al. Improved prediction of COPD in at-risk patients using lung function pre-screening in primary care: a real-life study and cost-effectiveness analysis. Primary Care Respiratory Journal. Jun. 2012;21(2):159-66. KQ2E7a, KQ3I1, KQ4I1. [pmid: 22270480].
383 Tian J, Zhou Y, Cui J, et al. Peak expiratory flow as a screening tool to detect airflow obstruction in a primary health care setting. International Journal of Tuberculosis & Lung Disease. May. 2012;16(5):674-80. KQ2E2a, KQ3E2a. [pmid: 22409956].
384 Tonnel AB, Perez T, Grosbois JM, et al. Effect of tiotropium on health-related quality of life as a primary efficacy endpoint in COPD. Int J Chron Obstruct Pulmon Dis. 2008;3(2):301-10. KQ7I1, KQ8E6. [pmid: 18686739].
385 Trivedi R, Richard N, Mehta R, et al. Umeclidinium in patients with COPD: A randomised, placebo-controlled study. European Respiratory Journal. 2014;43(1):72-81. KQ7E7d. [pmid: 23949963].
386 Troosters T, Celli B, Kesten S, et al. Effectiveness of combination therapy with tiotropium in COPD. A secondary analysis of the UPLIFT trial. [Abstract]. Primary Care Respiratory Journal. 2010;19:A13. PMID: None. KQ7E5h.
387 Troosters T, Celli B, Lystig T, et al. Tiotropium as a first maintenance drug in COPD: secondary analysis of the UPLIFT trial. European Respiratory Journal. Jul. 2010;36(1):65-73. KQ7E5h. [pmid: 20185426].
388 Tzani P, Crisafulli E, Nicolini G, et al. Reduction in air trapping and dyspnea with an extrafine combination of beclomethasone and formoterol in COPD. [Abstract]. European Respiratory Society Annual Congress. Barcelona, Spain. September 18 22 2010. 1204. PMID: None. KQ7E7d.
389 van den Bemt L, Wouters BC, Grootens J, et al. Diagnostic accuracy of pre-bronchodilator FEV1/FEV6 from microspirometry to detect airflow obstruction in primary care: a randomised cross-sectional study. NPJ Primary Care Respiratory Medicine. 2014;24:14033. KQ3E3b. [pmid: 25119686].
390 van der Valk P, Monninkhof E, van der Palen J, et al. Effect of discontinuation of inhaled corticosteroids in patients with chronic obstructive pulmonary disease: the COPE study. Am J Respir Crit Care Med. Nov. 15. 2002;166(10):1358-63. KQ7E1. [pmid: 12406823].
391 van Dijk WD. Does spirometry still measure up in the diagnosis of COPD?. Chest. Jan. 2013;143(1):276-7. KQ3E5a. [pmid: 23276864].
392 Van Durme YM, Verhamme KM, Stijnen T, et al. Prevalence, incidence, and lifetime risk for the development of COPD in the elderly: the Rotterdam study. Chest. Feb. 2009;135(2):368-77. KQ2E7a. [pmid: 19201711].
393 van Grunsven P, Schermer T, Akkermans R, et al. Short- and long-term efficacy of fluticasone propionate in subjects with early signs and symptoms of chronic obstructive pulmonary disease. Results of the DIMCA study. Respiratory Medicine. Dec. 2003;97(12):1303-12. KQ7E3d. [pmid: 14682412].
394 van Grunsven PM, Schayck CP, Deuveren M, et al. Compliance during long-term treatment with fluticasone propionate in subjects with early signs of asthma or chronic obstructive pulmonary disease (COPD): results of the Detection, Intervention, and Monitoring Program of COPD and Asthma (DIMCA) Study. Journal of Asthma. 2000;37(3):225-34. KQ7E3d. [pmid: 10831147].
395 van Noord JA, Bantje TA, Eland ME, et al. A randomised controlled comparison of tiotropium nd ipratropium in the treatment of chronic obstructive pulmonary disease. The Dutch Tiotropium Study Group. Thorax. Apr. 2000;55(4):289-94. KQ7E7d. [pmid: 10722768].
396 van Noord JA, de Munck DR, Bantje TA, et al. Long-term treatment of chronic obstructive pulmonary disease with salmeterol and the additive effect of ipratropium. Eur Respir J. May. 2000;15(5):878-85. KQ7E7d. [pmid: 10853852].
397 van Schayck CP, Halbert RJ, Nordyke RJ, et al. Comparison of existing symptom-based questionnaires for identifying COPD in the general practice setting. Respirology. Jun. 2005;10(3):323-33. KQ2E5c. [pmid: 15955145].
398 van Schayck CP, Loozen JM, Wagena E, et al. Detecting patients at a high risk of developing chronic obstructive pulmonary disease in general practice: cross sectional case finding study. BMJ. Jun. 8. 2002;324(7350):1370. KQ2E7a. [pmid: 12052807].
399 Vedal S, Crapo RO. False positive rates of multiple pulmonary function tests in healthy subjects. Chest. May. 1983;19(3):263-6. KQ4E2b. [pmid: 6882951].
400 Verhoeven GT, Hegmans JP, Mulder PG, et al. Effects of fluticasone propionate in COPD patients with bronchial hyperresponsiveness. Thorax. Aug. 2002;57(8):694-700. KQ7E6. [pmid: 12149529].
401 Vestbo J, Pauwels R, Anderson JA, et al. Early onset of effect of salmeterol and fluticasone propionate in chronic obstructive pulmonary disease. Thorax. Apr. 2005;60(4):301-4. KQ7E5h. [pmid: 15790985].
402 Vestbo J, Anderson J, Brook RD, et al. The Study to Understand Mortality and Morbidity in COPD (SUMMIT) study protocol. European Respiratory Journal. May. 2013;41(5):1017-22. KQ7E5a. [pmid: 23018908].
403 Vincken W, van Noord JA, Greefhorst AP, et al. Improved health outcomes in patients with COPD during 1 yr’s treatment with tiotropium. Eur Respir J. Feb. 2002;19(2):209-16. KQ7E5b. [pmid: 11871363].
404 Vogelmeier C, Kardos P, Harari S, et al. Formoterol mono- and combination therapy with tiotropium in patients with COPD: a 6-month study. Respir Med. Nov. 2008;102(11):1511-20. KQ7E5h. [pmid: 18804362].
405 Voncken-Brewster V, Tange H, de VH, et al. A randomised controlled trial testing a web-based, computer-tailored self-management intervention for people with or at risk for chronic obstructive pulmonary disease: a study protocol. BMC Public Health. 2013;13:557. KQ5aE5f. [pmid: 23742208].
406 Wada H, Nakano Y, Nagao T, et al. Detection and prevalence of chronic obstructive pulmonary disease in a cardiovascular clinic: evaluation using a hand held FEV1/FEV6 meter and questionnaire. Respirology. Nov. 2010;15(8):1252-8. KQ2E2b, KQ3E3b. [pmid: 20920134].
407 Wadbo M, Lofdahl CG, Larsson K, et al. Effects of formoterol and ipratropium bromide in COPD: a 3-month placebo-controlled study. Eur Respir J. Nov. 2002;20(5):1138-46. KQ7E7d. [pmid: 12449166].
408 Walker WB, Franzini LR. Low-risk aversive group treatments, physiological feedback, and booster sessions for smoking cessation. Behavior Therapy. Jun. 1985;16(3):263-74. PMID: None. KQ5aE4.
409 Wallace LD, Troy KE. Office-based spirometry for early detection of obstructive lung disease. [Review] [28 refs]. Journal of the American Academy of Nurse Practitioners. Sep. 2006;18(9):414-21. KQ5aE5a. [pmid: 16958772].
410 Walters JAE, Johns DP, Gartlan J, et al. Impact of opportunistic spirometry in primary care on the diagnosis of chronic obstructive pulmonary disease (COPD). [Abstract]. Thoracic Society of Australia and New Zealand Annual Scientific Meeting. 25 28 March 2007. Auckland. 2007. Abstract. PMID: None. KQ3E7b.
411 Watson L, Vonk JM, Lofdahl CG, et al. Predictors of lung function and its decline in mild to moderate COPD in association with gender: results from the Euroscop study. Respiratory Medicine. Apr. 2006;100(4):746-53. KQ7E6. [pmid: 16199147].
412 Watz H, Krippner F, Kirsten A, et al. Effects Of Indacaterol On Lung Volumes And Physical Activity In Moderate Chronic Obstructive Pulmonary Disease. [Abstract]. American journal of respiratory and critical care medicine. 2012;185:A2257. PMID: None. KQ7E7d.
413 Wedzicha JA, Buhl R, Lawrence D, et al. Monotherapy with indacaterol once daily reduces the rate of exacerbations in patients with moderate-to-severe COPD: Post-hoc pooled analysis of 6 months data from three large phase III trials. Respiratory Medicine. Jan. 2015;109(1):105-11. KQ7E5h. [pmid: 25433954].
414 Wedzicha JA, Dahl R, Buhl R, et al. Pooled safety analysis of the fixed-dose combination of indacaterol and glycopyrronium (QVA149), its monocomponents, and tiotropium versus placebo in COPD patients. Respiratory Medicine. 2014;108(10):1498-507. KQ7E5a, KQ8E5a. [pmid: 25135743].
415 Weir DC, Bale GA, Bright P, et al. A double-blind placebo-controlled study of the effect of inhaled beclomethasone dipropionate for 2 years in patients with nonasthmatic chronic obstructive pulmonary disease. Clin Exp Allergy. Jun. 1999;29(Suppl 2):125-8. KQ7E5h. [pmid: 10421835].
416 Wielders PL, Ludwig-Sengpiel A, Locantore N, et al. A new class of bronchodilator improves lung function in COPD: a trial with GSK961081. European Respiratory Journal. Oct. 2013;42(4):972-81. KQ7E7d. [pmid: 23429913].
417 Wielders PLML, Ludwig SA, Locantore NW, et al. A dual-acting muscarinic antagonist, Ć?2-agonist [MABA] molecule (GSK961081) improves lung function in COPD. A randomised trial. [Abstract]. European Respiratory Journal: European Respiratory Society Annual Congress. Vienna, Austria. September 1 5 2012. 40:545s. PMID: None. KQ7E7d.
418 Wilson RS, Connellan SJ. Domiciliary nebulised salbutamol solution in severe chronic airway obstruction. Thorax. Nov. 1980;35(11):873-6. KQ7E7d. [pmid: 7013150].
419 Wisnivesky J, Skloot G, Rundle A, et al. Spirometry screening for airway obstruction in asymptomatic smokers. Australian Family Physician. Jul. 2014;43(7):463-7. KQ3E7b. [pmid: 25006609].
420 Wouters EF, Postma DS, Fokkens B, et al. Withdrawal of fluticasone propionate from combined salmeterol/fluticasone treatment in patients with COPD causes immediate and sustained disease deterioration: a randomised controlled trial. Thorax. Jun. 2005;60(6):480-7. KQ7E5b. [pmid: 15923248].
421 Yang WL, Liu JM, Sun XG, et al. Effect of fluticasone propionate/salmeterol on exercise endurance in moderate-severe COPD. Respirology Conference: 16th Congress of the Asian Pacific Society of Respirology Shanghai China Conference Start: 20111103 Conference End: 20111106 Conference Publication. 2011;16:90. PMID: None. KQ7E2a.
422 Yawn B, Duvall K, Peabody J, et al. Improving clinical diagnosis of COPD in primary care: results of a cluster-randomized controlled study utilizing a screening questionnaire with or without a handheld spirometric device compared with usual care. [Abstract]. Chest. 2012;142:735A. KQ2E6.
423 Yawn BP, Duvall K, Peabody J, et al. The Impact of Screening Tools on Diagnosis of Chronic Obstructive Pulmonary Disease in Primary Care. Am J Prev Med. 2014. Sep. 15. KQ1E6, KQ2E6. [pmid: 25241196].
424 Yoshimoto D, Nakano Y, Onishi K, et al. The relationship between the COPD assessment test score and airflow limitation in Japan in patients aged over 40 years with a smoking history. Int J COPD. 2014;9:1357-63. PMID:. [doi: 10.2147/COPD.S61265]. KQ2E3b.
425 Zarowitz BJ, O’Shea T, Lefkovitz A, et al. Development and validation of a screening tool for chronic obstructive pulmonary disease in nursing home residents. J AM MED DIR ASSOC. Nov. 2011;12(9):668-74. KQ2E2b. [pmid: 21450260].
426 Zheng J, Guia T, Wang JJ, et al. The efficacy and safety of inhaled fluticasone furoate (FF)/vilanterol (VI) in Asian patients with COPD. [Abstract]. Respirology. 2014;18:31. PMID: None. KQ7E4.
427 Zheng JP, Yang L, Wu YM, et al. The efficacy and safety of combination salmeterol (50 microg)/fluticasone propionate (500 microg) inhalation twice daily via accuhaler in Chinese patients with COPD. Chest. Dec. 2007;132(6):1756-63. KQ7E2. [pmid: 17951625].
428 Zhou YM, Chen SY, Tian J, et al. Development and validation of a chronic obstructive pulmonary disease screening questionnaire in China. International Journal of Tuberculosis & Lung Disease. Dec. 2013;17(12):1645-51. KQ2E2a. [pmid: 24200283].