# Ongoing Studies

Study Country | Aim | Population Country | Intervention | Control | Relevant Outcomes | Status
TargetCOPD: a randomized controlled trial of targeted case finding for COPD versus routine practice in primary care ISRCTN14930255 | Compare the benefits and cost effectiveness of two alternative case finding approaches for identifying undiagnosed COPD in GP (targeted case finding vs usual care) | Current and former smokers, age 40–79; UK | Mailed lung health questionnaire; those with respiratory symptoms invited to spirometry. Also, flagged in the GP’s computer and if they come into practice for any reason, they are given a questionnaire. | Flagged in the GP computer and given the questionnaire if they show up in the GP practice for any reason. | Economic evaluation of case finding for COPD (cost per case identified) | Recruiting Estimated completion: January 2015
DOC Study: Determining the Optimal approach to identifying individuals with Chronis Obstructive Pulmonary Disease | Determining the optimal approach to identifying individuals with chronic obstructive pulmonary disease | Current smokers age 35+ in GP practices | Lung function tests and a case-finding questionnaire with immediate feedback | Lung function tests and a case-finding questionnaire with no results given for 6 months | Efficacy and cost-effectiveness of case-finding; impact on smoking behavior | Completed (not published) Completion date: July 2012
Early Detection of COPD Patients in GOLD 0 (Smokers) Population (MARKO) NCT01550679 | Development of the MARKO questionnaire for detection of COPD | Current and former smokers, age 45–60 Croatia | MARKO questionnaire +/− COPD6 lung function measurement | Gold Standard: Pulmonologist diagnosis | Discriminative power, prevalence of COPD, sensitivity | Recruiting Estimated completion: December, 2016
Microspirometry as a ‘point of care’ test in diagnosing COPD by the general practitioner; a cluster-randomised trial (EMPERIC). NTR4041 | Compare proportion of diagnostic spirometric assessment to determine presence or absence of COPD within 3 months after visit to GP. | Current or former smokers, age 50+, with respiratory symptoms that could indicate COPD Netherlands | Microspirometry measurement of FEV_1_/FEV_6_ in patients with symptoms of COPD | Usual care | Proportion of diagnostic assessments resulting in diagnosis of COPD, efficiency of testing | Status NR Estimated completion: September 2014
Developing a COPD Case Finding Methodology for Primary Care NCT01880177 | Develop a new screening measure for identifying at-risk COPD cases in primary care | Current and former smokers, age 40+ US | Focus groups | NA | Development of COPD case finding tool | Recruiting Estimated completion: May 2015
Evaluation of a symptom-based COPD population screener (COPD-PS) questionnaire for screening of COPD in primary care UMIN000011433 | Examine the usefulness of the COPD population screener (COPD-PS) questionnaire with a handheld spirometric device to identify undiagnosed COPD in primary care | Age 20+, patients with chronic disease who treated at primary care physicians Japan | COPD-PS, handheld device (not specified) | Gold Standard: Not specified | New COPD diagnosis | Enrolling Estimated completion: March 2016
Effectiveness of Spirometry as a Motivational Tool to Quit Smoking (ESPIMOAT) NCT01821885 | Asses the efficacy of the spirometry and a minimal smoking cessation counselling intervention to quit smoking in smokers without an existing COPD diagnosis | Current smokers, age 40+ Spain | Spirometry and a brief advice to quit smoking | Brief advice to quit smoking | Smoking cessation rate (12 months), number of cigarettes, smoking abstinence difference between patients with COPD and without | Ongoing Estimated completion: February 2015
Effectiveness of Regular Reporting of Spirometric Results on Smoking Quit Rate. (ESPIROTAB) NCT01296295 | Evaluate the effectiveness of regular reporting of spirometric results combined with smoking cessation advice on smoking quit rate in adult smokers in primary care | Current smokers, age 18+ Spain | Brief structured smoking cessation advice combined with a detailed and structured discussion of spirometric results | Brief structured smoking cessation advice | Smoking abstinence (12 months) | Unknown (Protocol published 2011)
Effectiveness of Smoking Cessation Advice Combined With Spirometric Results in Adult Smokers (ESPITAP) NCT01194596 | Evaluate the effectiveness of the spirometric results information with smoking cessation advice compared to smoking cessation advice alone | Current smokers, age 35–70 Spain | Brief structured smoking cessation advice together with a detailed and structured discussion of spirometric results | Brief structured smoking cessation advice | Smoking abstinence (12 months), smoking reduction | Unknown (Protocol published 2011)
Multicentric Randomized Clinical Trial to Evaluate the Long-term Effectiveness of a Motivational Intervention Against Smoking, Based on the Information Obtained From Spirometry in Primary Care. (RESET-ESPITAP2) NCT02153047 | Evaluate the effectiveness of smoking cessation advice with spirometry data compared to smoking cessation advice alone | Current smokers, age 35–70 Spain | Brief structured smoking cessation advice together with a detailed and structured 20-minutes visit with details of the spirometry data | Brief structured smoking cessation advice | Smoking cessation (12 months), smoking reduction | Ongoing Estimated completion: November 2014
The Get Quit - Stay Quit Study (GQSQ) NCT01980485 | Evaluate the effectiveness of Lung Age feedback compared to scores from spirometry alone | Current smokers, age 18+ | Feedback on lung age and exhaled carbon monoxide | Informed of scores on the spirometry. | Use of tobacco in last seven days, time to relapse (time frame 6 months) | Ongoing Estimated completion: December 2013
Study to Evaluate the Effect of Fluticasone Furoate/Vilanterol on Survival in Subjects With Chronic Obstructive Pulmonary Disease NCT01313676 | Determine if fluticasone furoate/vilanterol improves survival in patients with chronic obstructive pulmonary disease with a history of or increased risk of heart disease | COPD patients age 40–80; current or former smokers; FEV_1_/FVC ≤0.70; FEV_1_ 50–70% predicted; increased heart disease risk (established CAD. PVD, stroke, MI, diabetes, organ disease, or hypercholesterolemia) | IG1: Fluticasone fuorate/vilaterol (100/25 mcg) once daily IG2: Fluticasone furoate (100mcg) once daily IG3: Vilanterol (25 mcg) once daily | Placebo | All-cause mortality; time to cardiovascular composite endpoint (death, MI, stroke, unstable angina, TIA) | Ongoing Estimated Completion: January 2015

Abbreviations: CAD = coronary artery disease; COPD = chronic obstructive pulmonary disease; FEV_1_/FEV_6_ = forced expiratory volume in 1 second/forced expiratory volume in 6 seconds; FEV_1_/FVC = forced expiratory volume in 1 second/forced vital capacity; GOLD = Global Initiative for Chronic Obstructive Lung Disease; GP = general practice; mcg = microgram; MI = myocardial infarction; NA = not applicable; PVD = peripheral vascular disease; TIA = transient ischemic attack; UK = United Kingdom