# Detailed Methods

## Systematic Review Literature Search Strategies

### AHRQ

Screening for Chronic Obstructive Pulmonary Disease Using Spirometry – 2008

http://www.uspreventiveservicestaskforce.org/uspstf/uspscopd.htm

### BMJ Clinical Evidence

COPD – June 2011

http://clinicalevidence.bmj.com/x/systematic-review/1502/overview.html

### Cochrane Database of Systematic Reviews

#1 | “chronic obstructive pulmonary disease”:ti,ab,kw
#2 | “chronic obstructive airway disease”:ti,ab,kw
#3 | “chronic airflow limitation”:ti,ab,kw
#4 | “chronic obstructive respiratory disease”:ti,ab,kw
#5 | “obstructive lung” next disease*:ti,ab,kw
#6 | “chronic bronchitis”:ti,ab,kw
#7 | COPD:ti,ab,kw or COAD:ti,ab,kw
#8 | spirometry:ti,ab,kw
#9 | bronchospirometry:ti,ab,kw
#10 | #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 from 2008 to 2013, in Cochrane Reviews (Reviews only)

### Database of Abstracts of Reviews of Effects (via CRD)

1. (((COPD) OR (COAD) OR (chronic obstructive pulmonary disease) OR (obstructive lung disease) OR (chronic obstructive airway disease) OR (chronic airflow limitation) OR (chronic obstructive respiratory disease) OR (chronic bronchitis))) IN DARE FROM 2008 TO 2013
2. (spiromet*) OR (bronchospiromet*) IN DARE FROM 2008 TO 2013
3. #1 OR #2

### Health Technology Assessment (via CRD)

1. (((COPD) OR (COAD) OR (chronic obstructive pulmonary disease) OR (obstructive lung disease) OR (chronic obstructive airway disease) OR (chronic airflow limitation) OR (chronic obstructive respiratory disease) OR (chronic bronchitis))) IN HTA FROM 2008 TO 2013
2. (spiromet*) OR (bronchospiromet*) IN HTA FROM 2008 TO 2013
3. #1 OR #2

### Institute of Medicine

A Nationwide Framework for Surveillance of Cardiovascular and Chronic Lung Diseases - July 2001

http://www.iom.edu/Reports/2011/A-Nationwide-Framework-for-Surveillance-of-Cardiovascular-and-Chronic-Lung-Diseases.aspx

### National Institute for Health and Clinical Excellence

Chronic obstructive pulmonary disease: Management of chronic obstructive pulmonary disease in adults in primary and secondary care - June 2010

http://guidance.nice.org.uk/CG101/NICEGuidance/pdf/English

Chronic obstructive pulmonary disease quality standard – July 2011

http://publications.nice.org.uk/chronic-obstructive-pulmonary-disease-quality-standard-qs10

Roflumilast for the management of severe chronic obstructive pulmonary disease – January 2012

http://guidance.nice.org.uk/TA244/Guidance/pdf/English

### PubMed

#14 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #9 OR #13 Filters: Publication date from 2008/01/01 to 2013/12/31; English | 624 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=36)
#13 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #12 AND systematic[sb] | 159 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=33)
#12 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #10 OR #11 AND (publisher[sb] OR inprocess[sb] OR pubmednotmedline[sb]) | 4004 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=32)
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search spirometry[tiab] OR bronchospirometry[tiab] | 10586 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=30)
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search COPD[tiab] OR COAD[tiab] OR chronic obstructive pulmonary disease[tiab] OR chronic obstructive airway disease[tiab] OR chronic airflow limitation[tiab] OR chronic obstructive respiratory disease[tiab] OR obstructive lung disease*[tiab] OR chronic bronchitis[tiab] | 38182 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=29)
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #8 AND systematic[sb] Filters: English | 952 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=27)
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 | 36698 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=25)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search spirometry[title] OR bronchospirometry[title] | 1656 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=24)
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search COPD[title] OR COAD[title] OR chronic obstructive pulmonary disease[title] OR chronic obstructive airway disease[title] OR chronic airflow limitation[title] OR chronic obstructive respiratory disease[title] OR obstructive lung disease*[title] OR chronic bronchitis[title] | 22030 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=23)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Bronchospirometry”[Majr:NoExp] | 192 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=21)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Spirometry”[Majr:NoExp] | 3773 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Lung Diseases, Obstructive”[Majr:NoExp] | 13093 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Bronchitis, Chronic”[Majr:NoExp] | 529 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Pulmonary Disease, Chronic Obstructive”[Majr:NoExp] | 16952 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)

## Search Strategies to Identify Relevant Literature for Key Questions

Key:

/ = MeSH subject heading

MH = CINAHL subject heading

$ = truncation

* = truncation

ti = word in title

ab = word in abstract

fs = floating subheading

adj# = adjacent within × number of words

N# = adjacent within × number of words

pt = publication type

kw = keyword

tx = all text

### CINAHL – all KQ

S32 (S16 OR S31)
S31 (S26 OR S30)
S30 (S10 AND S22 AND S29) Limiters - English Language
S29 (S27 OR S28)
S28 TI ( (influenza or flu or pneumococcal) N5 (vaccinat* or immuniz* or shot*) ) OR AB ( (influenza or flu or pneumococcal) N5 (vaccinat* or immuniz* or shot*) )
S27 (MH “Immunization”) OR (MH “Immunization Programs”) OR (MH “Influenza Vaccine”) OR (MH “Pneumococcal Vaccine”)
S26 (S10 AND S22 AND S25) Limiters - Published Date: 20120101–20151231; English Language 21
S25 (S23 OR S24)
S24 TI ( smok* N10 (cessation or quit* or stop* or abstain* or abstinence) ) OR AB ( smok* N10 (cessation or quit* or stop* or abstain* or abstinence) ) OR TI ( cigarette* N10 (cessation or quit* or stop* or abstain* or abstinence) ) OR AB ( cigarette* N10 (cessation or quit* or stop* or abstain* or abstinence) )
S23 (MH “Smoking Cessation”) OR (MH “Smoking Cessation Programs”)
S22 S17 OR S18 OR S19 OR S20 OR
S21 TI ( (biofeedback or feedback) ) OR AB ( (biofeedback or feedback) )
S20 TI “health assessment” OR AB “health assessment” OR TI “risk assessment” OR AB “risk assessment”
S19 TI “respiratory function*” OR AB “respiratory function*” OR TI “lung function*” OR AB “lung function*”
S18 TI spiromet* OR AB spiromet* OR TI bronchospiromet* OR AB bronchospiromet*
S17 (MH “Respiratory Function Tests+”)
S16 S9 AND S15 Limiters - Published Date: 20000101–20151231; English Language; Exclude MEDLINE records
S15 (S10 OR S11 OR S12 OR S13 OR S14 )
S14 (TI longitudinal OR AB longitudinal OR TI “follow up” OR AB “follow up” OR TI followup OR AB followup)
S13 ( TI database* OR AB database* ) OR ( TI registry OR AB registry ) OR ( TI registries OR AB registries )
S12 TX cohort OR TX observational OR TX nonrandom* OR TX non-random*
S11 (MH “Prospective Studies”) OR (MH “Concurrent Prospective Studies”) OR (MH “Nonconcurrent Prospective Studies”) OR (MH “Correlational Studies”) 179,301
S10 (MH “Meta Analysis”) OR (MH “Control Group”) OR (MH “Single-Blind Studies”) OR (MH “Double-Blind Studies”) OR (MH “Triple-Blind Studies”) OR (MH “Randomized Controlled Trials”) OR (MH “Clinical Trials”) OR (MH “Random Assignment”) OR (TX clinical n1 trial*) OR (TX controlled n1 trial*) OR (PT Clinical trial) OR (PT randomized controlled trial) 237,468
S9 (S1 OR S2 OR S3 OR S4 OR S5 OR S6 OR S7 OR S8 )
S8 ( TI “copd” OR AB “copd” ) OR ( TI “coad” OR AB “coad” )
S7 TI “chronic bronchitis” OR AB “chronic bronchitis”
S6 TI “obstructive lung disease*” OR AB “obstructive lung disease*”
S5 TI “chronic obstructive respiratory disease*” OR AB “chronic obstructive respiratory disease*”
S4 TI “chronic airflow limitation*” OR AB “chronic airflow limitation*”
S3 TI “chronic obstructive airway disease*” OR AB “chronic obstructive airway disease*”
S2 TI “chronic obstructive pulmonary disease*” OR AB “chronic obstructive pulmonary disease*”
S1 (MH “Pulmonary Disease, Chronic Obstructive”) OR (MH “Bronchitis, Chronic”) OR (MH “Lung Diseases, Obstructive”)

### CENTRAL – All KQ

Issue 11 of 12, November 2014

Search Name: | COPD_all KQ_FINALrev
Date Run: | 18/12/14 20:27:21.122
Description: | sal 12.18.2014 _ USE FOR BRIDGE (added separate KQ5 search)

ID | Search | Hits
#1 | “chronic obstructive pulmonary” next disease*:ti,ab,kw | 4543
#2 | “chronic obstructive airway” next disease*:ti,ab,kw | 59
#3 | “chronic airflow” next limitation*:ti,ab,kw | 93
#4 | “chronic obstructive respiratory” next disease*:ti,ab,kw | 13
#5 | “obstructive lung” next disease*:ti,ab,kw | 1349
#6 | “chronic bronchitis”:ti,ab,kw | 1311
#7 | COPD:ti,ab,kw or COAD:ti,ab,kw | 7061
#8 | #1 or #2 or #3 or #4 or #5 or #6 or #7 | 10374
#9 | (prescreen* or pre-screen* or screen*):ti,ab,kw | 20930
#10 | (early or earlier):ti,ab,kw near/3 (identif* or test* or detect*):ti,ab,kw | 2799
#11 | (spiromet* or bronchospiromet*):ti,ab,kw | 3516
#12 | (respiratory or lung):ti,ab,kw near/3 test*:ti,ab,kw | 4588
#13 | (“peak flow” or “peak expiratory flow”):ti,ab,kw | 3923
#14 | questionnaire*:ti,ab,kw | 40364
#15 | (famil* near/3 histor*):ti,ab,kw | 1514
#16 | #9 or #10 or #11 or #12 or #13 or #14 or #15 | 70804
#17 | #8 and #16 Publication Year from 2000 to 2014, in Trials | 1547
#18 | (treat* or therap*):ti | 206863
#19 | bronchodilator*:ti,ab,kw | 5818
#20 | anticholinergic*:ti,ab,kw | 2006
#21 | beta*:ti,ab,kw near/3 (agonist* or adrenegenic or adrenoceptor):ti,ab,kw | 4869
#22 | (SABA or LABA):ti,ab,kw | 268
#23 | Albuterol:ti,ab,kw | 3243
#24 | Salbutamol:ti,ab,kw | 3071
#25 | Fenoterol:ti,ab,kw | 815
#26 | Levalbuterol:ti,ab,kw | 75
#27 | Xopenex HFA:ti,ab,kw | 0
#28 | Pirbuterol:ti,ab,kw | 60
#29 | Maxair Autohaler:ti,ab,kw | 8
#30 | Terbutaline:ti,ab,kw | 1269
#31 | Spiriva:ti,ab,kw | 34
#32 | Arformoterol:ti,ab,kw | 37
#33 | Brovana:ti,ab,kw | 0
#34 | Formoterol:ti,ab,kw | 1671
#35 | Foradil:ti,ab,kw | 77
#36 | Indacaterol:ti,ab,kw | 172
#37 | Onbrez breezhaler:ti,ab,kw | 1
#38 | Arcapta:ti,ab,kw | 0
#39 | Salmeterol:ti,ab,kw | 2038
#40 | Serevent diskus:ti,ab,kw | 6
#41 | Olodaterol:ti,ab,kw | 20
#42 | Vilanterol:ti,ab,kw | 83
#43 | (muscarin* next antagonist*):ti,ab,kw | 716
#44 | antimuscarin*:ti,ab,kw | 359
#45 | (anti next muscarin*):ti,ab,kw | 33
#46 | (SAMA or LAMA):ti,ab,kw | 61
#47 | Ipratropium:ti,ab,kw | 1350
#48 | Aclidinium:ti,ab,kw | 97
#49 | Tudorza Pressair:ti,ab,kw | 1
#50 | Glycopyrronium bromide:ti,ab,kw | 197
#51 | Seebri breezhaler:ti,ab,kw | 2
#52 | Tiotropium:ti,ab,kw | 697
#53 | Respimat:ti,ab,kw | 90
#54 | HandiHaler:ti,ab,kw | 53
#55 | glucocorticoid*:ti,ab,kw | 5045
#56 | corticosteroid:ti,ab,kw | 5487
#57 | Beclomethasone:ti,ab,kw | 1843
#58 | Qvar:ti,ab,kw | 30
#59 | Betamethasone:ti,ab,kw | 1513
#60 | Budesonide:ti,ab,kw | 2928
#61 | Pulmicort flexhaler:ti,ab,kw | 0
#62 | Ciclesonide:ti,ab,kw | 374
#63 | Alvesco:ti,ab,kw | 1
#64 | Formoterol:ti,ab,kw | 1671
#65 | Symbicort:ti,ab,kw | 148
#66 | Flunisolide:ti,ab,kw | 199
#67 | Aerobid:ti,ab,kw | 5
#68 | Fluticasone:ti,ab,kw | 3064
#69 | Flovent:ti,ab,kw | 14
#70 | Mometasone:ti,ab,kw | 658
#71 | Asmanex:ti,ab,kw | 4
#72 | Triamcinolone:ti,ab,kw | 1502
#73 | (dry next powder* next inhaler*):ti,ab,kw | 742
#74 | (metered next dose* next inhaler*):ti,ab,kw | 1849
#75 | (breath next actuated* next inhaler*):ti,ab,kw | 23
#76 | Accuhaler:ti,ab,kw | 86
#77 | Turbohaler:ti,ab,kw | 97
#78 | Diskhaler:ti,ab,kw | 159
#79 | (nebulizer* or nebuliser*):ti,ab,kw | 2333
#80 | {or #18–#79} | 230089
#81 | #8 and #80 Publication Year from 2010 to 2014, in Trials | 1082
#82 | (smok* or cigarette*):ti,ab,kw near/5 (stop* or cessat* or cease or abstin* or abstain* or control* or quit*):ti,ab,kw | 7366
#83 | (influenza or flu or pneumococcal):ti,ab,kw near/5 (vaccinat* or immuniz* or shot*):ti,ab,kw | 1671
#84 | (spiromet* or bronchospiromet*):ti,ab,kw | 3516
#85 | (respiratory or lung):ti,ab,kw next (function* or test*):ti,ab,kw | 8102
#86 | (health or risk):ti,ab,kw next assessment:ti,ab,kw | 10655
#87 | (biofeedback or feedback):ti,ab,kw | 6849
#88 | {or #84–#87} | 27662
#89 | #82 and #88 Publication Year from 2012 to 2014, in Trials | 93
#90 | #83 and #88 in Trials | 47
#91 | #17 or #81 or #89 or #90 | 2439

### Medline

#### KQ1 Screening

Database: Ovid MEDLINE(R) without Revisions <1996 to April Week 5 2014>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <May 07, 2014>, Ovid MEDLINE(R) Daily Update <May 07, 2014>

Search Strategy:

1. Pulmonary Disease, Chronic Obstructive/ (21575)
2. Bronchitis, Chronic/ (758)
3. Lung Diseases, Obstructive/ (5633)
4. chronic obstructive pulmonary disease$.ti,ab. (23299)
5. chronic obstructive airway disease$.ti,ab. (143)
6. chronic airflow limitation$.ti,ab. (126)
7. chronic obstructive respiratory disease$.ti,ab. (37)
8. obstructive lung disease$.ti,ab. (2547)
9. chronic bronchitis.ti,ab. (3055)
10. copd.ti,ab. (22187)
11. coad.ti,ab. (82)
12. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 (40054)
13. Mass screening/ (54347)
14. Spirometry/ (6858)
15. Bronchospirometry/ (50)
16. Respiratory Function Tests/ (17034)
17. screen$.ti,ab. (359518)
18. spiromet$.ti,ab. (10662)
19. bronchospiromet$.ti,ab. (2)
20. ((respiratory or lung) adj2 function test$).ti,ab. (2313)
21. 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 (401003)
22. 12 and 21 (7258)
23. Pulmonary Disease, Chronic Obstructive/di [Diagnosis] (3577)
24. Bronchitis, Chronic/di (123)
25. Lung Diseases, Obstructive/di (833)
26. 22 or 23 or 24 or 25 (9749)
27. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ (168286)
28. control groups/ or double-blind method/ or single-blind method/ (95648)
29. meta-analysis as topic/ (11332)
30. Random$.ti,ab. (566948)
31. clinical trial$.ti,ab. (174767)
32. controlled trial$.ti,ab. (102034)
33. meta analy$.ti,ab. (57428)
34. 27 or 28 or 29 or 30 or 31 or 32 or 33 (832073)
35. 26 and 34 (1647)
36. limit 35 to (english language and yr=“2005 -Current”) (1047)
37. remove duplicates from 36 (1047)

#### KQ2 Targeted screening/risk stratification

Database: Ovid MEDLINE(R) without Revisions <1996 to August Week 1 2014>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <August 19, 2014>, Ovid MEDLINE(R) Daily Update <August 19, 2014>

Search Strategy:

1. Pulmonary Disease, Chronic Obstructive/ (22311)
2. Bronchitis, Chronic/ (775)
3. Lung Diseases, Obstructive/ (5646)
4. chronic obstructive pulmonary disease$.ti,ab. (24173)
5. chronic obstructive airway disease$.ti,ab. (149)
6. chronic airflow limitation$.ti,ab. (129)
7. chronic obstructive respiratory disease$.ti,ab. (40)
8. obstructive lung disease$.ti,ab. (2620)
9. chronic bronchitis.ti,ab. (3104)
10. copd.ti,ab. (23050)
11. coad.ti,ab. (90)
12. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 (41375)
13. Risk Assessment/ (164921)
14. Risk factors/ (465571)
15. risk factor$.ti,ab. (303338)
16. (risk adj3 assess$).ti,ab. (55062)
17. (risk adj3 identif$).ti,ab. (42244)
18. ((high or increase$ or elevated) adj3 risk).ti,ab. (325626)
19. at risk.ti,ab. (85844)
20. 13 or 14 or 15 or 16 or 17 or 18 or 19 (981501)
21. Mass screening/ (55328)
22. Questionnaires/ (256126)
23. Genetic predisposition to disease/ (86380)
24. screen$.ti,ab. (371043)
25. prescreen$.ti,ab. (1071)
26. pre screen$.ti,ab. (687)
27. questionnaire$.ti,ab. (263412)
28. (famil$ adj3 histor$).ti,ab. (36947)
29. ((early or earlier) adj3 (identif$ or test$ or detect$)).ti,ab. (63026)
30. 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 (897008)
31. 12 and 20 and 30 (1620)
32. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ or meta-analysis as topic/ (178003)
33. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt. (502715)
34. Random$.ti,ab. (585176)
35. control groups/ or double-blind method/ or single-blind method/ (97386)
36. clinical trial$.ti,ab. (181062)
37. controlled trial$.ti,ab. (106461)
38. meta analy$.ti,ab. (61215)
39. cohort studies/ or longitudinal studies/ or follow-up studies/ or prospective studies/ or retrospective studies/ (1019077)
40. cohort.ti,ab. (231970)
41. longitudinal.ti,ab. (111196)
42. (follow up or followup).ti,ab. (494927)
43. 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 (2206572)
44. 31 and 43 (771)
45. limit 44 to (english language and yr=“2000 -Current”)

#### KQ3 Test performance/Dx accuracy

Database: Ovid MEDLINE(R) without Revisions <1996 to August Week 1 2014>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <August 19, 2014>, Ovid MEDLINE(R) Daily Update <August 19, 2014>

Search Strategy:

1. Pulmonary Disease, Chronic Obstructive/ (22311)
2. Bronchitis, Chronic/ (775)
3. Lung Diseases, Obstructive/ (5646)
4. chronic obstructive pulmonary disease$.ti,ab. (24173)
5. chronic obstructive airway disease$.ti,ab. (149)
6. chronic airflow limitation$.ti,ab. (129)
7. chronic obstructive respiratory disease$.ti,ab. (40)
8. obstructive lung disease$.ti,ab. (2620)
9. chronic bronchitis.ti,ab. (3104)
10. copd.ti,ab. (23050)
11. coad.ti,ab. (90)
12. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 (41375)
13. Mass screening/ (55328)
14. Spirometry/ (7020)
15. Bronchospirometry/ (50)
16. Respiratory Function Tests/ (17283)
17. Peak Expiratory Flow Rate/ (2808)
18. screen$.ti,ab. (371043)
19. spiromet$.ti,ab. (10972)
20. bronchospiromet$.ti,ab. (2)
21. ((respiratory or lung) adj2 function test$).ti,ab. (2363)
22. peak flow.ti,ab. (2686)
23. peak expiratory flow.ti,ab. (3646)
24. (test$ or detect$).ti. (318894)
25. 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 (701053)
26. 12 and 25 (8273)
27. Pulmonary Disease, Chronic Obstructive/di [Diagnosis] (3715)
28. Bronchitis, Chronic/di (125)
29. Lung Diseases, Obstructive/di (836)
30. 26 or 27 or 28 or 29 (10699)
31. “Sensitivity and Specificity”/ (250038)
32. “Predictive Value of Tests”/ (123921)
33. ROC Curve/ (27949)
34. False Negative Reactions/ (7749)
35. False Positive Reactions/ (12818)
36. Diagnostic Errors/ (15459)
37. “Reproducibility of Results”/ (249704)
38. Reference Values/ (90327)
39. Reference Standards/ (24352)
40. Observer Variation/ (27474)
41. Receiver operat$.ti,ab. (33075)
42. ROC curve$.ti,ab. (13779)
43. sensitivit$.ti,ab. (398115)
44. specificit$.ti,ab. (239264)
45. predictive value.ti,ab. (46839)
46. accuracy.ti,ab. (188213)
47. false positive$.ti,ab. (28994)
48. false negative$.ti,ab. (16366)
49. miss rate$.ti,ab. (229)
50. error rate$.ti,ab. (7478)
51. 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 (1169692)
52. 30 and 51 (1923)
53. limit 52 to (english language and yr=“2000 -Current”) (1543)
54. remove duplicates from 53 (1543)
55. limit 52 to (english language and yr=“2000 -Current”)

#### KQ 4, 6 Screening harms

Database: Ovid MEDLINE(R) without Revisions <1996 to April Week 5 2014>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <May 07, 2014>, Ovid MEDLINE(R) Daily Update <May 07, 2014>

Search Strategy:

1. Pulmonary Disease, Chronic Obstructive/ (21603)
2. Bronchitis, Chronic/ (760)
3. Lung Diseases, Obstructive/ (5634)
4. chronic obstructive pulmonary disease$.ti,ab. (23351)
5. chronic obstructive airway disease$.ti,ab. (143)
6. chronic airflow limitation$.ti,ab. (126)
7. chronic obstructive respiratory disease$.ti,ab. (37)
8. obstructive lung disease$.ti,ab. (2555)
9. chronic bronchitis.ti,ab. (3056)
10. copd.ti,ab. (22246)
11. coad.ti,ab. (82)
12. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 (40131)
13. Mass screening/ (54403)
14. Spirometry/ (6866)
15. Bronchospirometry/ (50)
16. Respiratory Function Tests/ (17041)
17. screen$.ti,ab. (359803)
18. spiromet$.ti,ab. (10674)
19. bronchospiromet$.ti,ab. (2)
20. ((respiratory or lung) adj2 function test$).ti,ab. (2313)
21. 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 (401318)
22. 12 and 21 (7266)
23. Pulmonary Disease, Chronic Obstructive/di [Diagnosis] (3580)
24. Bronchitis, Chronic/di (123)
25. Lung Diseases, Obstructive/di (834)
26. 22 or 23 or 24 or 25 (9760)
27. Mortality/ (15506)
28. Morbidity/ (12726)
29. Death/ (4360)
30. safety.ti,ab. (233647)
31. harm$.ti,ab. (82227)
32. mortality.ti,ab. (347296)
33. complication$.ti,ab. (421796)
34. (death or deaths).ti,ab. (398868)
35. (adverse adj2 (interaction$ or response$ or effect$ or event$ or reaction$ or outcome$)).ti,ab. (202261)
36. side effect$.ti,ab. (113733)
37. adverse effects.fs. (807421)
38. mortality.fs. (267483)
39. false reassurance.ti,ab. (84)
40. false assurance.ti,ab. (6)
41. (unnecessar$ adj3 (treat$ or therap$)).ti,ab. (2358)
42. overtreat$.ti,ab. (1889)
43. Arrhythmias, Cardiac/ (17745)
44. cardiac ectop$.ti,ab. (20)
45. ectopic heartbeat$.ti,ab. (9)
46. arrhythmia$.ti,ab. (35782)
47. premature atrial contraction$.ti,ab. (122)
48. premature ventricular contraction$.ti,ab. (718)
49. 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 (2104318)
50. 26 and 49 (3083)
51. limit 50 to (english language and yr=“2005 -Current”) (1810)

#### KQ 5 Spirometry/respiratory tests and smoking cessation/vaccination

Database: Ovid MEDLINE(R) <1946 to November Week 3 2014>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <December 11, 2014>, Ovid MEDLINE(R) Daily Update <November 19, 2014>

Search Strategy:

1. Smoking cessation/ (22129)
2. “Tobacco Use Cessation”/ (817)
3. Smoking/pc [Prevention & Control] (16116)
4. ((smok$ or cigarette$) adj10 (cessation or quit$ or stop$ or abstain$ or abstinence)).ti,ab. (28363)
5. 1 or 2 or 3 or 4 (45364)
6. Immunization/ (43536)
7. Vaccination/ (57981)
8. Immunization Programs/ (7906)
9. Influenza vaccines/ (17540)
10. Pneumococcal Vaccines/ (5169)
11. ((influenza or flu or pneumococcal) adj5 (vaccinat* or immuniz* or shot*)).ti,ab. (13136)
12. 6 or 7 or 8 or 9 or 10 or 11 (123196)
13. Spirometry/ (18008)
14. Bronchospirometry/ (715)
15. Respiratory Function Tests/ (39767)
16. spiromet$.ti,ab. (16391)
17. bronchospiromet$.ti,ab. (217)
18. ((respiratory or lung) adj3 (function$ or test$)).ti,ab. (46458)
19. health assessment.ti,ab. (5497)
20. risk assessment.ti,ab. (34715)
21. (biofeedback or feedback).ti,ab. (96905)
22. 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 (231679)
23. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ or meta-analysis as topic/ (286881)
24. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt. (757319)
25. Random$.ti,ab. (772026)
26. control groups/ or double-blind method/ or single-blind method/ (154325)
27. clinical trial$.ti,ab. (238000)
28. controlled trial$.ti,ab. (133172)
29. meta analy$.ti,ab. (73510)
30. 23 or 24 or 25 or 26 or 27 or 28 or 29 (1477927)
31. 5 and 22 and 30 (490)
32. limit 31 to (english language and yr=“2012 -Current”) (97)
33. 12 and 22 and 30 (114)
34. limit 33 to english language (109)
35. 32 or 34 (205)
36. Animal/ not (Human/ and Animal/) (4006515)
37. 35 not 36 (199)
38. remove duplicates from 37 (174)

#### KQ 7 Tx

Database: Ovid MEDLINE(R) without Revisions <1996 to August Week 1 2014>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <August 19, 2014>, Ovid MEDLINE(R) Daily Update <August 19, 2014>

Search Strategy:

1. Pulmonary Disease, Chronic Obstructive/ (22311)
2. Bronchitis, Chronic/ (775)
3. Lung Diseases, Obstructive/ (5646)
4. chronic obstructive pulmonary disease$.ti,ab. (24173)
5. chronic obstructive airway disease$.ti,ab. (149)
6. chronic airflow limitation$.ti,ab. (129)
7. chronic obstructive respiratory disease$.ti,ab. (40)
8. obstructive lung disease$.ti,ab. (2620)
9. chronic bronchitis.ti,ab. (3104)
10. copd.ti,ab. (23050)
11. coad.ti,ab. (90)
12. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 (41375)
13. Bronchodilator Agents/ (10069)
14. Cholinergic Antagonists/ (3214)
15. Adrenergic beta-Agonists/ (10398)
16. Adrenergic beta-2 Receptor Agonists/ (1548)
17. “Nebulizers and Vaporizers”/ (5367)
18. Expectorants/ (1015)
19. Muscarinic Antagonists/ (6055)
20. Adrenal Cortex Hormones/ (20492)
21. Albuterol/ (4944)
22. Fenoterol/ (356)
23. Ipratropium/ (729)
24. Terbutaline/ (921)
25. Bronchodilator$.ti,ab. (5995)
26. anticholinergic$.ti,ab. (4956)
27. (beta$ adj3 (agonist$ or adrenegenic or adrenoceptor)).ti,ab. (16200)
28. (SABA or LABA).ti,ab. (957)
29. Albuterol.ti,ab. (1527)
30. Salbutamol.ti,ab. (3184)
31. Fenoterol.ti,ab. (414)
32. Levalbuterol.ti,ab. (126)
33. Xopenex HFA.ti,ab. (1)
34. Pirbuterol.ti,ab. (18)
35. Maxair Autohaler.ti,ab. (2)
36. Terbutaline.ti,ab. (1132)
37. Spiriva.ti,ab. (48)
38. Arformoterol.ti,ab. (31)
39. Brovana.ti,ab. (1)
40. Formoterol.ti,ab. (1412)
41. Foradil.ti,ab. (51)
42. Indacaterol.ti,ab. (207)
43. Onbrez breezhaler.ti,ab. (5)
44. Arcapta.ti,ab. (2)
45. Salmeterol.ti,ab. (1803)
46. Serevent diskus.ti,ab. (7)
47. Olodaterol.ti,ab. (27)
48. Vilanterol.ti,ab. (79)
49. muscarin$ antagonist$.ti,ab. (1229)
50. antimuscarin$.ti,ab. (1338)
51. anti muscarin$.ti,ab. (141)
52. (SAMA or LAMA).ti,ab. (592)
53. Ipratropium.ti,ab. (976)
54. Aclidinium.ti,ab. (83)
55. Tudorza Pressair.ti,ab. (2)
56. Glycopyrronium bromide.ti,ab. (40)
57. Seebri breezhaler.ti,ab. (2)
58. Tiotropium.ti,ab. (903)
59. Respimat.ti,ab. (95)
60. HandiHaler.ti,ab. (86)
61. glucocorticoid$.ti,ab. (33132)
62. (inhal$ and corticosteroid$).ti,ab. (7605)
63. Beclomethasone.ti,ab. (1435)
64. Qvar.ti,ab. (61)
65. Betamethasone.ti,ab. (2084)
66. Budesonide.ti,ab. (3304)
67. Pulmicort flexhaler.ti,ab. (1)
68. Ciclesonide.ti,ab. (271)
69. Alvesco.ti,ab. (8)
70. Formoterol.ti,ab. (1412)
71. Symbicort.ti,ab. (119)
72. Flunisolide.ti,ab. (172)
73. Aerobid.ti,ab. (4)
74. Fluticasone.ti,ab. (2681)
75. Flovent.ti,ab. (20)
76. Mometasone.ti,ab. (592)
77. Asmanex.ti,ab. (3)
78. Triamcinolone.ti,ab. (3650)
79. Dry powder$ inhaler$.ti,ab. (1219)
80. Metered dose inhaler$.ti,ab. (1986)
81. Breath actuated inhaler$.ti,ab. (34)
82. Accuhaler.ti,ab. (65)
83. Turbohaler.ti,ab. (71)
84. Diskhaler.ti,ab. (118)
85. Nebuli?er$.ti,ab. (2511)
86. 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56 or 57 or 58 or 59 or 60 or 61 or 62 or 63 or 64 or 65 or 66 or 67 or 68 or 69 or 70 or 71 or 72 or 73 or 74 or 75 or 76 or 77 or 78 or 79 or 80 or 81 or 82 or 83 or 84 or 85 (111811)
87. 12 and 86 (6603)
88. Pulmonary Disease, Chronic Obstructive/dt (4605)
89. Bronchitis, Chronic/dt (251)
90. Lung Diseases, Obstructive/dt (994)
91. 87 or 88 or 89 or 90 (8607)
92. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ or meta-analysis as topic/ (178003)
93. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt. (502715)
94. Random$.ti,ab. (585176)
95. control groups/ or double-blind method/ or single-blind method/ (97386)
96. clinical trial$.ti,ab. (181062)
97. controlled trial$.ti,ab. (106461)
98. meta analy$.ti,ab. (61215)
99. 92 or 93 or 94 or 95 or 96 or 97 or 98 (1072456)
100. 91 and 99 (3045)
101. limit 100 to (english language and yr=“2010 -Current”)

#### KQ8 Tx harms

1. Pulmonary Disease, Chronic Obstructive/
2. Bronchitis, Chronic/
3. Lung Diseases, Obstructive/
4. chronic obstructive pulmonary disease$.ti,ab.
5. chronic obstructive airway disease$.ti,ab.
6. chronic airflow limitation$.ti,ab.
7. chronic obstructive respiratory disease$.ti,ab.
8. obstructive lung disease$.ti,ab.
9. chronic bronchitis.ti,ab.
10. copd.ti,ab.
11. coad.ti,ab.
12. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11
13. Bronchodilator Agents/
14. Cholinergic Antagonists/
15. Adrenergic beta-Agonists/
16. Adrenergic beta-2 Receptor Agonists/
17. “Nebulizers and Vaporizers”/
18. Expectorants/
19. Muscarinic Antagonists/
20. Adrenal Cortex Hormones/
21. Albuterol/
22. Fenoterol/
23. Ipratropium/
24. Terbutaline/
25. Bronchodilator$.ti,ab.
26. anticholinergic$.ti,ab.
27. (beta$ adj3 (agonist$ or adrenegenic or adrenoceptor)).ti,ab.
28. (SABA or LABA).ti,ab.
29. Albuterol.ti,ab.
30. Salbutamol.ti,ab.
31. Fenoterol.ti,ab.
32. Levalbuterol.ti,ab.
33. Xopenex HFA.ti,ab.
34. Pirbuterol.ti,ab.
35. Maxair Autohaler.ti,ab.
36. Terbutaline.ti,ab.
37. Spiriva.ti,ab.
38. Arformoterol.ti,ab.
39. Brovana.ti,ab.
40. Formoterol.ti,ab.
41. Foradil.ti,ab.
42. Indacaterol.ti,ab.
43. Onbrez breezhaler.ti,ab.
44. Arcapta.ti,ab.
45. Salmeterol.ti,ab.
46. Serevent diskus.ti,ab.
47. Olodaterol.ti,ab.
48. Vilanterol.ti,ab.
49. muscarin$ antagonist$.ti,ab.
50. antimuscarin$.ti,ab.
51. anti muscarin$.ti,ab.
52. (SAMA or LAMA).ti,ab.
53. Ipratropium.ti,ab.
54. Aclidinium.ti,ab.
55. Tudorza Pressair.ti,ab.
56. Glycopyrronium bromide.ti,ab.
57. Seebri breezhaler.ti,ab.
58. Tiotropium.ti,ab.
59. Respimat.ti,ab.
60. HandiHaler.ti,ab.
61. glucocorticoid$.ti,ab.
62. (inhal$ and corticosteroid$).ti,ab.
63. Beclomethasone.ti,ab.
64. Qvar.ti,ab.
65. Betamethasone.ti,ab.
66. Budesonide.ti,ab.
67. Pulmicort flexhaler.ti,ab.
68. Ciclesonide.ti,ab.
69. Alvesco.ti,ab.
70. Formoterol.ti,ab.
71. Symbicort.ti,ab.
72. Flunisolide.ti,ab.
73. Aerobid.ti,ab.
74. Fluticasone.ti,ab.
75. Flovent.ti,ab.
76. Mometasone.ti,ab.
77. Asmanex.ti,ab.
78. Triamcinolone.ti,ab.
79. Dry powder$ inhaler$.ti,ab.
80. Metered dose inhaler$.ti,ab.
81. Breath actuated inhaler$.ti,ab.
82. Accuhaler.ti,ab.
83. Turbohaler.ti,ab.
84. Diskhaler.ti,ab.
85. Nebuli?er$.ti,ab.
86. 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56 or 57 or 58 or 59 or 60 or 61 or 62 or 63 or 64 or 65 or 66 or 67 or 68 or 69 or 70 or 71 or 72 or 73 or 74 or 75 or 76 or 77 or 78 or 79 or 80 or 81 or 82 or 83 or 84 or 85
87. 12 and 86
88. Pulmonary Disease, Chronic Obstructive/dt
89. Bronchitis, Chronic/dt
90. Lung Diseases, Obstructive/dt
91. 87 or 88 or 89 or 90
92. Mortality/
93. Morbidity/
94. Death/
95. “Drug-Related Side Effects and Adverse Reactions”/
96. safety.ti,ab.
97. harm$.ti,ab.
98. mortality.ti,ab.
99. toxicity.ti,ab.
100. complication$.ti,ab.
101. (death or deaths).ti,ab.
102. (adverse adj2 (interaction$ or response$ or effect$ or event$ or reaction$ or outcome$)).ti,ab.
103. side effect$.ti,ab.
104. adverse effects.fs.
105. toxicity.fs.
106. mortality.fs.
107. Dizziness/
108. Headache/
109. Xerostomia/
110. Constipation/
111. Urinary Retention/
112. Urinary Tract Infections/
113. Muscle Cramp/
114. Hematoma/
115. Candidiasis, Oral/
116. Bone Density/de [Drug Effects]
117. Fractures, Bone/
118. Cataract/
119. Glaucoma/
120. Glaucoma, open-angle/
121. Cough/
122. Bronchial Spasm/
123. Arrhythmias, Cardiac/
124. Tachycardia/
125. Heart Failure/
126. Heart Arrest/
127. Heart Rate/de [Drug Effects]
128. Myocardial Infarction/
129. Cardiomyopathies/
130. xerostomia$.ti,ab.
131. dry mouth.ti,ab.
132. headache$.ti,ab.
133. tremor$.ti,ab.
134. constipat$.ti,ab.
135. urinary retention.ti,ab.
136. urinary tract infection$.ti,ab.
137. muscle cramp$.ti,ab.
138. (bruise$ or bruising).ti,ab.
139. h?ematoma$.ti,ab.
140. ((oral or oropharyngeal) adj candidiasis).ti,ab.
141. ((low or decrease$) adj3 (body mass density or BMD)).ti,ab.
142. fracture$.ti,ab.
143. cataract$.ti,ab.
144. glaucoma.ti,ab.
145. paradoxical bronchospasm$.ti,ab.
146. bronchial spasm$.ti,ab.
147. respiratory death$.ti,ab.
148. cardiovascular event$.ti,ab.
149. arrhythmi$.ti,ab.
150. tachycardi$.ti,ab.
151. palpitation$.ti,ab.
152. ((rapid or increase$ or elevat$) adj3 (heart rate or heartbeat)).ti,ab.
153. myocardial infarction$.ti,ab.
154. cardiomyopath$.ti,ab.
155. (heart adj (failure$ or attack$)).ti,ab.
156. cardiac death$.ti,ab.
157. 92 or 93 or 94 or 95 or 96 or 97 or 98 or 99 or 100 or 101 or 102 or 103 or 104 or 105 or 106 or 107 or 108 or 109 or 110 or 111 or 112 or 113 or 114 or 115 or 116 or 117 or 118 or 119 or 120 or 121 or 122 or 123 or 124 or 125 or 126 or 127 or 128 or 129 or 130 or 131 or 132 or 133 or 134 or 135 or 136 or 137 or 138 or 139 or 140 or 141 or 142 or 143 or 144 or 145 or 146 or 147 or 148 or 149 or 150 or 151 or 152 or 153 or 154 or 155 or 156
158. 91 and 157
159. limit 158 to (english language and yr=“2010 -Current”)

### Targeted immunization uptake search

Database: Ovid MEDLINE(R) without Revisions <1996 to April Week 5 2014>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <May 07, 2014>, Ovid MEDLINE(R) Daily Update <May 07, 2014>

Search Strategy:

1. Pulmonary Disease, Chronic Obstructive/ (21601)
2. Bronchitis, Chronic/ (760)
3. Lung Diseases, Obstructive/ (5634)
4. chronic obstructive pulmonary disease$.ti,ab. (23386)
5. chronic obstructive airway disease$.ti,ab. (144)
6. chronic airflow limitation$.ti,ab. (126)
7. chronic obstructive respiratory disease$.ti,ab. (37)
8. obstructive lung disease$.ti,ab. (2556)
9. chronic bronchitis.ti,ab. (3061)
10. copd.ti,ab. (22271)
11. coad.ti,ab. (82)
12. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 (40171)
13. Immunization/ (16139)
14. Vaccination/ (29248)
15. Immunization Programs/ (6769)
16. Influenza vaccines/ (11809)
17. Pneumococcal Vaccines/ (4213)
18. 13 or 14 or 15 or 16 or 17 (59646)
19. ((influenza or flu or pneumococcal) adj5 (vaccinat* or immuniz* or shot*)).ti,ab. (9511)
20. 13 or 14 or 15 or 16 or 17 or 18 or 19 (61940)
21. 12 and 20 (346)
22. limit 21 to (english language and yr=“2005 -Current”) (195)
23. remove duplicates from 22 (193)

### Pubmed, publisher-supplied All KQ

Search | Query | Items found
#16 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((#13 OR #14 OR #15)) AND publisher[sb]) AND English[Language] | 756 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#15 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 AND #11 AND #12) | 336 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#14 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 AND #11 AND #12) AND (“2012”[Date - Publication] : “3000”[Date - Publication]) | 74 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#13 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#4) AND (“2000”[Date - Publication] : “3000”[Date - Publication]) | 31664 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#12 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search random*[tiab] OR trial*[tiab] | 1138451 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #7 or #8 or #9 or #10 | 176023 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search biofeedback[tiab] OR feedback[tiab] | 92412 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search health assessment[tiab] OR risk assessment[tiab] | 39593 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search respiratory function*[tiab] OR lung function*[tiab] | 33105 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search spirometr*[tiab] OR bronchospiromet*[tiab] | 15424 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search vaccinat*[tiab] OR immuniz*[tiab] | 194038 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (smok*[tiab] OR cigarette*[tiab]) AND (cessation[tiab] OR quit*[tiab] OR stop*[tiab] OR abstain*[tiab] OR abstinence[tiab]) | 29021 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #1 OR #2 OR #3 | 47520 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search COPD[title] OR COAD[title] | 10813 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search obstructive lung disease*[tiab] OR chronic bronchitis[tiab] | 13886 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search chronic obstructive pulmonary disease*[tiab] OR chronic obstructive respiratory disease*[tiab] OR chronic obstructive airway[tiab] OR chronic airflow limitation*[tiab] | 30163 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)

Appendix A Figure 1 Literature Flow Diagram

This figure is a flow chart that summarizes the search and selection of articles included in the evidence review. There were 19,225 citations identified through literature databases. An additional 114 citations were identified from outside sources, such as reference lists and suggestions from peer reviewers. After duplicates were removed, 13,141 unique citations were screened at the title/abstract stage. The full text of 465 citations were examined for inclusion for one or more of the eight Key Questions. The following number of studies were included for Key Question 1 (k=0), Key Question 2 (k=14), Key Question 3 (k=5), Key Question 4 (k=8), Key Question 5 (k=5), Key Question 6 (k=1), Key Question 7 (k=11), and Key Question 8 (k=8). Reasons for excluding the other articles are available in Appendix C.

Appendix A Table 1 Inclusion and Exclusion Criteria

| KQs | Inclusion | Exclusion
Populations | 1–4 | Asymptomatic adults^*^ aged 40 and over^†^ | Patients with diagnosed COPD or other respiratory conditions (KQ1 only); patients with identified alpha-1 antitrypsin deficiency; pregnant women
Populations | 5–6 | 5a/6a: Asymptomatic adults^*^ aged 40 and over^†^; current smokers 5b/6b: Asymptomatic adults^*^ aged 40 and over^†^; | Patients with identified alpha-1 antitrypsin deficiency; pregnant women
Populations | 7–8 | Asymptomatic adults^*^ aged 40 and over with screen detected fixed airway obstruction; patients with mild (FEV_1_ ≥ 80% normal) to moderate (FEV_1_ 50–79% normal) COPD^‡^; or a population representative of mild or moderate disease (mean population FEV_1_ ≥ 60% normal) | Patients with severe (FEV_1_ 30–49% normal) or very severe (FEV_1_ <30% normal) COPD^‡^; pregnant women; patients with COPD-related symptoms (e.g. persistent dyspnea, chronic sputum production and/or cough); patients with identified alpha-1 antitrypsin deficiency
Setting | 1–8 | Primary or specialty care or community-based settings; developed countries, as defined by Human Development Index (HDI) in “very high human development” category (>0.8)^§^ | Inpatient settings; countries not categorized as “very high human development (>0.8)”
Interventions | 1–4 | Pre-bronchodilator screening spirometry, questionnaires or risk assessment tools; peak flow meter; confirmatory post-bronchodilator spirometry | Spirometry or other modalities used for disease monitoring or management
Interventions | 5–6 | 5a/6a: Screening pulmonary function testing with or without smoking cessation interventions and counseling 5b/6b: Screening pulmonary function testing with or without vaccination promotion interventions and counseling | Spirometry or other modalities used for disease monitoring or management
| 7–8 | Pharmacotherapy (including short and long acting beta-agonists, anticholinergics, inhaled corticosteroids, or combinations of these treatments) | Oxygen therapy, surgical therapies, lung transplant, systemic corticosteroids, phosphodiesterase-4 inhibitors, mucolytic agents, pulmonary rehabilitation\|\|
Comparisons | 1 | Usual care; no screening
Comparisons | 2–4 | KQ2/4: pre- or post-bronchodilator spirometry as the reference standard KQ3/4: post-bronchodilator spirometry as the reference standard
Comparisons | 5–6 | 5a/6a: Smoking cessation counseling or interventions not including screening pulmonary function tests; usual care 5b/6b: Immunization promotion counseling or interventions not including screening pulmonary function tests; usual care
Comparisons | 7–8 | Usual care; placebo; no treatment
Outcomes | 1 | All-cause mortality, disease specific mortality, COPD-related morbidity; HRQoL
Outcomes | 2 | fixed airflow obstruction requisite for COPD diagnosis as determined by established diagnostic standards (i.e. FEV_1_/FVC < 0.70); test performance including: sensitivity and specificity (per person); positive (PPV) and negative (NPV) predictive value (per person); diagnostic yield by disease severity
Outcomes | 3 | fixed airflow obstruction requisite for COPD diagnosis as determined by established diagnostic standards (i.e. FEV_1_/FVC < 0.70) ; test performance including: sensitivity and specificity (per person); positive (PPV) and negative (NPV) predictive value (per person); diagnostic yield by disease severity
Outcomes | 4, 6, 8 | Serious adverse events requiring unexpected or unwanted medical attention and/or resulting in death (e.g., requiring hospitalization), adverse events reported by ≥ 5% of the study population, false reassurance for screen-negative smokers, false positive rate and missed diagnoses from screening
Outcomes | 5 | Self-reported or biologically validated smoking abstinence rates, sustained abstinence over the course of the study, number of quit attempts; immunization rates
Outcomes | 7 | All-cause mortality, disease specific mortality, COPD-related morbidity; HRQoL
Study Designs | 1, 5, 7 | RCTs, systematic reviews (of included study designs) | Cohort studies, case-control studies, case series
Study Designs | 2–3 | Diagnostic accuracy studies (including observational/cohort studies), systematic reviews (of included study designs)
Study Designs | 4, 6 | RCTs, large screening registry or database observational studies, cohort studies, systematic reviews (of included study designs)
Study Designs | 8 | RCTs included for KQ7, large screening registries, systematic reviews (of included study designs), FDA labels
Study Quality | 1–8 | Good- & fair-quality | Poor-quality
Language | 1–8 | English | Non-English studies
Language | 1–8 | English | Non-English studies

* We will consider asymptomatic patients to be made up of individuals in one of the following states: those who are free of the disease; those in whom the disease is present, but who have physical symptoms that are undetected by the patient or the clinician (e.g., have mild dyspnea that goes unnoticed); or those who have nonspecific symptoms (e.g., sporadic sputum production or cough) that have gone unrecognized as being related to COPD.

† Recent survey data shows that the prevalence of COPD is highest in adults aged 65–84 years (8.3% in men 65–74 years; 11.2% in women 75–84 years of age). Epidemiological surveys suggest an incidence of 3 to 5% amongst adults aged 45 and under. Based on these data, this evidence review will focus on adults aged 40 and older.

‡ Based on the GOLD criteria COPD classifications

§ Settings: Included Countries: All countries listed as “very high” human development on Human Development Index (http://hdr.undp.org/en/statistics/): Andorra, Argentina, Australia, Austria, Barbados, Belgium, Brunei Darussalam, Canada, Chile, Croatia, Cyprus, Czech Republic, Denmark, Estonia, Finland, France, Germany, Greece, Hong Kong, Hungary, Iceland, Ireland, Israel, Italy, Japan, Korea, Latvia, Liechtenstein, Lithuania, Luxembourg, Malta, Netherlands, New Zealand, Norway, Poland, Portugal, Qatar, Seychelles, Singapore, Slovakia, Slovenia, Spain, Sweden, Switzerland, United Arab Emirates, United Kingdom, United States

|| Patients with severe disease would constitute a very small minority of those identified by asymptomatic screening spirometry and thus the treatment modalities recommended for these patients will not be considered in this evidence review (i.e. pulmonary rehabilitation, oxygen therapy, surgical treatment to reduce lung volume, and lung transplantation).

Appendix A Table 2 Quality Assessment Criteria

Design | USPSTF quality rating criteria104 | National Institute for Health and Clinical Excellence methodology checklists105 | QUADAS I and IITools106,107
Systematic reviews and meta-analyses | - Comprehensiveness of sources considered/search strategy used; - Standard appraisal of included studies; - Validity of conclusions; - Recency and relevance are especially important for systematic reviews | - The study addresses an appropriate and clearly focused question; - A description of the methodology used is included; - The literature search is sufficiently rigorous to identify all the relevant studies; - Study quality is assessed and taken into account; - There are enough similarities between the studies selected to make combining them reasonable | Not applicable
Randomized controlled trials (RCTs) | - Initial assembly of comparable groups employs adequate randomization, including first concealment and whether potential confounders were distributed equally among groups; - Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination); - Important differential loss to followup or overall high loss to followup; - Measurements: equal, reliable, and valid (includes masking of outcome assessment); - Clear definition of the interventions; - All important outcomes considered | - The study addresses an appropriate and clearly focused question; - The assignment of subjects to treatment groups is randomized; - An adequate concealment method is used; - Subjects and investigators are kept ‘blind’ about treatment allocation; - The treatment and control groups are similar at the start of the trial; - The only difference between groups is the treatment under investigation; - All relevant outcomes are measured in a standard, valid and reliable way; - What percentage of the individuals or clusters recruited into each treatment arm of the study dropped out before the study was completed?; - All the subjects are analyzed in the groups to which they were randomly allocated (often referred to as intention-to-treat analysis); - Where the study is carried out at more than one site, results are comparable for all sites | Not applicable
Cohort studies | - Initial assembly of comparable groups employs consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts; - Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination); - Important differential loss to followup or overall high loss to followup; - Measurements: equal, reliable, and valid (includes masking of outcome assessment); - Clear definition of the interventions; - All important outcomes considered | - The study addresses an appropriate and clearly focused question; - The two groups being studied are selected from source populations that are comparable in all respects other than the factor under investigation; - The study indicates how many of the people asked to take part did so, in each of the groups being studied; - The likelihood that some eligible subjects might have the outcome at the time of enrollment is assessed and taken into account in the analysis; - What percentage of individuals or clusters recruited into each arm of the study dropped out before the study was completed?; - Comparison is made between full participants and those lost to followup, by exposure status; - The outcomes are clearly defined; - The assessment of outcome is made blind to exposure status; - Where blinding was not possible, there is some recognition that knowledge of exposure status could have influenced the assessment of outcome; - The measure of assessment of exposure is reliable; - Evidence from other sources is used to demonstrate that the method of outcome assessment is valid & reliable; - Exposure level or prognostic factor is assessed more than once; - The main potential confounders are identified and taken into account in the design and analysis; - Have confidence intervals been provided? | Not applicable
Diagnostic Accuracy Studies | - Screening test relevant, available for primary care, adequately described; - Study uses a credible reference standard, performed regardless of test results; - Reference standard interpreted independently of screening test; - Handles indeterminate result in a reasonable manner; - Spectrum of patients included in study; - Sample size; - Administration of reliable screening test | - The nature of the test being studied is clearly specified; - The test is compared with an appropriate gold standard; - Where no gold standard exists, a validated reference standard is used as a comparator; - Patients for testing are selected either as a consecutive series or randomly, from a clearly defined study population; - The test and gold standard are measured independently (blind) of each other; - The test and gold standard are applied as close together in time as possible; - Results are reported for all patients that are entered into the study; - A pre-diagnosis is made and reported | - Test clearly described (or referenced); - Was the spectrum of patients representative of the patients who will receive the test in primary care?; - Was the selection process clearly defined?; - Were the index test results interpreted without knowledge of the reference standard results?; - If a threshold was used, was it prespecified?; - Are there concerns that the index test, its conduct, or its interpretation differ from the review question?; - Is the reference standard acceptable for correctly classifying the target?; - Were the reference standard results interpreted without knowledge of the index test?; - Did the whole or partial selection of sample receive reference test; - Was there an appropriate interval between the index test and reference standard?; - Did all patients receive the same reference standard?; - Were all patients included in the analysis?