# References

1 LeBlanc E, Janowsky J, Chan B, Nelson H. Hormone replacement therapy and cognition: Systematic review and meta-analysis. JAMA. 2001;285:1489-99. [pmid: 11255426].
2 Teri L, McCurry S, Logsdon R. Memory, thinking, and aging. What we know about what we know. West J Med. 1997;4:269-75.
3 Keefover R. The clinical epidemiology of Alzheimer's disease. Neurol Clin. 1996;2:337-51. [pmid: 8827175].
4 Burke JR, Morgenlander JC. Update on Alzheimer's disease. Promising advances in detection and treatment. Postgrad Med. 1999;106:85-6, 89-90, 93-4. passim. [pmid: 10560470].
5 Evans DA, Funkenstein HH, Albert MS, et al. Prevalence of Alzheimer's disease in a community population of older persons. Higher than previously reported. JAMA. 1989;262:2551-6. [pmid: 2810583].
6 Jorm AF, Korten AE, Henderson AS. The prevalence of dementia: a quantitative integration of the literature. Acta Psychiatr Scand. 1987;76:465-79. [pmid: 3324647].
7 Breteler MM, Claus JJ, van Duijn CM, Launer LJ, Hofman A. Epidemiology of Alzheimer's disease. Epidemiol Rev. 1992;14:59-82. [pmid: 1289117]. [pmcid: 2547949].
8 Ernst RL, Hay JW. The US economic and social costs of Alzheimer's disease revisited. Am J Public Health. 1994;84:1261-4. [pmid: 8059882]. [pmcid: 1615456].
9 Smith CA, McCleary CA, Murdock GA, et al. Lifelong estrogen exposure and cognitive performance in elderly women. Brain Cogn. 1999;39:203-18. [pmid: 10101041].
10 Chiarello C, McMahon MA, Schaefer K. Visual cerebral lateralization over phases of the menstrual cycle: A preliminary investigation. Brain Cogn. 1989;11:18-36. [pmid: 2789815].
11 Hampson E, Kimura D. Reciprocal effects of hormonal fluctuations on human motor and perceptual-spatial skills. Behav Neurosci. 1988;102:456-459. [pmid: 3395456].
12 Hampson E. Estrogen-related variation in human spatial and articulatory-motor skills. Psychoneuroendocronology. 1990;15:97-111.
13 Yaffe K, Browner W, Cauley J, Launer L, Harris T. Association between bone mineral density and cognitive decline in older women. J Am Geriatr Soc. 1999;47:1176-82. [pmid: 10522949].
14 US Preventive Services Task Force. Guide to Clinical Preventive Services. Report of the U.S. Preventive Services Task Force,. 2nd ed. Baltimore: Williams & Wilkins. 1996.
15 Slavin RE. Best practice synthesis: An alternative to meta-analytic and traditional reviews. Educ Res. 1986;15:5-11.
16 Keating N, Cleary P, Rossi A, Zaslavsky A, Ayanian J. Use of hormone replacement therapy by postmenopausal women in the United States. Ann Intern Med. 1999;130. [pmid: 10189323].
17 Matthews KA, Kuller LH, Wing RR, Meilahn EN, Plantinga P. Prior to use of estrogen replacement therapy, are users healthier than nonusers?. Am J Epidemiol. 1996;143:971-8. [pmid: 8629615].
18 Folsom AR, Mink PJ, Sellers TA, Hong CP, Zheng W, Potter JD. Hormonal replacement therapy and morbidity and mortality in a prospective study of postmenopausal women. Am J Public Health. 1995;85:1128-32. [pmid: 7625511]. [pmcid: 1615815].
19 Derby CA, Hume AL, Barbour MM, McPhillips JB, Lasater TM, Carleton RA. Correlates of postmenopausal estrogen use and trends through the 1980s in two southeastern New England communities. Am J Epidemiol. 1993;137:1125-35. [pmid: 8317442].
20 Barrett-Connor E. Postmenopausal estrogen and prevention bias. Ann Intern Med. 1991;115:455-6. [pmid: 1872493].
21 Lezak M. Neuropsychological Assessement. 3rd ed. New York: Oxford University Press. 1995.
22 Sherwin BB. Estrogen and/or androgen replacement therapy and cognitive functioning in surgically menopausal women. Psychoneuroendocrinology. 1988;13:345-57. [pmid: 3067252].
23 Fedor-Freybergh P. The influence of oestrogens on the wellbeing and mental performance in climacteric and postmenopausal women. Acta Obstet Gynecol Scand Suppl. 1977;64:1-91. [pmid: 331844].
24 Resnick SM, Metter EJ, Zonderman AB. Estrogen replacement therapy and longitudinal decline in visual memory. A possible protective effect?. Neurology. 1997;49:1491-7. [pmid: 9409335].
25 Jadad AR, Moore RA, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17:1-12. [pmid: 8721797].
26 Harris R, Helfand M, Woolf S, et al. Current methods of the Third US Preventive Services Task Force: A review of the process. Am J Prev Med. 2001;20:21-35. [pmid: 11306229].
27 McKhann G, Drachman D, Folstein M, Katzman R, Price D, Stadlan EM. Clinical diagnosis of Alzheimer's disease: report of the NINCDS-ADRDA Work Group under the auspices of Department of Health and Human Services Task Force on Alzheimer's Disease. Neurology. 1984;34:939-44. [pmid: 6610841].
28 Lopez OL, Swihart AA, Becker JT, et al. Reliability of NINCDS-ADRDA clinical criteria for the diagnosis of Alzheimer's disease. Neurology. 1990;40:1517-22. [pmid: 2215942].
29 Blacker D, Albert MS, Bassett SS, Go RC, Harrell LE, Folstein MF. Reliability and validity of NINCDS-ADRDA criteria for Alzheimer's disease. The National Institute of Mental Health Genetics Initiative. Arch Neurol. 1994;51:1198-204. [pmid: 7986174].
30 Tang MX, Jacobs D, Stern Y, et al. Effect of oestrogen during menopause on risk and age at onset of Alzheimer's disease. Lancet. 1996;348:429-32. [pmid: 8709781].
31 Kawas C, Resnick S, Morrison A, et al. A prospective study of estrogen replacement therapy and the risk of developing Alzheimer's disease: the Baltimore Longitudinal Study of Aging [published erratum appears in Neurology 1998 Aug;51(2):654]. Neurology. 1997;48:1517-21. [pmid: 9191758].
32 Amaducci LA, Fratiglioni L, Rocca WA, et al. Risk factors for clinically diagnosed Alzheimer's disease: a case-control study of an Italian population. Neurology. 1986;36:922-31. [pmid: 3714054].
33 Heyman A, Wilkinson WE, Stafford JA, Helms MJ, Sigmon AH, Weinberg T. Alzheimer's disease: a study of epidemiological aspects. Ann Neurol. 1984;15:335-41. [pmid: 6742780].
34 Henderson VW, Paganini-Hill A, Emanuel CK, Dunn ME, Buckwalter JG. Estrogen replacement therapy in older women. Comparisons between Alzheimer's disease cases and nondemented control subjects. Arch Neurol. 1994;51:896-900. [pmid: 8080389].
35 Graves AB, White E, Koepsell TD, et al. A case-control study of Alzheimer's disease. Ann Neurol. 1990;28:766-74. [pmid: 2285263].
36 Broe GA, Henderson AS, Creasey H, et al. A case-control study of Alzheimer's disease in Australia. Neurology. 1990;40:1698-707. [pmid: 2146525].
37 Brenner DE, Kukull WA, Stergachis A, et al. Postmenopausal estrogen replacement therapy and the risk of Alzheimer's disease: a population-based case-control study. Am J Epidemiol. 1994;140:262-7. [pmid: 8030629].
38 Mortel KF, Meyer JS. Lack of postmenopausal estrogen replacement therapy and the risk of dementia. J Neuropsychiatry Clin Neurosci. 1995;7:334-7. [pmid: 7580193].
39 Paganini-Hill A, Henderson VW. Estrogen replacement therapy and risk of Alzheimer disease. Arch Intern Med. 1996;156:2213-7. [pmid: 8885820].
40 Waring SC, Rocca WA, Petersen RC, O'Brien PC, Tangalos EG, Kokmen E. Postmenopausal estrogen replacement therapy and risk of AD: a population-based study. Neurology. 1999;52:965-70. [pmid: 10102413].
41 Harwood DG, Barker WW, Loewenstein DA, et al. A cross-ethnic analysis of risk factors for AD in white Hispanics and white non-Hispanics. Neurology. 1999;52:551-6. [pmid: 10025786].
42 Normand SL. Meta-analysis: formulating, evaluating, combining, and reporting. Stat Med. 1999;18:321-59. [pmid: 10070677].
43 Spiegelhalter D, Thomas A, Best N. WinBUGS Version 1. 2 User Manual. 1.2 ed. Cambridge: MRC Biostatistics Unit; 1999.
44 Egger M, Davey Smith G, Schneider M, Minder C. Bias in meta-analysis detected by a simple, graphical test. Br Med J. 1997;315:629-34. [pmid: 9310563]. [pmcid: 2127453].
45 Duval S, Tweedie R. A Nonparametric "trim and fill" method of accounting for publication bias in meta-analysis. J Am Stat Assoc. 2000;95:89-98.
46 Sutton AJ, Abrams KR, Jones DR, Sheldon TA, Song F. Methods for Meta-analysis in Medical Research. Chichester: John Wiley and Sons. 2000.
47 Polo-Kantola P, Portin R, Polo O, Helenius H, Irjala K, Erkkola R. The effect of short-term estrogen replacement therapy on cognition: a randomized, double-blind, cross-over trial in postmenopausal women. Obstet Gynecol. 1998;91:459-66. [pmid: 9491878].
48 Shaywitz SE, Shaywitz BA, Pugh KR, et al. Effect of estrogen on brain activation patterns in postmenopausal women during working memory tasks. JAMA. 1999;281:1197-202. [pmid: 10199429].
49 Phillips SM, Sherwin BB. Effects of estrogen on memory function in surgically menopausal women. Psychoneuroendocrinology. 1992;17:485-95. [pmid: 1484915].
50 Ditkoff EC, Crary WG, Cristo M, Lobo RA. Estrogen improves psychological function in asymptomatic postmenopausal women. Obstet Gynecol. 1991;78:991-5. [pmid: 1658700].
51 Hackman BW, Galbraith D. Replacement therapy and piperazine oestrone sulphate (`Harmogen') and its effect on memory. Curr Med Res & Opin. 1976;4:303-6. [pmid: 791587].
52 Vanhulle G, Demol P. A double-blind study into the influence of estriol on a number of psychological tests in post-menopausal women. In: van Keep PA, et al., ed. Consensus on MenopauseResearch. Lancaster, England: MTP. 1976.
53 Szklo M, Cerhan J, Diez-Roux AV, et al. Estrogen replacement therapy and cognitive functioning in the Atherosclerosis Risk in Communities (ARIC) Study. Am J Epidemiol. 1996;144:1048-57. [pmid: 8942436].
54 Resnick SM, Maki PM, Golski S, Kraut MA, Zonderman AB. Effects of estrogen replacement therapy on PET cerebral blood flow and neuropsychological performance. Horm Behav. 1998;34:171-82. [pmid: 9799627].
55 Kimura D. Estrogen replacement therapy may protect against intellectual decline in postmenopausal women. Horm Behav. 1995;29:312-21. [pmid: 7490007].
56 Robinson D, Friedman L, Marcus R, Tinklenberg J, Yesavage J. Estrogen replacement therapy and memory in older women. J Am Geriatr Soc. 1994;42:919-22. [pmid: 8064097].
57 Kampen DL, Sherwin BB. Estrogen use and verbal memory in healthy postmenopausal women. Obstet Gynecol. 1994;83:979-83. [pmid: 8190445].
58 Sherwin BB. Cognitive assessment for postmenopausal women and general assessment of their mental health. Psychopharmacol Bull. 1998;34:323-6. [pmid: 9803764].
59 Carlson LE, Sherwin BB. Relationships among cortisol (CRT), dehydroepiandrosterone-sulfate (DHEAS), and memory in a longitudinal study of healthy elderly men and women. Neurobiol Aging. 1999;20:315-24. [pmid: 10588579].
60 Jacobs DM, Tang MX, Stern Y, et al. Cognitive function in nondemented older women who took estrogen after menopause. Neurology. 1998;50:368-73. [pmid: 9484355].
61 Barrett-Connor E, Kritz-Silverstein D. Estrogen replacement therapy and cognitive function in older women. JAMA. 1993;269:2637-41. [pmid: 8487446].
62 Rice MM, Graves AB, McCurry SM, et al. Postmenopausal estrogen and estrogen-progestin use and 2-year rate of cognitive change in a cohort of older Japanese American women: The Kame Project. Arch Intern Med. 2000;160:1641-9. [pmid: 10847257].
63 Matthews K, Cauley J, Yaffe K, Zmuda JM. Estrogen replacement therapy and cognitive decline in older community women. J Am Geriatr Soc. 1999;47:518-23. [pmid: 10323642].
64 Janowsky JS, Chavez B. Sex steroids modify working memory. J Cogn Neurosci. 2000:407-14. [pmid: 10931767].
65 Funk JL, Mortel KF, Meyer JS. Effects of estrogen replacement therapy on cerebral perfusion and cognition among postmenopausal women. Dementia. 1991;2:268-272.
66 Yaffe K, Haan M, Byers A, Tangen C, Kuller L. Estrogen use, APOE, and cognitive decline: evidence of gene-environment interaction. Neurology. 2000;54:1949-54. [pmid: 10822435].
67 Hogervorst E, Boshuisen M, Riedel W, Willeken C, Jolles J. 1998 Curt P. Richter Award. The effect of hormone replacement therapy on cognitive function in elderly women. Psychoneuroendocrinology. 1999;24:43-68. [pmid: 10098219].
68 Paganini-Hill A. Oestrogen replacement therapy and Alzheimer's disease. Br J Obstet Gynaecol. 1996;103:80-6. [pmid: 8624348].
69 Shumaker SA, Reboussin BA, Espeland MA, et al. The Women's Health Initiative Memory Study (WHIMS): a trial of the effect of estrogen therapy in preventing and slowing the progression of dementia. Control Clin Trials. 1998;19:604-21. [pmid: 9875839].
70 Wren BG. Megatrials of hormonal replacement therapy. Drugs Aging. 1998;12:343-8. [pmid: 9606612]. [pmcid: 316480].
71 Yaffe K, Sawaya G, Lieberburg I, Grady D. Estrogen therapy in postmenopausal women: effects on cognitive function and dementia. JAMA. 1998;279:688-95. [pmid: 9496988].