# Discussion

## Conclusions

Table 4 represents a summary of evidence for the questions addressed in this review. Although the study populations and outcome measures differ, the 9 RCTs and 8 cohort studies offer some provisional conclusions about the effects of postmenopausal HRT on cognition. No deleterious effects on cognition have been reported. HRT does not appear to enhance performance on formal cognitive testing for asymptomatic women. However, some studies have found that symptomatic women have improved cognitive performance with HRT, especially in tests of verbal memory and vigilance. There is insufficient evidence about whether progestins attenuate these cognitive effects. Because of the heterogeneous study designs, no conclusions can be drawn about whether specific estrogen formulations or dosages might be more beneficial. Duration of use did not appear to be related to cognitive performance.

Table 4. Summary of Evidence

Key Questions | Evidence codes* | Quality of Evidence
Arrow 6a
1. Does HRT improve or stabilize cognition? | I, II-2 | Fair-poor: studies enlist different patient populations and measure many different outcomes; results for symptomatic women are different than asymptomatic women. Duration of studies is too short to be meaningful. Difficult to draw any conclusions because outcome measures are so diverse.
2 What is the optimal dose and duration of use? | | Fair-poor: too many other factors varied among studies to conclude which type or dose is protective. RCTs lasted only a few months and could not evaluate long-term use.
Arrow 6b
1. Does HRT lower the risk for dementia? | II-2 | Fair-poor: although the meta-analysis supports a protective effect, methodologic limitations and biases exist in individual studies (e.g., healthy user effect, use of proxy interviews, historical data obtained from demented subjects).
2 What is the optimal dose and duration of use? | II-2 | Fair-poor: several studies did not specify type of preparation or dose; results for duration of use were based on different measures and are mixed.

*Study Design Categories(from Guide to Clinical Prevention Services, 1996)^ 14 ^

I: Randomized, controlled trials II-1: Controlled trials without randomization II-2: Cohort or case-control analytic studies II-3: Multiple time series, dramatic uncontrolled experiments III: Opinions of respected authorities, descriptive epidemiology

Ten case-control and 2 cohort studies suggest that HRT users have a 34 percent decreased risk of Alzheimer disease (CI 0.53, 0.82), however, the studies included in the meta-analysis have important methodological limitations. It is unclear whether estrogen is also associated with a decreased risk of other forms of dementia. No conclusions can be drawn about the effects of adding progestins to the regimen, or whether specific dosages or formulations of estrogen are more protective.

## Limitations of the Literature

Studies of HRT use and cognition and dementia have many limitations. Risk estimates may have been falsely low in some of the case-control studies that used proxy respondents, who may not be aware of previous HRT exposure. Also, demented women may have been less likely to receive HRT because of compliance issues or because they were already receiving multiple medications. The relative risk estimates in the cohort studies might have been artificially decreased if women with early, subtle memory changes were less likely to remember previous HRT use. Finally, HRT users may be less likely to develop Alzheimer disease not because of postmenopausal estrogen exposure, but because they are healthier and more educated.

## Future Research

Since women have menopausal symptoms for only a limited time, future research on the effects of HRT on cognitive performance should focus on older, asymptomatic women instead of perimenopausal women. Because HRT users are different from nonusers in many lifestyle and health behaviors, studies should control for health status, health behavior, and education. The ideal studies would be large double-blind placebo-controlled trials with intervention arms containing estrogen with and without progestins. The trial should last for at least several years so that the effects of long-term HRT can be studied, and that subtle changes between treatment groups could be detected. Progestins should be included as part of the intervention arm because of the possibility that it may attenuate some of estrogen's cognitive effects. It should also include the various formulations and dosages of estrogen that are commonly used. Future studies also need to control for the psychological effects of estrogen to ensure that any cognitive effects are not secondary to changes in depressive symptoms. Studies should control for education.

Of crucial importance in designing a study of cognition is deciding which outcome measures to employ. The tests should not have ceiling values and need to be sensitive to very small differences because the effects of estrogen on cognition may be subtle. These tests should examine particular cognitive domains because the evidence indicates that estrogen may have neural and cognitive specificity. In particular, future studies should focus on the cognitive domains most consistently affected in previous studies, such as verbal memory, vigilance, complex attention, mental tracking, concept formation and reasoning, and motor speed. Future studies should include measures of the ability to care for oneself, live independently, and complete activities of daily living

Estrogen's cognitive and neural specificity should also be considered when interpreting the results of future research studies, including the two ongoing primary prevention trials of HRT and cognition, the Women's Health Initiative Study of Cognitive Aging (WHISCA)^ 69 ^ and the Women's International Study of Long Duration Oestrogen after Menopause in the United Kingdom.^ 70 ^ The results of these trials are still several years away but may answer many of the questions raised by observational data.