# Results

## Effects on Cognition

See Figure 1, Arrow 6a

### 1. Does HRT improve or stabilize cognition?

The literature search identified 9 randomized controlled trials (Appendix 5, Evidence Table 1), and 8 cohort studies (Appendix 5, Evidence Table 2) that used formal testing to measure the effects of HRT on cognition of women without dementia.

The randomized controlled trials are dissimilar in several ways. Three of the studies used a cross-over design,^22, 47, 48^ while the rest used separate experimental and placebo groups. The mean age of the women in the studies ranged from 45 to 80 years. Three studies included women immediately after a total abdominal hysterectomy/bilateral salpingo-oophroectomy,^22, 49, 50^ while 6 other studies included community volunteers with only a small percentage of women with surgical menopause.^23, 47, 48, 51, 52^ Some of the studies included women with menopausal symptoms,^22, 23, 49, 52^ while one specifically excluded symptomatic women.^ 50 ^ More than 40 different cognitive tests were used as outcome measures in these studies, and 30 of these tests were used by only one investigator (Appendix 6). Only 7 tests were used by more than 2 studies, and even when tests were repeated by several investigators, administration was not uniform. Only 2 studies, both done by the same research group, used the identical estrogen formulation and dose. Duration of use ranged from 21 days to 6 months. When analyzing the data, some studies performed between-group comparisons while others looked at within-group changes. Because of these differences among studies, results were not combined quantitatively. Instead, we grouped tests according to the cognitive process they measured: memory, attention, concept formation and reasoning, motor speed, mental status, verbal function, and learning ability (Table 1).

Figure 1. Benefits of Hormone Replacement Therapy

Analytic Framework 1

SERMs=Selective estrogen receptor modulators

#### Memory

Memory is the first process to be affected in Alzheimer disease; thus, memory tasks are often used to track dementia onset. Although cross-sectional studies suggest that HRT affects memory, especially verbal memory,^53-57^ results from randomized controlled trials and cohort studies are conflicting.

In one study^ 51 ^ of 18 women with menopausal symptoms, 9 women given 1.5 mg of piperazine oestrone for 6 months scored, on average, 5 points higher than baseline on a memory battery (the Guild Memory Test). The 9 women given placebo had a 1.8 point decrease in scores. The overall increase in the estrogen group's score can be attributed to 3 women whose scores increased by 13 to 20 points while on estrogen. The other women in the estrogen arm had either minor improvements or even decreases in scores.

Six studies, 2 randomized controlled trials and 4 cohort studies, used 4 tests of immediate verbal recall.^49, 58-62^ In these tests, subjects are shown verbal stimuli, such as lists of words, word pairs, or paragraphs, and asked to recall them immediately after seeing them.^ 21 ^ One randomized controlled trial^ 49 ^ and one randomized cross-over study,^ 58 ^ both done by the same investigators, found that 10 women randomized to intramuscular estradiol for 3 months performed better on 2 tests of immediate verbal recall. The women receiving estrogen immediately recalled 3.5 to 5 more words of a paragraph compared to when they were not receiving estrogen. There was no improvement in the placebo groups.^58, 49^ On another test, at the end of the study the placebo group recalled 5 fewer word pairs, but there was no change in the number of pairs recalled by women in the estrogen group.^ 49 ^ However, the women in both of these studies were immediately post-operative for total abdominal hysterectomy/bilateral salpingo-oophorectomy and likely had menopausal symptoms, though these were measured in only one study. When the same research group used a cohort design to study elderly women (average age 73 to 74 years) who were unlikely to be symptomatic, there was no longer a significant difference in scores on these tests between long-term users and nonusers.^ 59 ^

The third test of immediate verbal recall, the selective reminding test, was used in the 3 cohort studies. In this test, subjects are asked to recall a list of words and with each successive trial are reminded of the words they omitted.^ 21 ^ In one cohort study, 81 users recalled 1.58 more words and 646 nonusers recalled 0.41 fewer words after 2.5 years of follow-up.^ 60 ^ However, in the Rancho Bernardo cohort, 394 ever-users of HRT did not perform better on this same test than the 406 nonusers.^ 61 ^ The younger women in the Rancho Bernardo cohort performed significantly better than older women, suggesting that this test was sensitive enough to detect differences between groups. In addition, the users in the Rancho Bernardo cohort had a longer duration of use than those in the previous study (16.5 years versus 2.5 years), and were followed for longer (15 years versus 2.5 years).^ 61 ^ A third study^ 59 ^ compared the immediate selective reminding test scores of 10 long-term users to 27 nonusers. Although the users had higher baseline scores, there was no difference in the amount the scores changed over 18 months.

"Delayed verbal recall" refers to recall of the same verbal stimuli after 15 to 60 minutes. Estrogen exposure was associated with improvement in at least one test of delayed verbal recall in 2 out of 4 studies. Two randomized controlled trials that found improvements in immediate paragraph recall did not find that these benefits extended to delayed recall of a paragraph.^22, 49^ One of these trials found that while the placebo group recalled 2.3 fewer word pairs after the delay period, the average score of the estrogen group did not change.^ 49 ^ However, this result was not confirmed by a recent cohort study by the same research group.^ 59 ^

Two of the 3 cohort studies that looked at the delayed portion of the selective reminding test found an effect of estrogen.^59-61^ The studies found that after a 15-minute delay, users recalled 0.64 more words from a word list while nonusers recalled 0.41 fewer words. However, the scores on the other tests of delayed verbal recall that were used in these cohort studies did not differ between exposure groups.^59, 61^

On visual memory tests, subjects are shown configural stimuli (such as shapes and figures) and usually respond through visuomotor response (such as drawing). Six studies used 5 tests of visual recall. Eighteen women who became users of postmenopausal estrogen during the course of followup in the Baltimore Longitudinal Study of Aging had 0.28 fewer errors on the Benton Visual Retention test after 6.5 years of followup while never users had 1.67 more errors.^ 24 ^ However, 2 trials did not find that women given estrogen for 3 months did better than those given placebo on this same test.^47, 52^ No study found that women exposed to estrogen did better on 3 other tests of visual recall.^49, 59, 61^

#### Attention

Although performance on tests of attention is not as useful as performance on memory tests in predicting Alzheimer disease, 10 studies^23, 47-50, 52, 58, 59, 61, 63^ have looked at the effects of HRT on various aspects of attention. The most recent randomized controlled trial^ 48 ^ used nonstandardized tests to measure "working memory," which refers to the "ability to hold information in mind, to initialize information, and to use information to guide behavior without the aid of external cues."^ 21 ^ Although this study did not find a difference in scores according to estrogen exposure, the ease of the tests may have precluded finding a difference (ceiling effect). The study did find that the women given estrogen had increased activation of several areas of the brain on functional magnetic resonance imaging when performing the working memory tasks.^ 48 ^ Two other studies used tests to try to evaluate working memory; neither study found a difference in scores according to estrogen exposure.^47, 64^ It is unlikely that the null results are secondary to a ceiling effect, since the results in at least one of these studies were measured in milliseconds.^ 47 ^

Complex attention tasks require both attention and concentration. Performance on 2 standardized tests of complex attention, the digit symbol and trail making tests, was not affected by estrogen in any of the 5 studies that used them as cognitive measures.^47, 50, 52, 61, 63^ However, one of these trials found that nuns given estrogen had borderline improvement on another nonstandardized test of attention, the spot-pattern test (p=0.08).^ 52 ^ Another study found that estrogen-treated women did better on a Swedish test of attention.^ 23 ^ Both of these latter two studies found that women treated with estrogen had more improvement in symptoms than the untreated subjects. In fact, the latter study states that "there was a remarkable improvement in the ability to sleep in all oestrogen-treated patients,"^ 23 ^ and so the subjects on estrogen may have done better because they were less fatigued.

Women using estrogen showed improvement compared to the placebo group on 2 of the 13 tests of mental tracking, which includes such tasks as arithmetic, repeating numbers backwards, and repeating months backwards.^23, 47, 52, 61^ Although one randomized controlled trial found that estrogen exposure was related to performance on digit span (a test requiring subjects to repeat a list of 2 to 8 numbers backwards),^ 22 ^ the women randomized to estrogen in 3 other randomized controlled trials did not perform better on this test.^47, 50, 52^ Two of these studies^50, 52^ used women who were post-operative from total abdominal hysterectomy/bilateral salpingo-oophorectomy; however, the women had to have fewer than 4 hot flashes in a 2-week period to qualify for one of them.^ 50 ^ The 24 women randomized to oral conjugated equine estrogen (0.625 and 1.25 mg) for 3 months did not perform better on the test of digit span.^ 50 ^ However, all of the pre-treatment scores being in the normal range may have precluded finding a difference (ceiling effect).

A cross-over study of 62 women also did not find that women given estrogen for 3 months did better on the digit span test.^ 47 ^ Since this study was the largest of the randomized trials and reported a power of 90 percent, it is likely that the women in the other study^ 50 ^ may have done better on the digit span test secondary to improvement in menopausal symptoms. Indeed, when this research group used a cohort design to look at asymptomatic women, there was no difference between users' and nonusers' performances on another test of mental tracking, the visual memory span.^ 59 ^

The results on yet another test of mental tracking, the Stroop color word test, are also conflicting. A randomized controlled trial of 21 symptomatic women in Germany found that while the placebo group had no change in scores, the estrogen users were better able to read the word of a color despite it being printed in a different color, or to state the color of the word even though the word stood for another color.^ 23 ^ However, these results were not confirmed by the later, larger study.^ 47 ^

Of the 3 studies that measured vigilance, 2 found that estrogen improved women's abilities to sustain attention. In both of these studies, women were symptomatic with fatigue, sleep problems, hot flashes, and depression.^23, 52^ In contrast, a larger randomized cross-over trial did not find that women given estrogen performed better on 2 sensitive tests of vigilance.^ 47 ^

#### Concept formation and reasoning

Concept formation and reasoning refers to the quality or process of thinking. It was tested in 3 studies with conflicting results. While a randomized cross-over study and a cohort study found that subjects given estrogen improved in their abstract reasoning scores compared to when they took placebo,^22, 62^ a New York based cohort study did not find that scores for ever-users changed over 2.5 years compared to never-users.^ 60 ^

Table 1. Summary of Cognitive Test Results

Cognitive function | Reference | Positive tests/total tests* | Subject profile-Studies with positive tests | Education adequately controlled for in studies with positive tests** | Explanation of results and magnitude of effect§
Memory
Memory battery | 51¥ | 1/1 | Symptomatic | No | Increase of 8.0 with use
Immediate verbal recall | 22# †,49,59,60,61¥,62 | 4/9 | Symptomatic | Yes in 2/3 studies | Paragraph recall: increase of 2.2, 5.9¶, and 11.5¶ with use; selective reminding: increase of 2.4 and 2.8¶ with use; associate learning: increase of 1.7 and 14.0¶ with use
Delayed verbal recall | 49,59,60,61¥ | 3/8 | Asymptomatic/Symptomatic | Yes in 2/3 studies | Paragraph recall: change of -5.4 and 1.52¶ with use; selective reminding: increase of 16.6¶ and 21.6¶ with use; associate learning: increase of 2.6 and 19.3¶ with use
Visual memory | 24,47,49,52, 59, 61¥ | 1/9 | Not stated | Yes | Fewer errors made by users in 1 study; 8 measures in 5 other studies were negative
Attention
Working memory | 47¥,48,64 | 0/5 | N/A | N/A | Increase of 0.2 ^‡^ , 0.7 ^‡^ , and 3.2 with use
Complex attention | 23#,47,50, 52¥, 61,62,63 | 2/9 | Symptomatic | No | Positive findings were on 2 tests not repeated by other studies; 1 was only of borderline significance (P=.08); 4 studies found no effects on digit symbol; 2 studies found no effect on trail making
Mental tracking | 22#,23#, 47¥,,49,50¥, 52¥,59, 61,62 | 2/14 | Symptomatic | Yes in 1/2 studies | 1 of 5 studies had improvement on digit span ^‡^ ; change of -1.67, 2.25 and 11.25¶ with use
Vigilance | 47¥,23#,52¥ | 3/5 | Symptomatic | No | 5 different tests were used; in 1 study, visual search improved by 0.4 to 4 min¶ and sorting improved by 3 to 4 min¶ with use; other positive result was only of borderline significance (P=.07)
Concept Formation & Reasoning | 22#,60¥,62, | 2/3 | Asymptomatic/Symptomatic | Yes | Abstract reasoning; increase of 3.4¶ and 11.0¶ with use
Motor Speed | 47¥,22#,23# | 2/3 | Symptomatic | Yes in 1/2 studies | Clerical speed and accuracy: increase of 9.5¶ with use; reaction time: 160-millisecond improvement with use
Mental Status | 61¥,62,63¥, 65¥,66 | 2/5 | Asymptomatic | N/A | Dementia screening exams ^‡^ : increase of 0.89 & 0.90¶ with use
Verbal Functions & Language | 59,61¥,62,65¥ | 1/4 | Asymptomatic | N/A | Category fluency and retrieval: increase of 3.4¶ & 6.0 with use

* Positive test indicates that women using estrogen scored significantly higher (at 0.10 significance level) than nonusers. Total tests refers to the total number of test sessions on that cognitive measure. The same test may have been used by more than one study and some studies may have used more than one type of test to measure that cognitive function.

** Either baseline education was measured and was equal between groups or was adjusted for in the analysis.

§ Scores normalized using a total of 100 points.

# Scores derived from figure and represent estimates of effect magnitude.

† Denominator not reported so estimated by authors.

¶ Significant (P<.05).

¥ No data given in study.

‡Ceiling effect may have contributed to null findings.

#### Motor speed

Although motor speed is not very predictive of Alzheimer disease because it is not affected until later stages of the disease, losses in motor speed will affect performance on any task that requires a motor response. For example, motor slowing can look like a reasoning deficit if the reasoning task requires any sort of motor response or manipulation. Motor speed, as measured by simple reaction time, was improved by postmenopausal estrogen in one study^ 23 ^ but not another.^ 47 ^ A randomized controlled trial that found estrogen improved reaction time by over 100 milliseconds included symptomatic women.^ 23 ^ A larger, more recent trial did not find a difference in reaction time between exposure groups, even though measurements were also in milliseconds.^ 47 ^ Women given estrogen had improvement in clerical speed and accuracy in another study.^ 22 ^

#### Dementia screening measures

Three early studies did not find that women given estrogen had improvement in mental status as measured by the mini-mental status exam or Cognitive Capacity Screening Exam.^61, 63, 65^ However, this is not unexpected, given that the simplicity of the mental status exam for cognitively intact women might preclude finding subtle differences (ceiling effect). Two recent cohort studies using more sensitive multidimensional tests of cognition found that over time users performed better than nonusers.^62, 66^

#### Verbal function

Only one^ 62 ^ of 4 studies found that users performed better than nonusers on tests of verbal functions and language skills.^59-62^ Users of unopposed estrogen were more fluent in naming categories.^ 62 ^

#### Influence of symptoms

In the randomized controlled trials, changes in cognitive measures were most likely to occur in symptomatic women (Table 2). In all 4 trials of women with somatic complaints, HRT improved at least one cognitive function. The cognitive processes that were most consistently improved were verbal recall^22, 49, 59, 60^ and vigilance,^23,52^ although complex attention,^23, 52^ mental tracking,^22, 52^ concept formation and reasoning,^ 22 ^ and motor speed^22, 23^ were also affected.

Table 2. Influence of Symptoms on Results of Randomized Controlled Trials

Subject profile | Reference Number | Results
Symptomatic Subjects had various complaints, including hot flashes, sleep problems, depression, fatigue, chest pressure | 22 49 23 51 52 | All of the studies found that women given estrogen had improvement in at least one cognitive test
Not symptomatic Subjects had fewer than 4 hot flashes during 2 week trial | 50 | No improvement in cognition in women using estrogen
Not known if subjects were symptomatic | 47 48 | Neither study found an improvement in cognition in women using estrogen

Symptomatic women may perform better on cognitive testing when given estrogen because they sleep better, are less fatigued, have fewer hot flashes, or have improved mood. Many of the effects were in tests of attention, which are particularly sensitive to anything that elevates mood. Alternatively, the subtle effects of estrogen on cognition may be apparent only in subjects who are not performing at maximum cognitive ability because of fatigue and loss of sleep secondary to menopausal symptoms.

One study that looked at asymptomatic women did not find that women given estrogen had improved performance on tests of immediate verbal recall or attention.^ 50 ^ The largest study, a cross-over study of 62 women using transdermal estrogen for 3 months, also did not find any improvement in women exposed to estrogen on tests of immediate verbal recall, visual memory, attention (including working memory), or motor speed.^ 47 ^ This study used sensitive tests (outcomes measured in milliseconds) and had a power of 90 percent to detect a difference between users and nonusers.

#### Effects of progestins

All of the randomized controlled trials used unopposed estrogen. The 4 cohort studies that looked at the type of HRT found that most (greater than 70 percent) of the women used unopposed oral conjugated equine estrogen.^59-61, 65^ None of these studies looked at subgroups that used progestins. One small, nonrandomized trial of 19 symptomatic women used estradiol combined with progestins. They concluded that progestins did not attenuate the cognitive benefits of estrogen because users of the combined regimen had more improvement on a test of delayed verbal recall than nonusers. However, unlike the results in several previous randomized controlled trials of symptomatic women, immediate verbal recall was not enhanced by HRT exposure.^ 67 ^

One recent cohort study looked separately at users of unopposed and combined HRT regimens. Women currently using unopposed estrogen had more improvement in global cognition, abstract reasoning, and category fluency, compared with never-users. However, current users of estrogen combined with progestin had a decline in global cognition and mental tracking scores.^ 62 ^

### 2. What is the optimal dose and duration of use?

Most of the women in the cohort studies used oral estrogen, but dosages were not given. Therefore, information on dosing comes from randomized controlled trials that used a variety of preparations and doses. Only 3 of the randomized controlled trials used oral conjugated equine estrogen in doses commonly prescribed in the U.S. (either 0.625 or 1.25 milligrams), and none found that women randomized to estrogen performed better on several tests of cognition.^48, 64, 50^ A study using transdermal estrogen also did not find a difference in cognitive test scores between the estrogen and placebo groups 47. Although the 2 studies that used intramuscular estradiol found that estrogen favorably affected women's performances on cognitive testing, these studies were done by the same author and enrolled symptomatic women.^22, 49^ Some of the early studies that found beneficial effects on cognition used larger doses of oral estrogen than are currently prescribed.^51, 52^ Although it is tempting to conclude that the different estrogen formulations or dosages may have contributed to the studies' disparate findings, too many other factors vary among studies to draw any conclusions about which formulation or dose may be most protective.

The trials lasted only several months, and so information about duration of use comes from the cohort studies. The one cohort study that looked at duration found that users of greater than 20 years scored 1 point higher on category fluency, a test of verbal functions and language skills.^ 61 ^ However, these long-term users did not perform better on any of the other 8 measures of cognition. Although one cohort study looking at recency of use actually found that past users had more benefit than current users,^ 63 ^ another study found that past users had scores intermediate between current and never-users.^ 62 ^

## Summary

- It is difficult to compare studies about HRT and cognitive function and report overall conclusions because the studies enlist different patient populations and report different cognitive test outcomes.
- Only studies that used women with menopausal symptoms found that estrogen improved cognitive performance. The most consistent findings in these studies appeared to be on verbal memory and vigilance tests, although effects on complex attention, mental tracking, concept formation and reasoning, and motor speed were also seen.
- Postmenopausal estrogen does not seem to enhance asymptomatic women's performance on cognitive testing.
- There is insufficient evidence about the effects of the addition of progestins to estrogen. One non-randomized trial of a small number of women found that progestins may attenuate some of estrogen's effects on immediate verbal recall in symptomatic women.
- The randomized controlled trials are too dissimilar in design to conclude that any formulations or dosage may be more beneficial for cognitive function in symptomatic women.
- Only one cohort study looked at duration of use, and it did not find that long-term users were performing consistently better over time than never-users.

## Effects on Dementia

See Figure 2, Arrow 6b

### 1. Does HRT lower the risk for dementia?

Ten case-control studies (Appendix 5, EvidenceTable 3) and 2 cohort studies (Appendix 5, Evidence Table 4) on the association between HRT use and risk of dementia were identified from the literature review and met inclusion criteria.

The early case-control studies did not find an association between HRT and dementia (Odds Ratios [ORs] of 0.78 to 2.38) and all received poor quality scores.^32, 33, 35, 36^ HRT use was only one of many risk factors evaluated in these studies. These early studies all used proxy interviews to determine exposure to HRT in both cases and controls, and none used blinded interviewers. Two of the studies evaluated the agreement in reported HRT use between controls and their surrogates and found good agreement (Kappa values were 0.63 and 0.64).^33, 35^ The studies were relatively small, with the number of users ranging from 8 to 21, or about 8 to 18 percent of the study population. All of the studies controlled for age, but only one study controlled for education.^ 33 ^

Figure 2. Adverse Effects of Hormone Replacement Therapy

Analytic Framework 2

SERMs=Selective estrogen receptor modulators

DVT/PE=Deep-vein thrombosis/pulmonary embolus

All but one of the case-control studies published since 1990 found a significantly decreased risk of dementia among HRT users (ORs of 0.33 to 1.1).^34, 37-41^ In some of these studies, however, the method of determining estrogen exposure may have resulted in a falsely low rate of HRT use in cases. For example, several of the studies used proxy interviews for cases but self-interviews for controls.^34, 38, 41^ Because proxy informants would be expected to have less knowledge about HRT use, the rate of estrogen exposure in cases may have been underestimated. These studies were rated poor.

The largest case-control study, which was nested in the Leisure World Cohort and also rated poor, used data from death certificates to determine dementia outcomes, and defined HRT exposure with a self-administered questionnaire completed an average 5 years before death. Because dementia is insidious in onset and women with cognitive decline were not excluded at baseline, cases might have been less likely than controls to remember previous estrogen use at the time of the original questionnaire. This might have falsely lowered the percentage of users among demented subjects and led to the finding of decreased risk among HRT users (OR 0.65; 95% CI 0.29, 0.88).^ 39 ^

Three studies used more objective measures such as medical or pharmacy records to determine estrogen use, but their results are conflicting. One poor-quality study stated that "medical records were the primary source material,"^ 38 ^ but did not specify how the material was abstracted or how much of the information on HRT use was actually derived from proxy interviews. They found that HRT users had a 45 percent reduction in risk of dementia (CI 0.26, 1.16).

A good-quality study enlisted subjects from the Group Health Cooperative of Puget Sound, a health maintenance organization (HMO) in Seattle, Washington.^ 37 ^ Cases were identified from the Alzheimer Disease Patient Registry, which uses NINCDS-ADRDA criteria to diagnose Alzheimer disease. The HMO's computerized pharmacy records were then used to identify subjects who had filled a prescription for any form of postmenopausal estrogen since 1977. Proxy interviews were used for information prior to 1977. Almost half of both groups used HRT, which is a higher percentage of users than in the general U.S. population and suggests a highly selected study population. Also, because HRT use was defined through prescription data, women who never took or discontinued the medication within days after first filling the prescription would be classified as users. Such misclassification could have biased the results to the null. After controlling for age and history of hysterectomy before and after age 55, this study found no decreased risk among ever-users of HRT (OR 1.1; 95% CI 0.6, 1.8).

The Rochester Epidemiology Project records-linkage system was used to identify cases and controls in a fair-quality study.^ 40 ^ Dementia diagnosis and HRT use were determined through blinded record abstraction. After controlling for age, education, and length of time in the linkage system, this study found that users of any form of estrogen for greater than 6 months after the menopause but before the onset of Alzheimer disease was associated with a 58 percent reduction (OR 0.42; 95% CI 0.18, 0.96).

The strongest evidence for an association between HRT use and Alzheimer disease comes from 2 fair-quality cohort studies (Appendix 5, Evidence Table 4). The Manhattan Study of Aging cohort was formed from Medicare listings and senior housing centers.^ 30 ^ The average age of subjects was 74.2 years. One hundred fifty-six ever-users of postmenopausal estrogen and 968 nonusers were followed for 1 to 5 years for the development of Alzheimer disease as defined by the NINCDS-ADRDA criteria. After controlling for education, age, and ethnicity, the study found that users were significantly less likely to develop Alzheimer disease (Relative Risk (RR) 0.5; 95% CI 0.25, 0.9). Users who developed Alzheimer disease also had a later age of onset. One problem with this study, however, was that subjects developed Alzheimer disease within 5 years of the initial interview. Given that a diagnosis of Alzheimer disease lags symptom onset by 3.5 to 5.5 years,^ 8 ^ cases may have been less likely to remember HRT usage. Also, concerns about compliance in women with mild cognitive problems could have made it less likely that they were prescribed HRT.

The Baltimore Longitudinal Study of Aging followed 230 HRT users and 242 nonusers aged 28 to 94 (average 61.5) for up to 16 years, which makes it less likely that the Alzheimer disease subjects had subtle memory problems at the beginning of the study.^ 31 ^ They evaluated the subjects every 2 years for the development of Alzheimer disease as diagnosed by the NINCDS-ADRDA criteria. After controlling for age and education, they found that relative risk of dementia in users was 0.457, with a 95% confidence interval of 0.209-0.997.

The results of these 10 case-control and 2 cohort studies were combined by meta-analysis (Figure 3). The test of homogeneity indicated that the studies were homogeneous (p>0.10). The fixed and random effects models did not differ, so we present only the random effects model. When the studies were combined quantitatively, the summary odds ratio was 0.66 (CI 0.53, 0.82). When case-control or cohort studies were analyzed separately, the estimates did not change (Table 3). Excluding poor-quality studies or studies with potential proxy bias did not changes these estimates. Also, restricting the analysis to studies that looked only at Alzheimer disease or used only NINCDS criteria did not change the estimate, although the confidence intervals were wider given the smaller number of studies. Sensitivity analysis using different prior distributions and using various values for confidence intervals also did not significantly change the risk estimates.

Table 3. Summary of Meta-analysis Results of HRT and Dementia

Studies included | Number of Studies | References | Fixed | Effects | Random | Effects | Test of Homogeneity X2 (p value)
Studies included | Number of Studies | References | Odds Ratio | 95% Confidence Interval | Odds Ratio | 95% Confidence Interval | Test of Homogeneity X2 (p value)
All studies | 12 | 30-41 | 0.66 | 0.55-0.78 | 0.66 | 0.53-0.82 | 11.92 (p>0.10)
Case-control only | 10 | 32-41 | 0.69 | 0.58-0.83 | 0.71 | 0.56-0.91 | 11.04 (P>0.10)
Cohort only | 2 | 30, 31 | 0.50 | 0.30-0.77 | 0.50 | 0.30-0.80 | 0.87 (P>0.10)
Excluding poor quality studies | 4 | 30, 31, 37, 40 | | | 0.64 | 0.32-1.06
Excluding studies with proxy bias | 9 | 30 - 33, 35-37, 39, 40 | | | 0.72 | 0.55-0.96
Alzheimer disease only | 11 | 30-37, 39-41 | | | 0.68 | 0.51-0.89
Alzheimer disease by NINCDS-Rcriteria | 7 | 30, 31, 34-37, 41 | | | 0.67 | 0.46-0.92
Alzheimer disease by NINCDS-R criteria-case -control only | 5 | 34-37, 41 | | | 0.77 | 0.46-1.16
All studies except Heyman^ 33 ^ | 11 | 30-32, 34-41 | 0.65 | 0.55-0.77 | 0.65 | 0.52-0.80
Using confidence intervals for Heyman^ 33 ^ from Yaffe^ 71 ^ | 12 | 30-41 | 0.67 | 0.57-0.79 | 0.68 | 0.53-0.84
Using t distribution | 12 | 30-41 | | | 0.67 | 0.53-0.81
Using Yaffe^ 71 ^ as prior distribution | 12 | 30-41 | | | 0.67 | 0.51-0.87

NINCDS-R = National Institute of Neurological and Communicative Disorders and Stroke

Figure 3. Results of Meta-Analysis of Dementia Studies

Although the summary odds ratio indicates a decreased risk of dementia in women exposed to postmenopausal estrogen, confounders may explain this relationship. Women who use HRT are more educated,^16, 17, 19^ and formal education has been found to be protective against dementia.^3, 7^ However, several of the studies controlled for education and still found a decreased risk.^34, 40, 41^ HRT users are also healthier and have healthier lifestyles, and physical health status has been associated with cognitive changes with advancing age.^ 2 ^ Users are also younger than nonusers, and the most important risk factor for dementia is advancing age. All of the studies controlled for age.

Only one study using pharmacy records looked at the effect of progestins. Although the number of progestin users was small, adding progestins to the logistic regression model did not change the risk estimates, indicating that it was not a significant confounder.^ 37 ^ Another study did not find that excluding women who reported a surgical menopause (who are usually taking unopposed estrogen) affected the results.^ 31 ^

Only one study looked at dementia other than Alzheimer disease.^ 38 ^ This study included women with dementia secondary to ischemic vascular disease. Women who used HRT had a 50 percent decreased risk of developing ischemic vascular disease, although this result was not statistically significant (OR 0.50; CI 0.26, 1.20).

### 2. What is the optimal dose and duration of use?

The older case-control studies do not specify the formulation of HRT used.^32, 33, 35, 36^ The more recent case-control studies define HRT exposure as the use of any form (oral, IM, topical, suppository) of estrogen after menopause.^34, 37, 39, 40^ The cohort studies included only women who used oral or transdermal forms of estrogen.^30, 31^ In the studies that looked at this information, 66 to 95 percent of the women used oral conjugated equine estrogen.^34, 37, 40^ While one study found that only oral estrogen was associated with a decreased risk of Alzheimer disease,^ 37 ^ another study found that oral, injectable, and/or cream forms of estrogen were all associated with a decreased risk.^ 39 ^

Although one study found that taking at least 1.25 mg of oral conjugated estrogen was associated with greater dementia risk reduction,^ 39 ^ another study did not find that cumulative dose was associated with dementia risk.^ 40 ^

The results for duration of use were also mixed. In the Manhattan Study of Aging, users with more than one year of use had a relative risk of 0.13 (CI 0.02, 0.92) compared to a relative risk of 0.47 (CI 0.20, 1.10) in users for less than one year.^ 30 ^ In another study only users for more than 6 months had a decreased risk.^ 40 ^ While one case-control study^ 68 ^ and one cohort study^ 30 ^ found that increasing duration of use was associated with a decreased risk of dementia, another case-control study and cohort study did not confirm this finding.^31, 37^.

Studies that looked at currency of use also found different results. Two of the case-control studies that looked only at current users found a decreased risk,^34, 38^ while a third did not.^ 33 ^ Another study found that the odds ratio for the risk of dementia in current users was 0.6 (CI 0.3, 1.2) compared to 1.7 (CI 0.9, 3.2) in former users.^ 37 ^ However, women with dementia may be less likely to be prescribed HRT because of compliance issues or because of complex medication regimens (prescribing bias).

## Summary

- Based on data from 12 case-control and cohort studies, there appears to be a 34 percent decreased risk of dementia among HRT users (OR 0.66, CI 0.53, 0.82).
- The studies upon which this risk estimate is based have several limitations. -In case-control studies, proxy respondents may not be aware of previous HRT use. -In case-control studies, demented women may have been less likely to receive HRT because of compliance issues and multiple medications. -In cohort studies, women with early memory problems may not have remembered previous HRT use. -Women who use HRT are healthier ("healthy user bias").
- There are insufficient data about the addition of progestins.
- There are insufficient data about other forms of dementia.
- There are insufficient and conflicting data about a dose-response or duration effect.
- Although some studies have found that current users had a decreased risk, this could be secondary to prescribing bias.